# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlorobenzene
CAS Numbers: | 108-90-7
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: Available information regarding adverse effects following acute-duration inhalation exposure to chlorobenzene is limited to evaluations of lethality (Rozenbaum et al. 1947), developmental toxicity studies of rats and rabbits in which no adverse effects were observed at exposure concentrations as high as 590 ppm (John et al. 1984), and a study that evaluated effects of a single 30-minute exposure at 2,990–7,970 ppm (Shell Oil Co. 1991).

Agency Contacts (Chemical Managers): Breanna Alman, MPH

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlorobenzene
CAS Numbers: | 108-90-7
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: Available information regarding the effects of intermediate-duration inhalation exposure to chlorobenzene is limited. Chlorobenzene exposure-related liver effects (increased liver weight and increased incidence of hepatocellular hypertrophy) and kidney effects (renal lesions including chronic interstitial nephritis and foci of regenerative epithelium) were reported for two generations of parental male (but not female) rats repeatedly exposed to chlorobenzene vapor at 150 ppm (NOAEL of 50 ppm) for 18–20 weeks (Nair et al. 1987). NIOSH (1977) reported significantly increased relative liver and kidney weights 31 and 13%, respectively, greater than controls) among rats (but not rabbits) repeatedly exposed to chlorobenzene vapor for up to 24 weeks at 250 ppm; however, there were no increased incidences of exposure-related histopathological liver or kidney lesions. Similar exposure of rabbits resulted in no significant changes in liver or kidney weight and no evidence of exposure-related increased incidence of histopathological liver or kidney lesions. No effects on liver or kidney were noted among dogs repeatedly exposed to chlorobenzene vapor at concentrations as high as 453.2 ppm for up to 6 months (Monsanto Co. 1980). No data were located to support the findings of liver and kidney effects in the 2-generation study of rats (Nair et al. 1987) at exposure levels as low as 150 ppm. No intermediate-duration inhalation MRL was derived for chlorobenzene because intermediate-duration inhalation studies of rats and rabbits (NIOSH 1977) and dogs (Monsanto Co. 1980) did not identify effects on liver or kidney at exposure levels approximately 2–3 times higher than the LOAEL of 150 ppm for parental male rats of the 2-generation study (Nair et al. 1987).

Agency Contacts (Chemical Managers): Breanna Alman, MPH

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlorobenzene
CAS Numbers: | 108-90-7
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No exposure-response human or animal data are available for the chronic-duration inhalation exposure to chlorobenzene.

Agency Contacts (Chemical Managers): Breanna Alman, MPH

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlorobenzene
CAS Numbers: | 108-90-7
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: Limited studies that evaluated the effects of acute-duration oral exposure to chlorobenzene found adverse effects only at doses that also caused lethality (Monsanto Co. 1977; NTP 1985).

Agency Contacts (Chemical Managers): Breanna Alman, MPH

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlorobenzene
CAS Numbers: | 108-90-7
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL | 0.07mg/kg/day
Critical Effect: | Hepatic effect; bile duct hyperplasia
Reference: | Monsanto Co. 1967a
Point of Departure: | BMDL_10_ of 9.59 mg/kg (BMDL_ADJ_ of 6.85 mg/kg/day)
Uncertainty Factor: | 100
LSE Graph Key: | 9
Species: | Dog

MRL Summary: An intermediate-duration oral MRL of 0.07 mg/kg/day was derived for chlorobenzene based on dose-related hepatic changes (bile duct hyperplasia) in dogs treated orally (via capsule) with chlorobenzene 5 days/week for 13 weeks (Monsanto Co. 1967a). The MRL is based on a BMDL_10_ of 9.59 mg/kg, which was adjusted to continuous duration exposure to a BMDL_ADJ_ of 6.85 mg/kg/day and divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability). 1967a

Selection of the Critical Effect: There are no intermediate-duration oral studies in humans. Several intermediate-duration oral studies are available for rats or mice treated with chlorobenzene by gavage (Monsanto Co. 1967b; NTP 1985) or dogs treated via capsule (Monsanto Co. 1967a). NOAELs and LOAELs identified in these studies are summarized in Table A-1. The effects observed at the lowest LOAEL (55 mg/kg/day for liver and kidney effects in dogs) were considered to represent the critical effects for deriving an intermediate-duration oral MRL for chlorobenzene.

Table A-1 Intermediate-Duration Oral NOAELs and LOAELs for Chlorobenzene

Species (dosing) | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Body weight
Rat (GO, 5 days/week) | 125 | 250 | 12% lower mean final body weight in males | NTP 1985
Mouse (GO, 5 days/week) | 125 | 250 | 15–20% lower mean final body weight | NTP 1985
Dog (C, 5 days/week) | 55 | 280 | Emaciation, weight loss at lethal dose | Monsanto Co. 1967a
Rat (GO, 7 days/week) | 250 | | | Monsanto Co. 1967b
Hematological
Dog (C, 5 days/week) | 55 | 280 | Low hemogram, increased numbers of immature WBCs | Monsanto Co. 1967a
Rat (GO, 7 days/week) | 250 | | | Monsanto Co. 1967b
Hepatic
Dog (C, 5 days/week) | 28 | 55 | 22% increased liver weight, bile duct hyperplasia (2/4 males) | Monsanto Co. 1967a
Rat (GO, 5 days/week) | 60 | 125 | 19% increased liver weight in females (LOAEL of 250 mg/kg in males) | NTP 1985
Mouse (GO, 5 days/week) | 60 | 125 | 14% increased liver weight in males
Mouse (GO, 5 days/week) | | 250 | Hepatic necrosis/degeneration in males and females | NTP 1985
Rat (GO, 7 days/week) | 100 | 250 | 27–29% increased mean relative liver weight | Monsanto Co. 1967b
Renal
Rat (GO) | 100 | 250 | 13–14% increased kidney weight | Monsanto Co. 1967b
Mouse (GO, 5 days/week) | 125 | 250 | Renal necrosis/degeneration | NTP 1985
Dog (C, 5 days/week) | 55 | 280 | Increased kidney weight; tubule dilatation, vacuolation, epithelial degeneration | Monsanto Co. 1967a
Rat (GO, 5 days/week) | 250 | 500 | 13–15% increased kidney weight | NTP 1985
Immunological
Mouse (GO, 5 days/week) | 125 | 250 | Lymphoid depletion/necrosis in thymus and spleen; myeloid depletion in bone marrow in males; lymphoid depletion/necrosis in spleen in females | NTP 1985
Rat (GO, 5 days/week) | 500 | 750 | Myeloid depletion in bone marrow, lymphoid depletion in spleen | NTP 1985

C = capsule administration; GO = gavage in oil; LOAEL = lowest-observed-adverse-effect-level; NOAEL = no-observed-adverse-effect level; WBC = white blood cell

Selection of the Principal Study: The study of Monsanto Co. (1967a) was selected as the principal study for deriving an intermediate-duration oral MRL for chlorobenzene because it identified the lowest LOAEL of 55 mg/kg/day for increases in liver and kidney weight and increased incidences of histopathologic liver and kidney lesions in chlorobenzene-treated dogs (see Table A-1).

Summary of the Principal Study:

Monsanto Co. 1967a. 13-Week oral administration- dogs. Monochlorobenzene final report. Monsanto Company . Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0200587. 877800212. 8DHQ10780212.

Groups of beagle dogs (4/sex/group) were treated with chlorobenzene orally (in capsule) at 0, 0.025, 0.05, or 0.25 mL/kg/day (0, 28, 55, and 280 mg/kg/day, respectively, based on a density of 1.1058 g/mL for chlorobenzene), 5 days/week for 13 weeks. Dogs were monitored for survival, clinical signs, food intake, and body weight. At study initiation and 1 and 3 months, blood was collected for clinical chemistry and hematology and urine was collected for urinalysis. At death or terminal sacrifice, all animals were subjected to gross pathological examination; organ or tissues weighed included heart, liver, spleen, kidneys, testes, thyroid, and adrenals. Selected tissues were processed for histopathologic examination.

All dogs in control, 28, and 55 mg/kg/day groups survived to terminal sacrifice. Four of eight dogs dosed at 280 mg/kg/day died or were sacrificed moribund (between weeks 3 and 5). Decedents exhibited decreased appetite, decreased activity, anorexia, and body weight loss. There were no clear signs of exposure-related body weight effects at 28 and 55 mg/kg/day dose levels. Other effects observed at 280 mg/kg/day included liver and kidney effects (56–77% increased mean relative liver weight, 62–87% increased mean relative kidney weight, increased incidences of pathologic liver and kidney lesions), increased adrenal weight, alterations in selected hematological parameters (low hemogram, increased numbers of immature WBCs), increases in selected serum chemistry parameters (low blood sugar; increased alkaline phosphatase, ALT, total bilirubin, and total cholesterol), increased urinary acetone and bilirubin, and death. The small numbers of animals (4/sex/group) limit the power to determine dose levels resulting in statistically significant changes in liver and kidney lesion incidences. However, as shown in Table A-2, the high-dose level (280 mg/kg/day) is an adverse effect level for liver effects in males (87% increased mean relative liver weight and centrilobular degeneration and bile duct hyperplasia in 4/4 high-dose males; no incidences in controls) and females (62% increased mean relative liver weight and centrilobular degeneration in 3/4 high-dose females; no incidences in controls). Bile duct hyperplasia was noted in 2/4 male dogs and 1/4 female dogs in the 55 mg/kg/day dose group (4/4 males and 3/4 females in the 280 mg/kg/day dose group, compared to no incidences among control or 28 mg/kg/day groups of males or females). The incidences of bile duct hyperplasia in the 55 mg/kg/day group of male dogs is considered to represent a LOAEL for chlorobenzene-induced liver effects. Furthermore, after combining sexes, the bile duct hyperplasia exhibited a dose-response characteristic (incidences of 3/8 and 7/8 at 55 and 280 mg/kg/day, respectively). The 28 mg/kg/day dose level is considered a NOAEL for liver effects and the 280 mg/kg/day dose level is considered a serious LOAEL for multiple degenerative liver effects (e.g., centrilobular degeneration, vacuolation, bile duct hyperplasia). As shown in Table A-3, the 280 mg/kg/day dose level represents a LOAEL for increased incidences of kidney lesions (e.g., significantly increased incidences of tubule dilatation, vacuolation, epithelial degeneration in combined sexes). The smaller number and nature of the reported histopathologic kidney lesions at the low- and mid-dose levels (28 and 55 mg/kg/day) and/or lack of dose-response characteristics suggest that the mid-dose (55 mg/kg/day) represents a NOAEL for kidney effects.

Table A-2 Liver Lesion Incidences in Male and Female Dogs Administered Chlorobenzene in Capsules 5 days/week for 13 Weeks^a^

Effect | Chlorobenzene dose (mg/kg)
Effect | 0 | | 28 | | 55 | | 280
Effect | Male | Female | Male | Female | Male | Female | Male | Female
Parenchymal irregularity | | | 3/4 (1) | | 2/4 (1) | 3/4 (1)
Chronic hepatitis | | 1/4 (1)
Portal fibrosis | | | 1/4 (1) | | 1/4 (1)
Stromal infiltration | | 1/4 (1) | | | 2/4 (1) | 1/4 (1)
Focal leukocyte infiltration | | | 2/4 (1) | | 1/4 (1)
Pigment deposition | | | | 1/4 (1) | | | 1/4 (1) | 2/4 (1–2)
Extramedullary blood production | 1/4 (1) | 1/4 (1)
Centrilobular degeneration | | | | | | | 4/4^b^ (3) | 4/4^b^ (1–3)
Vacuolation | | | | | | 1/4 (1) | 3/4 (2–4) | 3/4 (1–3)
Bile duct hyperplasia | | | | | 2/4 (1) | 1/4 (1) | 4/4^b^ (+/0–4) | 3/4 (1)
Cytologic changes | | | | | 1/4 (1) | | 2/4 (2–3) | 2/4 (1–2)
Cloudy swelling | | | | | 2/4 (1–3) | 1/4 (1)
Cholangitis | | | | | | | 1/4 (2) | 1/4 (1)
Bile stasis | | | | | | | 2/4 (1–3) | 2/4 (3)

a Numbers in parentheses denote relative severity of lesion (4 represents highest degree of severity).

b Significantly different from control incidence (p<0.05).

Source: Monsanto Co. 1967a

Table A-3 Kidney Lesion Incidences in Male and Female Dogs Administered Chlorobenzene in Capsules 5 days/week for 13 Weeks^a^

Effect | Chlorobenzene dose (mg/kg)
Effect | 0 | | 28 | | 55 | | 280
Effect | Male | Female | Male | Female | Male | Female | Male | Female
Pelvic epithelial irregularity | | 1/4 (2) | 2/4 (1–2)
Terminal proximal tubule swelling | 3/4 (2) | | 3/4 (1–3) | | 3/4 (3) | | 1/4 (3) | 1/4 (1)
Terminal proximal tubule vacuolation | | | 1/4 (1) | | | | | 2/4 (4)
Tubule dilatation | | | | | 1/4 (1) | 1/4 (1) | 2/4 (1–2) | 2/4 (2)
Tubule epithelial degeneration | | | | | 1/4 (1) | | 1/4 (2) | 3/4 (1–3)
Proximal convoluted tubule swelling | | | | | | | 1/4 (1) | 1/4 (1)
Proximal convoluted tubule vacuolation | | | | | | 1/4 (1) | 1/4 (1) | 3/4 (2–3)
Glomerular swelling | | | | | | | 1/4 (2)
Glomerulosclerosis | 1/4 (1) | 1/4 (1) | | 4/4 (1) | 1/4 (1) | 3/4 (1) | 1/4 (1)
Chronic pyelitis | | 2/4 (2–3) | 1/4 (1) | | | 1/4 (2)
Intraluminal foreign matter | | | | | | | | 1/4 (1)
Epithelial pigment deposition | | | | | | | 2/4 (2–3) | 1/4 (+/0)

a Numbers in parentheses denote relative severity of lesion (4 represents highest degree of severity).

Selection of the Point of Departure: Among available rat, mouse, and dog studies that employed intermediate-duration oral exposure, the lowest LOAEL is 55 mg/kg/day for liver effects in the dogs; the corresponding NOAEL is 28 mg/kg/day. Because the study employed only four dogs/sex/group, results for each sex were combined for each reported liver lesion type. The dataset for bile duct hyperplasia for combined sexes (see Table A-4) was considered adequate for benchmark dose (BMD) analysis. The data were fit to all available dichotomous models in EPA’s Benchmark Dose Software (BMDS, version 3.12) using the extra risk option. A benchmark response (BMR) of 10% over the control incidence was used. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), scaled residual at the data point (except the control) closest to the predefined BMR, BMDL that is not 10 times lower than the lowest non-zero dose, and visual inspection of the dose-response curve.

Table A-4 Dataset for Benchmark Dose Analysis of Bile Duct Hyperplasia Incidences in Male and Female Dogs Administered Chlorobenzene in Capsule for 13 Weeks^a^

| Chlorobenzene dose (mg/kg/day)
| Control | 28 | 55 | 280
Males | 0/4 | 0/4 | 2/4 (1) | 4/4^b^
Females | 0/4 | 0/4 | 1/4 (1) | 3/4 (1)
Males and females (combined) | 0/8 | 0/8 | 3/8 (1) | 7/8^b^ (+/0–4)

a Numbers in parentheses denote relative severity of lesion (4 represents highest degree of severity).

b Significantly different from control incidence (p<0.05).

Source: Monsanto Co. 1967a

The model predictions are presented in Table A-5. Among all models providing adequate fit to the data, the lowest BMDL (Multistage 1-degree model) was selected as the point of departure because the difference between the BMDLs estimated from these models was >3-fold.

Table A-5 Results from BMD Analysis of Bile Duct Hyperplasia Incidence in Male and Female Dogs Administered Chlorobenzene in Capsule 5 Days/Week for 13 Weeks (Monsanto Co. 1967a)

Model | BMD_10_ (mg/kg) | BMDL_10_ (mg/kg) | p-Value^a^ | AIC | Scaled residuals^b^
Model | BMD_10_ (mg/kg) | BMDL_10_ (mg/kg) | p-Value^a^ | AIC | Dose near BMD | Control group
Dichotomous Hill | 47.04 | 20.44 | 0.959 | 22.62 | 3.00×10^−3^ | −3.49×10^−4^
Gamma^c^ | 29.15 | 10.37 | 0.182 | 25.05 | −9.13×10^−1^ | −3.49×10^−4^
Log-Logistic^d^ | 31.35 | 11.08 | 0.507 | 22.57 | −8.40×10^−1^ | −3.49×10^−4^
Multistage Degree 3^e^ | 23.07 | 9.96 | 0.165 | 25.43 | −1.05 | −3.49×10^−4^
Multistage Degree 2^e^ | 23.07 | 9.96 | 0.165 | 25.43 | −1.05 | −3.55×10^−4^
Multistage Degree 1 ^e^ ^,^ ^f^ | 16.41 | 9.59 | 0.593 | 21.81 | −1.26 | −3.49×10^−4^
Weibull^c^ | 26.73 | 10.20 | 0.176 | 25.20 | −9.73×10^−1^ | −3.71×10^−4^
Logistic | 54.72 | 30.85 | 0.118 | 25.77 | 1.61 | −7.80×10^−1^
Log-Probit | 32.93 | 12.70 | 0.523 | 22.41 | −7.74×10^−1^ | −3.49×10^−4^
Probit | 52.18 | 31.71 | 0.123 | 25.55 | 1.64 | −7.21×10^−1^

a Values <0.1 fail to meet adequate fit

b Scaled residuals for dose group near the BMD and for the control dose group

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Betas restricted to ≥0.

f Recommended model. All models provided adequate fit to the data. BMDLs for models providing adequate fit were not sufficiently close (differed by >3-fold). Therefore, the model with lowest BMDL was selected (1-degree Multistage).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with a 10% relative deviation from control)

BMD modeling was also conducted on selected kidney lesion data (tubule dilatation, tubule epithelial degeneration, and proximal convoluted tubule vacuolation) for combined sexes (see Table A-6) because they exhibited some evidence of dose-response characteristics and statistically significantly increased incidences for these lesions were observed at the highest dose (280 mg/kg/day). Each dataset was fit to all available dichotomous models in EPA’s BMDS (version 3.1.2) using the BMD approach described for the liver lesion data above.

Table A-6 Dataset for Benchmark Dose Analysis of Selected Kidney Lesion in Male and Female Dogs Administered Chlorobenzene in Capsule in 13 Weeks

| Chlorobenzene dose (mg/kg)
| Control | 28 | 55 | 280
Tubule dilatation
Males | 0/4 | 0/4 | 1/4 | 2/4
Females | 0/4 | 0/4 | 1/4 | 2/4
Males and females combined | 0/8 | 0/8 | 2/8 | 4/8^a^
Tubule epithelial degeneration
Males | 0/4 | 0/4 | 1/4 | 1/4
Females | 0/4 | 0/4 | 0/4 | 3/4
Males and females combined | 0/8 | 0/8 | 1/8 | 4/8^a^
Proximal convoluted tubule vacuolation
Males | 0/4 | 0/4 | 0/4 | 1/4
Females | 0/4 | 0/4 | 1/4 | 3/4
Males and females combined | 0/8 | 0/8 | 1/8 | 4/8^a^

a Significantly different from control incidence (p<0.05).

All models provided adequate fit to each dataset for kidney lesions. The model results for tubule dilatation are presented in Table A-7. Most models provided adequate fit to the incidence data. The estimated BMDLs varied by greater than 3-fold, thus, the model with the lowest BMDL was selected (Log-Logistic model). The model for tubule dilatation estimated a BMD_10_ of 37.71 mg/kg and BMDL_10_ of 14.07 mg/kg. The incidence data for proximal convoluted tubule vacuolation and tubule epithelial degeneration were the same. The results of the BMD modeling for these two endpoints are presented in Table A-8. All models provided adequate fit and the Log-Probit model was selected because it had the lowest BMDL value. This model estimated a BMD_10_ of 61.67 mg/kg and BMDL_10_ of 13.99 mg/kg.

Table A-7 Results from BMD Analysis of Renal Tubule Dilatation Incidence in Male and Female Dogs Administered Chlorobenzene in Capsule 5 Days/Week for 13 Weeks (Monsanto Co. 1967a)

Model | BMD_10_^a^ (mg/kg) | BMDL_10_^a^ (mg/kg) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_10_^a^ (mg/kg) | BMDL_10_^a^ (mg/kg) | p-Value^b^ | AIC | Dose near BMD | Control group
Dichotomous Hill | 48.55 | 16.15 | 0.999 | 24.09 | 3.92×10^−3^ | −3.49×10^−4^
Gamma^d^ | 38.94 | 21.00 | 0.682 | 24.03 | −7.93×10^−1^ | −3.49×10^−4^
Log-Logistic ^e^ ^,^ ^f^ | 37.71 | 14.07 | 0.511 | 25.91 | −7.94×10^−1^ | −3.49×10^−4^
Multistage Degree 3^g^ | 38.94 | 21.00 | 0.682 | 24.03 | −7.93×10^−1^ | −3.49×10^−4^
Multistage Degree 2^g^ | 38.94 | 21.00 | 0.682 | 24.03 | −7.93×10^−1^ | −3.49×10^−4^
Multistage Degree 1^g^ | 38.94 | 21.00 | 0.682 | 24.03 | −7.93×10^−1^ | −3.49×10^−4^
Weibull^d^ | 38.94 | 21.00 | 0.682 | 24.03 | −7.93×10^−1^ | −3.49×10^−4^
Logistic | 104.66 | 63.17 | 0.190 | 27.86 | 1.48 | −6.94×10^−1^
Log-Probit | | | 0.531 | 25.77 | −7.40×10^−1^ | −3.49×10^−4^
Probit | 95.50 | 58.90 | 0.199 | 27.70 | 1.47 | −6.54×10^−1^

a BMD and BMDL values for models that do not provide adequate are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMD and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Recommended model. BMDLs for models providing adequate fit were not sufficiently close (differed by >3-fold). Therefore, the model with lowest BMDL was selected (Log-Logistic).

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with a 10% relative deviation from control)

Table A-8 Results from BMD Analysis of Renal Proximal Tubule Vacuolation and Tubule Epithelial Degeneration Incidences in Male and Female Dogs Administered Chlorobenzene in Capsule 5 Days/Week for 13 Weeks (Monsanto Co. 1967a)

Model | BMD_10_^a^ (mg/kg) | BMDL_10_^a^ (mg/kg) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_10_^a^ (mg/kg) | BMDL_10_^a^ (mg/kg) | p-Value^b^ | AIC | Dose near BMD | Control group
Dichotomous Hill | 53.67 | 20.27 | 1.000 | 21.12 | 8.67×10^−4^ | −3.49×10^−4^
Gamma^d^ | 65.97 | 25.36 | 0.480 | 23.83 | 4.88×10^−1^ | −3.55×10^−4^
Log-Logistic^e^ | 63.81 | 19.73 | 0.497 | 23.80 | 4.51×10^−1^ | −3.56×10^−4^
Multistage Degree 3^f^ | 67.37 | 25.06 | 0.461 | 23.94 | 4.74×10^−1^ | −3.52×10^−4^
Multistage Degree 2^f^ | 67.37 | 25.06 | 0.762 | 21.94 | 4.74×10^−1^ | −3.49×10^−4^
Multistage Degree 1^f^ | 47.59 | 24.41 | 0.904 | 20.17 | 9.19×10^−2^ | −3.49×10^−4^
Weibull^d^ | 66.14 | 25.28 | 0.476 | 23.86 | 4.80×10^−1^ | −3.49×10^−4^
Logistic | 127.20 | 75.54 | 0.497 | 22.78 | 9.37×10^−1^ | −4.60×10^−1^
Log-Probit ^g^ | 61.67 | 13.99 | 0.534 | 23.68 | 4.23×10^−1^ | −8.93×10^−3^
Probit | 114.82 | 69.29 | 0.522 | 22.65 | 9.10×10^−1^ | −4.21×10^−1^

a BMD and BMDL values for models that do not provide adequate are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMD and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. BMDLs for models providing adequate fit were not sufficiently close (differed by >3-fold). Therefore, the model with lowest BMDL was selected (Log-Probit).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with a 10% relative deviation from control)

A comparison of the BMD values for the liver and kidney endpoint was made:

- BMD_10_ of 16.41 mg/kg for bile duct hyperplasia (BMDL_10_ of 9.59 mg/kg),
- BMD_10_ of 37.71 mg/kg for renal tubular dilation (BMDL_10_ of 14.07 mg/kg), and
- BMD_10_ of 61.67 mg/kg for proximal convoluted tubule vacuolation and tubule epithelial degeneration (BMDL_10_ of 13.99 mg/kg)

The bile duct hyperplasia had the lowest BMD_10_ and was selected as the critical effect. The BMDL_10_ of 9.59 mg/kg for this endpoint was selected as the POD for the MRL. This BMDL_10_ was estimated using the 1-degree Multistage model, which is presented in Figure A-1.

Figure A-1 Fit of 1-Degree Multistage Model for Bile Duct Hyperplasia in Male and Female Dogs Administered Chlorobenzene 5 Days/Week for 13 Weeks (Monsanto Co. 1967a)

Intermittent Exposure: The BMDL_10_ of 9.59 mg/kg/day was adjusted for intermittent exposure (5 days/7 days) resulting in adjusted value of 6.85 mg/kg/day.

BMDL_ADJ_ = 9.59 mg / kg × (5 days / 7 days) = 6.85 mg / kg / day

Uncertainty Factor: The BMDL_ADJ_ was divided by a total uncertainty factor (UF) of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = BMDL_ADJ_ ÷ UFs 6.85 mg / kg / day ÷ (10 × 10) = 0.0685 mg / kg / day ≈ 0.07 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support: As shown in Table A-1, liver and kidney effects were observed in rats and mice treated orally with chlorobenzene for intermediate-duration periods (Monsanto Co. 1967b; NTP 1985).

Agency Contacts (Chemical Managers): Breanna Alman, MPH

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlorobenzene
CAS Numbers: | 108-90-7
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: One 2-year oral toxicity and carcinogenicity study of rats gavaged with chlorobenzene at 60 or 120 mg/kg/day reported decreased survival and increased incidences of neoplastic liver lesions at 120 mg/kg/day in the absence of other signs of exposure-related adverse effects (NTP 1985). There were no signs of adverse effects in mice similarly treated at 30 or 60 mg/kg/day (males) or 60 or 120 mg/kg/day (females) (NTP 1985). No nonlethal and nonneoplastic effects were observed in the rats or mice following chronic-duration oral exposures at doses resulting in adverse nonneoplastic effects in animals following intermediate-duration exposures. Therefore, no chronic-duration oral MRL was derived for chlorobenzene.

Agency Contacts (Chemical Managers): Breanna Alman, MPH