# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-62, Atlanta, Georgia 30333.

## Chlorine gas Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlorine gas
CAS Numbers: | 7782-50-5
Date: | June 2010
Profile Status: | Final Draft Post-Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 7, 9, 10, 11
Species: | Human

[underlined: Minimal Risk Level]: 0.06 [ ] mg/kg/day [X] ppm

[underlined: References]: Anglen DA. 1981. Sensory response of human subjects to chlorine in air. Ann Arbor, MI: University of Michigan.

D’Alessandro A, Kuschner W, Wong H, . 1996. Exaggerated responses to chlorine inhalation among persons with nonspecific airway hyperreactivity. Chest 109:331–337.8620701

Rotman HH, Fliegelman MJ, Moore T, . 1983. Effects of low concentrations of chlorine on pulmonary function in humans. J Appl Physiol 54:1120–1124.6853288

Schins RPF, Emmen H, Hoogendijk L, . 2000. Nasal inflammatory and respiratory parameters in human volunteers during and after repeated exposure to chlorine. Eur Respir J 16:626–632.11106203

Shusterman D, Murphy, MA, Balmes J. 1998. Subjects with seasonal allergic rhinitis and nonrhinitic subjects react differentially to nasal provocation with chlorine gas. J Allergy Clin Immunol 101:732–740.9648699

Shusterman D, Murphy, MA, Balmes J. 2003b. Influence of age, gender, and allergy status on nasal reactivity to inhaled chlorine. Inhal Toxicol 15:1179–1189.14515221

[underlined: Experimental design and effects noted in each study]: Anglen (1981) exposed up to 29 male and female volunteers to 0, 0.5, 1, or 2 ppm chlorine for either 4 or 8 hours. Sensations were recorded before and during exposure, and pulmonary function was monitored by measuring FVC and FEV_1_ before and at various times during exposure. Itching and burning of the throat were the highest responses and were most prevalent by the end of an 8-hour exposure to 1 ppm chlorine. Responses for sensations of itching or burning of the nose and eyes were also prevalent at 1 ppm chlorine. In general, males provided stronger irritation responses than females. Exposure to 1 or 2 ppm chlorine for 8 hours produced significant changes in pulmonary function, but similar exposures to 0.5 ppm did not. Exposure to 2 ppm for up to 30 minutes produced no increase in subjective irritation and exposure to 2 ppm for 2 hours did not alter pulmonary function.

Rotman et al. (1983) studied eight healthy male volunteers exposed to target concentrations of 0, 0.5, or 1 ppm chlorine (Rotman et al. 1983). Pulmonary tests were conducted before exposure, after a 4- and 8-hour exposure period and again 2 and 24 hours after exposure ceased. During exposure, the subjects exercised on a treadmill for 15 minutes of each hour to simulate light-to-moderate work that raised the heart rate to 100 beats per minute. Specific respiratory parameters measured included FVC, FEV_1_, FEV_1_% forced expired volume in 1 second as %FVC (FEV1%), peak expiratory flow rate (PEFR), FEF_50_ and FEF_25_, TLC, expiratory reserve volume (ERV), functional residual capacity (FRC), residual volume, airway resistance (Raw), single-breath DL_CO_, closing volume, and difference in nitrogen concentrations between 750 and 1,250 mL of inhaled vital capacity (ΔN_2_). Exposure to 1 ppm chlorine caused runny nose and mild burning in the throat, but no such effects were reported at 0.5 ppm. Significant changes in pulmonary function tests were mostly restricted to the 1 ppm exposure level and were evident after 4 hours of exposure. Changes were observed in FEV_1_, PEFR, FEF_50_, FEF_25_, TLC, Raw, and ΔN_2_. Greater changes in some of these parameters were seen after 8 hours of exposure. Few changes were still evident 24 hours after exposure, but most parameters had returned to pre-exposure values by that time. It should be noted that one volunteer who was atopic experienced severe distress during exposure to 1 ppm and was forced to exit the chamber before the full 8-hour period due to shortness of breath and wheezing.

D’Alessandro et al. (1996) evaluated pulmonary function in subjects with (n=10) and without (n=5) airway hyperreactivity (HR, defined by baseline methacholine hyperresponsiveness). The HR subjects were exposed to 0.4 or 1.0 ppm chlorine, whereas the healthy subjects were exposed to 1.0 ppm chlorine. All exposures lasted 60 minutes. Airflow and airway resistance were measured immediately before and immediately after exposure. Also, lung volumes, airflow, diffusing capacity, airway resistance, and responsiveness to methacholine were measured 24 hours before and 24 hours after exposure. Exposure of the HR group to 0.4 ppm chlorine resulted in no significant change in airflow or resistance either immediately or 24 hours after exposure. Exposure to 1.0 ppm chlorine resulted in an immediate decrease in FEV_1_ and FEF_25–75%_ and increase in airway resistance among normal and HR subjects, but the magnitude of the effects among HR subjects was significantly greater than in healthy subjects. Twenty-four hours after exposure, there were no significant changes for healthy or HR subjects in airflow, lung volumes, diffusing capacity, resistance, or methacholine responsiveness. Comparing relative changes from baseline immediately after exposure between normal and HR subjects showed that HR subjects had much greater changes in pulmonary function tests.

Schins et al. (2000) studied eight volunteers exposed to chlorine 6 hours/day on 3 consecutive days to each of the four exposure conditions, 0, 0.1, 0.3, and 0.5 ppm chlorine (Schins et al. 2000). Pulmonary function including effort-dependent parameters and effort-independent parameters were evaluated before and after exposures. In addition, nasal lavage measurements were performed before and after each exposure and 1 and 4 days after each exposure. The nasal lavage fluid was examined for total cells, epithelial cells, neutrophils, lymphocytes, eosinophils, monocytes, albumin (an indicator of epithelial permeability), and interleukin-8 (indicator of inflammatory response). Subjective complaints by the subjects were judged to be not treatment-related. Examination of the nasal lavages gave no indication of an inflammatory response or irritant effects on the nasal epithelium. The results of the pulmonary function tests showed that the only significant effect related to chlorine exposure was a difference in maximal mid expiratory flow (MMEF) between 0 and 0.5 ppm exposure; however, this was attributed to an unexplained shift in baseline values during control exposure (0 ppm).

Shusterman et al. (2003b) measured nasal airway resistance in 52 healthy adults (24 males and 28 females) before and after exposure to 0 or 1 ppm chlorine for 15 minutes. Subjects were stratified on age (18–34, 35–51, 52–69 years), gender, and allergic rhinitis status (27 were positive). Nasal airway resistance was measured by active posterior rhinomanometry. Exposures to air and chlorine were a week apart. Subjects with allergic rhinitis showed a significantly greater increase in nasal airway resistance (49% increase from baseline) than healthy subjects (10% increase from baseline) 15 minutes after exposure. The increase in nasal airway resistance was most pronounced in older subjects and least pronounced in the youngest group. No significant differences were seen between males and females. In an earlier study, the same group of investigators had reported that subjects with SAR (n=8) exposed to 0.5 ppm chlorine for 15 minutes experienced a much greater increase in nasal airway resistance than subjects without SAR (n=8), as measured by active posterior rhinomanometry (Shusterman et al. 1998). However, when subjective responses to odor, nasal irritation, and nasal congestion were analyzed separately by rhinitis status, no significant exposure-related changes were observed for rhinorrhea, postnasal drip, or headache either on a pool or stratified basis. In addition, within either the SAR or non-SAR group, there was no relationship between subjective and objective congestion after chlorine exposure. Pulmonary peak flow tests showed that none of the subjects exhibited clinically significant changes in peak flow, nor did they complain of cough, wheezing, or chest tightness on chlorine exposure days. The increased nasal airway resistance instrumentally detected in subjects with SAR is not considered an adverse effect since the subjects did not perceive it as such.

Collectively, this group of studies provides evidence of sensory irritation and transient pulmonary changes occurring in humans exposed to 1 ppm chlorine for up to 8 hours/day. The pulmonary changes indicated increased airway resistance and reduced air flow. No such changes were reported in volunteers exposed to 0.5 ppm chlorine

[underlined: Dose and end point used for MRL derivation]: 0.5 ppm is a NOAEL for sensory irritation and pulmonary function.

The MRL is derived by adjusting for continuous exposure based on the fact that Rotman et al. (1983) reported that exposure to 1 ppm for 8 hours induced greater changes in pulmonary function tests than exposure to the same concentration for 4 hours, suggesting that the response was related to some function of concentration and duration rather than to concentration alone.

MRL = 0.5 ppm ( 8 hours / 24 hours ) = 0.167 ppm

8 hours was the longest period of exposure for which there is information.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 3 for human variability

Although sensitive individuals were tested in some of these studies, the number of individuals tested at the region of the NOAEL (0.4–0.5 ppm) was small. Therefore, an uncertainty factor of 3 is used to account for sensitive populations.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes, see above.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Results from the five studies summarized above are supportive of each other.

[underlined: Agency Contacts (Chemical Managers)]: G. Daniel Todd

## Chlorine gas Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlorine gas
CAS Numbers: | 7782-50-5
Date: | June 2010
Profile Status: | Final Draft Post-Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 30
Species: | Rat

[underlined: Minimal Risk Level]: 0.002 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Kutzman RS. 1983. A study of Fisher-344 rats subchronically exposed to 0, 0.5, 1.5, or 5.0 ppm chlorine. Upton, NY: Brookhaven National Laboratory. BNL 32710.

[underlined: Experimental design]: Groups of F344 rats (24 males, 10 females) were exposed to 0, 0.5, 1.5, or 5 ppm chlorine 6 hours/day, 5 days/week for 62 days (Kutzman 1983). Pulmonary function tests (plethysmograph-based assessment of multiple end points, including lung and tidal volumes, breathing frequency, transpulmonary pressure, lung compliance, N_2_ washout, diffusing capacity for CO_2_, maximum expiratory flow volume, peak expiratory flow, and airway resistance) were conducted in 21–24 anesthetized males 6 hours after the last exposure. Respiratory tissues from these rats were prepared for histopathology. The lung from some of these rats was also examined for collagen, elastin, total protein, and DNA. Histopathology of selected organs (nasal turbinates, lungs, peribronchial lymph node, brain, kidney, liver, spleen, testes, and heart) was evaluated in eight males per group. Also, 8 males were mated with untreated females and 10 exposed females were mated with untreated males for reproductive studies on females sacrificed on GD 19. In addition, 1 day after the last exposure, samples of blood and bone marrow from 10 males per group were prepared for analysis of chromosomal aberrations and sister chromatid exchanges.

[underlined: Effects noted in study and corresponding doses]: Exposure to 5 ppm cause severe eye and upper respiratory irritation, whereas rats exposed to 1.5 ppm showed occasionally less severe signs of irritation, and exposure to 0.5 ppm caused no obvious signs of irritation or discomfort. Female rats exposed to 5 ppm lost weight. Final weight was approximately 32% lower than controls; at 1.5 and 0.5 ppm, final weight was approximately 15 and 11% lower than in control rats, respectively. In males exposed to 5 ppm, final weight was approximately 15% lower than controls. No information was provided regarding food and water intake. Changes in organ weights were unremarkable. The tests of pulmonary function did not reveal marked abnormalities. The most significant effect was a reduction in airflow at 25% vital capacity in all exposed groups, indicating some degree of small airway involvement. An electrocardiogram did not reveal any significant cardiac alterations due to chlorine exposure. The lung biochemistry only showed an increased collagen concentration at 1.5 and 5 ppm. The cytogenetic studies showed no increased incidence of sister chromatid exchange or cellular proliferation in bone marrow and no increase in sister chromatid exchanges or chromosomal aberrations in peripheral lymphocytes. Analysis of sperm morphology was unremarkable. Results of the reproductive studies showed no effects on fertility, number of corpora lutea, viable embryos, early or late deaths, or preimplantation loses. There were no significant exposure-related increases in the incidences of animals with histological lesions in any of the examined tissues with the exception of a loss of cilia in the trachea. The incidences of slight to moderate loss of tracheal cilia were 1/23, 12/23, 4/23, and 13/23 in the 0, 0.5, 1.5, and 5 ppm exposure groups, respectively. Although the incidence for this lesion in the mid-exposure group was not significantly different from the control incidence, a statistically significant (p=0.0055) Cochran-Armitage trend test for these data can be demonstrated. However, when attempts were made to apply dose-response models to the data, no adequate fits of EPA Benchmark Dose Software models to the data were obtained (p-values for chi-square goodness of fit statistics were <0.1).

[underlined: Dose and end point used for MRL derivation]: 0.5 ppm is a minimal LOAEL for tracheal lesions.

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [X] 3 for extrapolation from animals to humans with dosimetric adjustment
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: The intermediate-duration inhalation MRL was calculated using EPA’s methodology (EPA 1994a) for a category 1 gas.

LOAEL_[ HEC ]_ = LOAEL_[ ADJ ]_ × RGDR_TB_

where:

- LOAEL_[ADJ]_ = 0.5 ppm × 6/24 hours × 5/7 days = 0.09 ppm and
- RGDR_TB_ = ratio of the regional gas dose in rats to that of humans for the tracheobronchial region

RGDR_TB_ = ( VE / SA_TB_ )_A_ / ( VE / SA_TB_ )_H_

where:

- VE = minute volume (0.137 L/minute for rats, 13.8 L/minute for humans [EPA 1994a]) and
- SA_TB_ = surface area of the tracheobronchial region (22.5 cm^2^ for rats and 3,200 cm^2^ for humans [EPA 1994a])

LOAEL_[ HEC ]_ = 0.09 ppm × ( 0.137 L / minute / 22.5 cm^2^ ) / ( 13.8 L / minute / 3,200 cm^2^ ) = 0.14 ppm

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes, see above.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: In a similar study, Barrow et al. (1979) evaluated the respiratory response in F344 rats exposed to 0, 1, 3, or 9 ppm chlorine 6 hours/day, 5 days/week for 6 weeks. Nasal discharge was seen occasionally in rats exposed to 1 ppm, but was common in rats exposed to 3 and 9 ppm. Respiratory difficulty was also apparent in some rats exposed to 9 ppm. At termination, gross necropsy revealed accumulation of inflammatory reactions in the upper nasal passages in rats exposed to 3 and 9 ppm chlorine. Microscopic evaluations showed indications of inflammatory reactions in the upper and lower respiratory tract of high-dose males and females. The nasal turbinates showed mucopurulent inflammation with secretory material and erosions of the mucosal epithelium. Changes in the trachea and bronchi consisted mostly of hyperplasia of the epithelial lining and inflammatory reactions. The alveolar sacs contained macrophages and secretory material and epithelial cells showed necrosis, hypertrophy, and hyperplasia. Alterations in rats exposed to 1 and 3 ppm were less extensive and were limited to focal mucopurulent inflammation of the nasal turbinates in females. Males exposed to 1 or 3 ppm showed deeper pulmonary changes consisting of slight to moderate inflammatory reaction around the respiratory bronchioles and alveolar ducts, increased alveolar macrophages, and isolated areas of atelectasis (incomplete expansion). A LOAEL of 1 ppm for respiratory effects can be defined in this study based on the presence of inflammatory changes in the nasal turbinates of females and in the lungs of males; no NOAEL was established. Incidences of animals with respiratory lesions were not presented in this study.

[underlined: Agency Contacts (Chemical Managers)]: G. Daniel Todd

## Chlorine gas Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlorine gas
CAS Numbers: | 7782-50-5
Date: | June 2010
Profile Status: | Final Draft Post-Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 34
Species: | Monkey

[underlined: Minimal Risk Level]: 0.00005 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Klonne DR, Ulrich CE, Riley MG, . 1987. One-year inhalation toxicity study of chlorine in Rhesus monkeys (Macaca mulatta). Fundam Appl Toxicol 9:557–572.3692014

[underlined: Experimental design]: Male and female Rhesus monkeys (4/sex/exposure level) were exposed to 0, 0.1, 0.5, or 2.3 ppm chlorine 6 hours/day, 5 days/week for 1 year (Klonne et al. 1987). Pulmonary diffusing capacity of CO and distribution of ventilation, body weights, urinalysis, EKG, hematology, and clinical chemistry were evaluated monthly during the study. At termination, the heart, lungs plus trachea, liver, gonads, kidneys, spleen, and brain were weighed. Histological evaluations were done on all major tissues and organs. The nasal tissues (at the first palatine ridge and just posterior to the third, fifth, and seventh palatine ridges), trachea, and lungs were also examined.

[underlined: Effects noted in study and corresponding doses]: Exposure to chlorine did not significantly affect body weight, hematology and clinical chemistry parameters, urinalysis, or the EKG. At approximately week 6 of exposure, monkeys in the 2.3 ppm group showed overt signs of ocular irritation (tearing, reddened eyes, rubbing the eyes) during the daily exposures; no signs of irritation were seen in the other exposure groups. Examination of the eyes at termination showed irritation of the conjunctiva at 2.3 ppm, but no evidence of gross changes; the corneas were not affected. During the study, there was a statistically significant trend in each group, including controls, for increasing pulmonary diffusing capacity and distribution of ventilation. However, there was no evidence of treatment-related effects at any interval during the study. The only treatment-related histopathological effects consisted of focal epithelial hyperplasia characterized by increased cell numbers and loss of cilia and goblet cells in the respiratory epithelium of the nose and trachea. The affected areas of the nasal passages showed hypercellularity with loss of goblet cells and cilia. In some of these areas, the nuclei showed altered polarity. Lesions were more frequent on the angular margins of the turbinates and less frequent on the lateral wall or septum adjacent to these margins. In some cases, the respiratory epithelial hyperplasia was associated with mild suppurative inflammatory response. Lesions in the trachea resembled those in the nose, but were less severe and involved only a small circumferential section of the ventral and ventrolateral trachea. The combined incidences of hyperplasia in the nasal epithelium with loss of goblet cells and cilia, characterized as trace and mild in males and females, were 1/8, 3/8, 6/8, and 8/8 in the control, 0.1, 0.5, and 2.3 ppm exposure groups, respectively. The exposure concentration of 0.1 ppm is considered a LOAEL for nasal lesions in monkeys.

Incidence data for nasal lesions in male and female monkeys exposed to chlorine gas (Klonne et al. 1987) were analyzed using the BMD approach for MRL derivation. Models in the EPA BMDS (version 1.4.1) (i.e., Gamma, Logistic, Log-logistic, Multi-stage, Probit, Log-probit, Quantal linear, Weibull) were fit to the nasal lesion data to determine potential points of departure for the MRL. A Quantal linear model provided the best fit to the data. The predicted exposure concentration associated with a 10% extra risk (BMC_10_) for nasal lesions in monkeys was 0.04 ppm; the lower 95% confidence limit on this concentration (BMCL_10_) was 0.02 ppm.

[underlined: Dose and end point used for MRL derivation]: BMCL_10_ of 0.02 ppm for nasal lesions in monkeys.

[ ] NOAEL [ ] LOAEL [X] BMCL_10_

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans with dosimetric adjustment
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: The intermediate-duration inhalation MRL was calculated using EPA’s methodology (EPA 1994a) for a category 1 gas.

BMCL_10 [ HEC ]_ = BMCL_10 [ ADJ ]_ × RGDR_ET_

where:

- BMCL_10[ADJ]_ = 0.02 ppm × 6/24 hours × 5/7 days = 0.004 ppm and
- RGDR_ET_ = ratio of the regional gas dose in rats to that of humans for the extrathoracic region

RGDR_ET_ = ( VE / SA_ET_ )_A_ / ( VE / SA_ET_ )_H_

where:

- VE = minute volume 2.1 m^3^/day for monkeys, calculated using the allometric equation for monkeys in EPA (1988) assuming a body weight of 7 kg for Rhesus monkeys with nasal cavity surface area of 62 cm^2^ (Gross and Morgan 1991); 20 m^3^/day for humans (EPA 1994a) and
- SA_ET_ = 62 cm^2^ surface area of the nasal cavity in Rhesus monkeys weighing 7 kg (Gross and Morgan 1991); 200 cm^2^ for humans (EPA 1994a)

RGDR_ET_ = ( 2.1 m^3^ / day / 62 cm^2^ ) / ( 20 m^3^ / day / 200 cm^2^ ) = 0.34

BMCL_10 [ HEC ]_ = 0.004 ppm × 0.34 = 0.00136 ppm

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes, see above.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Wolf et al. (1995) exposed groups of F344 rats and B6C3F_1_ mice (approximately 70/sex/exposure level) to 0, 0.4, 1, or 2.5 ppm chlorine gas for 2 years. Males from both species and female mice were exposed 6 hours/day, 5 days/week, whereas female rats were exposed 6 hours/day, 3 days/week. The reduced exposure of female rats was based on unpublished data from the investigators that showed female rats to have a greater sensitivity to repeated long-term exposure to chlorine. End points evaluated included gross and microscopic examination of the respiratory tract; the nasal passages were examined microscopically at five different levels. Both in rats and mice, there were no gross lesions attributable to exposure to chlorine, and microscopic evaluation of the respiratory tract showed that chlorine-related effects were restricted to the nasal passages. In the study, the incidences were presented as percentages of all animals for which the nasal passages were adequate for microscopic examination, but the number of animals examined was not provided. No lesions were seen in the larynx, trachea, bronchi, or bronchioles. In general, rats and mice exhibited similar types of lesions. For the most part, the nasal lesions were site-specific, but the severity and/or incidence were not always concentration-dependent. The majority of the nasal responses exhibited a rostral-to-caudal severity gradient. The lesions rarely extended to the nasopharyngeal meatus. Lesions observed included respiratory and olfactory epithelial degeneration, septal fenestration, mucosal inflammation, respiratory epithelial hyperplasia, squamous metaplasia, and goblet cell (only rats) hypertrophy and hyperplasia, and secretory metaplasia of the transitional epithelium of the lateral meatus. Also observed was intracellular accumulation of eosinophilic proteinaceous material involving the respiratory, transitional, and olfactory epithelia. Lesions were also observed in controls, but the incidences were significantly lower than in the treated groups. One of the lesions with the lowest incidence in controls was Goblet cell hyperplasia in female rats (4%); the respective incidences in the 0.4, 1, and 2.5 ppm group were 71, 90, and 91%. In mice, olfactory epithelium atrophy exhibited one of the lowest incidences in controls (3%); the respective incidences in the 0.4, 1, and 2.5 ppm group were 20, 21, and 39%. In both cases, severity also was concentration-related. Based on the increased incidence of various types of lesions in the nasal passages, the exposure level of 0.4 ppm constitutes a LOAEL for respiratory effects in rats and mice; a NOAEL was not defined.

[underlined: Agency Contacts (Chemical Managers)]: G. Daniel Todd

#### BENCHMARK MODELING OF NASAL LESIONS IN MONKEYS

Incidence data for nasal lesions in male and female monkeys exposed to chlorine gas (Klonne et al. 1987) were analyzed using the BMD approach for MRL derivation (Table A-1). Models in the EPA BMDS (version 1.4.1) (i.e., Gamma, Logistic, Log-logistic, Multi-stage, Probit, Log-probit, Quantal linear, Weibull) were fit to the nasal lesion data to determine potential points of departure for the MRL. A Quantal linear model provided the best fit to the data (Table A-2).

Table A-1 Incidence of Nasal Lesions Observed in Monkeys Exposed to Chlorine for 1 Year

Dose (ppm) | Total number of monkeys | Number of monkeys with lesions
0 | 8 | 1
0.1 | 8 | 3
0.5 | 8 | 6
2.3 | 8 | 8

Source: Klonne et al. 1987

Table A-2 Modeling Predictions for the Incidence of Nasal Lesions Observed in Monkeys Exposed to Chlorine for 1 Year

Model | BMC_10_ (ppm) | BMCL_10_ (ppm) | x^2^ p-value | AIC
Gamma^a^ | 0.04 | 0.02 | 0.95 | 29.72
Logistic | 0.09 | 0.05 | 0.76 | 30.17
Log-logistic^b^ | 0.05 | 0.009 | 0.53 | 32.21
Multi-stage^c^ | 0.04 | 0.02 | 0.95 | 29.72
Probit | 0.08 | 0.05 | 0.77 | 30.14
Log-probit^b^ | 0.06 | 0.03 | 0.81 | 30.09
Quantal linear | 0.04 | 0.02 | 0.95 | 29.72
Weibull^a^ | 0.04 | 0.02 | 0.95 | 29.72

a Restrict power ≥1.

b Slope restricted to >1.

c Restrict betas ≥0; lowest degree polynomial with an adequate fit is reported; degree of polynomial = 1.

Source: Klonne et al. 1987

From this model, the predicted exposure concentration associated with a 10% extra risk (BMC_10_) for nasal lesions in monkeys was 0.04 ppm; the lower 95% confidence limit on this concentration (BMCL_10_) was 0.02 ppm (Figure A-1).

Figure A-1 Predicted and Observed incidence of Nasal Mucosal Lesions in Monkeys Exposed to Chlorine for 1 Year