# 8 REFERENCES

*Cited in text

*Agnihotri NP, Pandey SY, Jain HK, . 1981. Persistence, leaching, and movement of chlorfenvinphos, chlorpyrifos, disulfoton, fensulfothion, monocroiophos and tetrachlorvinphos in soil. Ind J Agric Chem 14(1–2):27–31.
*Aguera A, Contreras M, Fernandez-Alba AR. 1993. Gas chromatographic analysis of organophosphorus pesticides of horticultural concern. J Chromatogr A 655(2):293–300.
*Akintonwa DA. 1984. Theoretical aspects of enzyme induction and inhibition leading to the reversal of resistance to biocides. J Theor Biol 106(1):79–87.6700238
*Akintonwa DA. 1985. The correlation between theoretical and experimental biotransformation of 2-chloro-1-(2’,4’ dichlorophenyl) vinyl diethylphosphate (chlorfenvinphos) in the dog and rat. J Theor Biol 114(1):103–108.4010306
*Akintonwa DA, Itam IH. 1988. The development of an assay for determination of monooxygenase of human foetal livers based on rate of decrease in substrate concentration. Drug Des Deliv 3(1):77–83.3255325
*Ambrose AM, Larson PS, Borzelleca JF, . 1970. Toxicologic studies on Diethyl-1-(2,4-Dichlorophenyl)-2-Chlorovinyl phosphate. Toxicol Appl Pharmacol 17:323–336.5471553
*Amer SM, Aly FAE. 1992. Cytogenetic effects of pesticides. IV. Cytogenetic effects of the insecticides Gardona and Dursban. Mutat Res 279(3):169–170.
*Ames RG, Brown SK, Rosenberg J, . 1989. Health symptoms and occupational exposure to flea control products among California pet handlers. Am Ind Hyg Assoc J 50(9):466–472.2801514
*Andersen ME, Clewell HJ, III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. Current concepts and approaches on animal test alternatives. H. Salem, ed. U.S. Army Chemical Research Development and Engineering Center, Aberdeen Proving Ground, Maryland.
*Atkinson R. 1988. Estimation of gas-phase hydroxyl radical rate constants for organic chemicals. Environ Toxicol Chem 7:435–442.
*Atkinson R, Carter WPL. 1984. Kinetics and mechanisms of the gas-phase reactions of ozone with organic compounds under atmospheric conditions. Chem Rev 84:437–470.
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicologicol profiles. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
*ATSDR/CDC. 1990. Subcommittee report on biological indicators of organ damage. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention, Atlanta, GA.
*Bagon DA, Warwick CJ. 1982. The determination of atmospheric concentrations of the active ingredient of pesticide formulations by high-performance liquid chromatography. Chromatographia 16:290–293.
*Barba A, Navarro M, Navarro-Garcia S. 1993. Adsorption of chlorfenvinphos and methidathion on saturated clays by different cations. J Environ Sci Health, Part B: Pestic Food Contam Agric Wastes 26(5–6):547–556.
*Barba A, Navarro M, Navarro Garcia S, . 1991. Adsorption of chlorfenvinphos and methidathion from saturating dissolutions of different cations. J Environ Sci Health B26(5–6):547–556. [French]
*Barna J, Simon G. 1973. Effect of small oral doses of Birlane (chlorfenvinphos) on intestinal resorption. Kiserl Orvostud 26(6):605–609.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. U.S. Environmental Protection Agency. Regul Toxicol Pharmacol 8:471–486.3222488
*Barrio CS, Asenio JS, Bernal JG. 1994. GC-NPD investigation of the recovery of organonitrogen and organophosphorus pesticides from apple samples: The effect of the extraction solvent. Chromatogr 30:320–324.
*Bauer H, Schonherr J. 1992. Determination of mobilities of organic compounds in plant cuticles and correlation with molar volumes. Pestic Sci 35(1):1–11.
Berstein ME. 1984. Agents affecting the male reproductive system: Effects of structure on activity. Drug Metab Rev 15:941–999.6396061
*Beroza m, Bowman MC. 1966. Gas Chromatographic Determination of Compound 4072 and Shell SD-8447 by Electron-Capture and Flame-Photometric Detection. J Agr Food Chem 14(6):625–627.
*Beynon KI, Davies L, Elgar K. 1966. Analysis of crops and soils for residues of diethyl 1-(2,4,-Dichlorophenyl)-2-Chlorovinyl Phosphate. I. Development of Method. J Sci Food Agric 17:162–167.
*Beynon KI, Edwards MJ, Elgar K, . 1968. Analysis of crops and soils for residues of chlorfenvinphos insecticide and its breakdown products. J Sci Fd Agric 19:302–307.
*Beynon KI, Edwards MJ, Thompson AR, . 1971. Persistence of chlorfenvinphos in natural waters. Pestic Sci 2(1):5–7.
*Beynon KI, Hutson DH, Wright AN. 1973. The metabolism and degradation of vinyl phosphate insecticides. Residue Rev 47:55–142.4585120
*Beynon KI, Wright AN. 1968. Breakdown of C-Chlorfenvinphos insectide on crops. J Sci Food Agric 19:146–153.5644504
*Binstein S, Devillers J. 1994. QSAR for organic chemical sorption in soils and sediments. Chemosphere 28(6):1171–1188.
*Bowman BT, Sans WW. 1983. Determination of octanol-water partitioning coefficients (Kow) of 61 organophosphorus and carbamate insecticides and their relationship to respective water solubility (S) values. J Environ Sci Health B18(6):667–683.
*Boyd EM, Carsky E. 1969. Kwashiorkorigenic diet and diazinon toxicity. Acta Pharmacol Toxicol 27(4):284–294.
*Bradway DE, Moseman R, May R. 1981. Analysis of Alkyl Phosphates by Extractive Alkylation. Bull Environ Contam Toxicol 26:520–523.7236910
*Braun HE, Frank R. 1980. Organochlorine and organophosphorus insecticides: Their use in eleven agricultural watersheds and their loss to stream waters in southern Ontario, Canada, 1975-1977. Sci Tot Environ 15:169–192.
*Brzezinski J. 1978. Effects of chlorfenvinfos on the disulfiram induced decrease of endogenous noradrenaline in the rat brain. Pol J Pharmacol Pharm 30(1):69–71.
*Bysshe SE. 1990. Bioconcentration factors in aquatic organisms. In: WJ Lyman, WF Reehl, DH Rosenblatt, eds. Handbook of chemical properties estimation methods. Environmental behavior of organic compounds. Washington, DC: American Chemical Society, 5-1 – 5-30.
*Camara MA, Navarro M, Navarro-Garcia S, . 1992. Catalytic degradation of chlorfenvinphos and methidathion deposited on kaolinite and bentonite saturated by different cations. J Environ Sci Health, Part B: Pestic Food Contam Agric Wastes 27(3):293–306.
*Chambers JE, Levi EL. 1992. Organophosphates: Chemistry, Fate, and Effect. San Diego, CA: Academy Press.
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations using physiologically-based pharmacokinetic modeling. Toxicol Ind Health 1:111–131.3843496
*Corneliussen PE. 1970. Pesticide residues in total diet samples. Pestic Monit J 4(3):89–105.5489544
*Coye MJ, Barnett PG, Midtling JE, . 1987. Clinical confirmation of organophosphate poisoning by serial cholinesterase analyses. Arch Intern Med 147:438–442.3827420
*Cupp CM, Kleiber G, Reigart R, . 1975. Hypothermia in organophosphate poisoning and response to PAM. J South Carolina Med Assoc 71(5):166–168.
*Davies DB, Holub BJ. 1980. Comparative subacute toxicity of dietary diazinon in the male and female rat. Toxicology and Applied Pharmacology 54:359–367.7394791
*Dean BJ. 1972. The mutagenic effects of organophosphorus pesticides on microorganisms. Arch Toxicol 30:67–74.
*Dolara P, Vezzani A, Caderni G, . 1993. Genetic toxicity of a mixture of fifteen pesticides commonly found in the Italian diet. Cell Biol Toxicol 9(4):333–343.8039010
*Domine D, Devillers J, Chastrette M, . 1992. Multivariant structure-property relationships (MSPR) of pesticides. Pestic Sci 35:73–82.
*Donninger C. 1971. Species specificity of phosphate triester anticholinesterases. Bull World Health Org 44(1–3):265–268.4999483
*Dudka J, Szczepaniak S. 1993. [Investigation of chlorfenvinphos influence on levels of free tryptophan in blood plasma of the rat]. Rocz Panstw Zakl Hig 44(2–3):199–203. [Polish]8016542
*Duggan RE, Corneliussen PE. 1972. Dietary intake of pesticide chemicals in the United States (III): June 1968-April 1970. Pestic Monit J 5:331–341.4133965
*Duggan RE, Corneliussen PE, Duggan MB, . 1983. Pesticide residue levels in foods in the United States from June 1, 1969 to June 30, 1976. Washington, DC: Food and Drug Administration, Division of Chemical Technology, 15, 22, 27, 30, 32, 33.
*Edson EF, Noakes DN. 1960. The comparative toxicity of six organophosphorous insecticides in the rat. Toxicol Appl Pharmacol 2:523–539.13725756
*Edwards CA, Thompson AR, Benyon KI, . 1968. Some effects of chlorfenvinphos, an organophosphorus insecticide, on populations of soil animals. Rev Ecol Biol Sol 5:199–224.
*Edwards MJ, Beynon KI, Edwards CA, . 1971. Movement of chlorfenvinphos in soil. Pestic Sci 2(1):1–4.
*Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
**Ellenhorn MJ, Barceloux DG. 1988. Medical Toxicology: Diagnosis and treatment of human poisoning. Elsevier. New York.
*Endo G, Horiguchi S, Kiyota I, . 1988. Serum cholinesterase and erythrocyte acetylcholinesterase activities in workers occupationally exposed to organophosphates. Proc. ICMR Semin. 8 Pr 561–564.
*EPA. 1976. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.3.
*EPA. 1978a. Memorandum Toxicology Branch Data review for chlorfenvienphos. Requested by Burroughs Wellcome. Tox review 003234 in FIA file #0001.
*EPA. 1978b. Memorandum Toxicology Branch. Amendment to existing regulations for reduction to the concentration of the active ingredient form 24.5 to 12.25.
*EPA. 1979. Memorandum Insecticide Rodenticide Branch EPA file symbol 59-RIO dermation dust caswell #187 Acute studies tox review 003232 in FIA file # 00001.
*EPA. 1982a. Memorandum Insecticide Rodenticide Branch EPA file symbol 59-Rot Dermaton flea collar acute studies tox review 001534 in FIA file # 0001.
*EPA. 1982b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.322.
*EPA. 1983. Memorandum Insecticide Rodenticide Branch EPA Reg No. 59-136. Dermaton II caswell No. 187 acute studies tox review 003231 in FIA file # 00001.
*EPA. 1987. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355 App. A.
*EPA. 1988. Chlorfenvinphos. In: Extremely Hazardous Substances. Superfund chemical profiles. Volume 1, A-L. U.S. Environmental Protection Agency. Park Ridge, NJ: Noyes Data Corporation, 323–326.
*EPA. 1990. Interim methods for development of inhalation reference doses. U.S. Environmental Protection Agency. EPA-600/8-90/066A.
*EPA. 1992a. Organophosphorus compounds by gas chromatography: capillary column technique. SW-846 Method 8141A. Test methods for Evaluating Solid Waste, Vol. IB: Laboratory Manual Physical/Chemical Methods. Office of Solid Waste and Emergency Response, U. S. Environmental Protection Agency, Washington, DC.
*EPA. 1992b. Method 1657. In: Methods for the determination of nonconventional pesticides in municipal and industrial wastewater. U.S. Environmental Protection Agency, Office of Water, Washington, DC. EPA/821/R-92-002.
*EPA. 1992c. Methods for the determination of nonconventional pesticides in municipal and industrial wastewater. U. S. Environmental Protection Agency, Office of Water. EPA 821-RR-92-002.
*EPA. 1992d. National Oil and Hazardous Substances Pollution Contingency Plan. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 300, App.B.
*EPA. 1993. Section 313. Toxic chemical release inventory reporting form R and instructions. Revised 1992 version. Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency, Washington, D.C. EPA 745-K-93-001.
*EPA. 1994. Response to Freedom of Information (FOI) request for chlofrenvinphos.
*EPA. 1995. Drinking water regulations and health advisories. Office of Water, U. S. Environmental Protection Agency. Washington D. C.
*EPA. 1996. National Oil and Hazardous Substances Contigency Plan; National Priorities List Update. Environmental Protection Agency. Code of Federal Regulations. 40 CFR. 300.
*Farm Chemicals Handbook. 1984. Chlorfenvinphos. Farm Chemicals Handbook, Pesticide Dictionary, 1984. Willoughby, OH: Meister Publishing Co., C50–C51.
*Farm Chemicals Handbook. 1993. Chlorfenvinphos. Farm Chemicals Handbook, Pesticide Dictionary, 1993. Willoughby, OH: Meister Publishing Co., C75–C76.
*FASE. 1996. Pesticide exports from US ports, 1992-1994. Foundation for Advancements in Science and Education. Los Angeles, CA.
*FDA. 1979. Birlane, Supona, chlorfenvinphos. Pesticide Analytical Manual, Vol. II. Pesticide Registry Section 180.322. 1–7.
*FDA. 1988. FDA pesticide program residue in foods1987. J Assoc Anal Chem 71(6):156A–174A.
*FDA. 1990. Residues in foods, 1989 (3rd annual FDA pesticide residue monitoring program report). J Assoc Off Anal Chem 73(5):127A–146A.
*FDA. 1991. Food and Drug Administration pesticide program - residues in foods - 1990. J Assoc Off Anal Chem 74(5):1–20.2026571
*FDA. 1992. US Food and Drug Administration pesticide program residues in food - 1991. J Assoc Off Anal Chem Int 75(5):135A–157A.
*FDA. 1993. Residue Monitoring. (Sixth annual report summarizing the results of the Food and Drug Administration). J Assoc Off Anal Chem Int 76(5):127A–148A.
*FDA. 1994. Residue monitoring. (Seventh annual report summarizing the results of the Food and Drug Administration). J AOAC Int 77(5):163–185.
*FDA. 1995. Residues in foods, (8th annual FDA pesticide residue monitoring program report). Journal of AOAC International 78(5):119A–142A.
*FEDRIP. 1994. Chlorfenvinfos. Federal Research in Progress. Dialog Information Services.
*Felthous JM. 1978. Pesticide poisoning fatality. Chem Eng News 56(16):67–68.
*Frank R, Braun HE, Ripley BD. 1990. Residues of insecticides and fungicides on Ontario-grown vegetables. Food Addit Contam 7(4):545–554.2394275
*Frank R, Logan L, Clegg BS. 1991. Pesticide and polychlorinated biphenyl residues in waters at the mouth of the Grand, Saugeen, and Thames Rivers, Ontario, Canada, 1986-1990. Arch Environ Contam Toxicol 21(4):585–595.1759852
*Gartell MJ, Craun JC, Podrebarac DS, . 1986. Pesticides, Selected Elements, and Other Chemicals in Infant and Toddler Total Diet Samples, October 1980-March 1982. J Assoc Off Anal Chem 69(1):123–145.3949685
*Gralewicz S, Kowalczyk W, Gorny R, . 1990. Brain electrical activity (EEG) after repetitive exposure to chlorphenvinphos an organophosphate anticholinesterase: I. Rabbit. Pol J Occup Med 3(1):51–67.2132936
*Gralewicz S, Tadeusz T, Socko R. 1995. Interaction of chlorphenvinphos with chlinergic receptors in the rabbit hypothalamus. Neurotoxicology and Teratology 17(3):289–295.7623739
*Gralewicz S, Tomas T, Socko R. 1989a. Effects of single exposure to chlorphenvinphos, an organophosphate insecticide, on electrical activity (EEG) of the rat brain. Pol J Occup Med 12(3):309–320.
*Gralewicz S, Tomas T, Gorny R, . 1989b. Changes in physiological and electrophysiological parameters in rabbits after single exposure to chlorphenvinphos. Pol J Occup Med 2(1):3–14.2489411
Gralewicz S, Tomas T, Gorny R, . 1991. Changes in brain bioelectrical activity (EEG) after repetitive exposure to an organo-phosphate anticholinesterase. II. Rat. Pol J Occup Med 4(2):183–196.
*Gunderson EL. 1988. FDA total diet study, April 1982-April 1984, dietary intakes of pesticides, selected elements and other chemicals. J Assoc Off Anal Chem 71:1200–1209.3240978
*Hansen LG. 1983. Biotransformation of organophosphorus compounds relative to delayed neurotoxicity. NeuroToxicology 4(1):97–111.6308528
*Harris JC. 1990. Rate of hydrolysis. In: Lyman WS, Reehl WF, Rosenblatt DH, eds. Handbook of Chemical Property Estimation Methods. Environmental Behavior of Organic Compounds. Washington, DC: American Chemical Society, 7–4.
*Hartley. 1987. The Agrochemicals Handbook. Second edition. Cambridge, England: Royal Society of Chemistry Information Services.
*Hayes AL, Wise RA, Weir FW. 1980. Assessment of occupational exposure to organophosphates in pest control operators. Am Ind Hyg Assoc J 41(8):568–575.7405825
*Hayes WJ, Jr. 1982. Pesticides Studied in Man. Baltimore, MD: Williams & Wilkins, 395–397.
*HazDat. 1994. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. Novenber 5, 1994.
*HazDat. 1996. Database. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
*Heikes DL, Craun JC. 1992. Rapid multiresidue procedure for the determination of pesticides in anhydrous lanolin and lanolin-containing pharmaceutical preparations utilizing gel permeation chromatography cleanup with gas chromatographic and mass spectrometric techniques. J Agric Food Chem 40(9):1586–1590.
*Hladk A, Kovac J, Krampl V. 1975. Residue determination of organophosphorus pesticides in animal tissue by temperature programmed GC (gas chromatography) and TLC (thin-layer chromatography) methods. Z Anal Chem 274:371–373.
*HSDB. 1994. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Program (via TOXNET), Bethesda, MD. May 1994.
*HSDB. 1996. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Program (via TOXNET), Bethesda, MD. January 1996.
*Hundley H, Cairns KT, Luke MA, . 1988. Pesticide residue findings by the Luke Method in domestic and imported foods and animal feeds for fiscal years 1982-1986. J Assoc Off Anal Chem 71(5):875–892.3235407
*Hunter CG. 1968. Percutaneous toxicity of an organophosphorus compound. Ind Med Surg 37(7):531.
*Hunter CG. 1969. Dermal toxicity of chlorfenvinphos (CFVP). Ind Med Surg 38(1):49–51.
*Hunter CG, Robinson J, Bedford CT, . 1972. Exposure to chlorfenvinphos by determination of a urinary metabolite. J Occup Med 14(2):119–122.5060736
*Hutson DH, Holmes DS, Crawford MJ. 1977. The involvement of glutathione in the reductive dechlorination of a phenacyl halide. Xenobiotica 7(1/2):107–115.
*Hutson DH, Logan CJ. 1986. Detoxification of the organophosphorus insecticide chlorfenvinphos by rat, rabbit and human liver enzymes. Xenobiotica 16(1):87–93.3946099
*Hutson DH, Millburn P. 1991. Enzyme-mediated selective toxicity of an organophosphate and a pyrethroid: Some examples from a range of animals. Biochem Soc Trans 19(3):737–740.
*Hutson DH, Wright AS. 1980. The effect of hepatic microsomal monooxygenase induction on the metabolism and toxicity of the organophosphorus insecticide chlorfenvinphos. Chem Biol Interact 31(1):93–101.
*Ikeda T, Tsuda S, Shirasu Y. 1991. Metabolic induction of the hepatic cytochrome P450 system by chlorfenvinphos in rats. Fundam Appl Toxicol 17(2):361–367.
*Ikeda T, Tsuda S, Shirasu Y. 1992. Pharmacokinetic analysis of protection by an organophosphorus insecticide, chlorfenvinphos, against the toxicity of its succeeding dosage in rats. Fundam Appl Toxicol 18(2):299–306.1601231
*Inch TD, Ley RV, Utley D. 1972. The mobility of some organophosphorus sheep dip insecticides in soil. Pestic Sci 3(3):243–253.
*IRIS. 1995. Integrated Risk Information System (IRIS). Online. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office, Cincinnati, OH May 1995.
*IRPTC. 1985. Treatment and disposal methods for waste chemicals. International Register of Potentially Toxic Chemicals, United Nations Environment Programme, Geneva Switzerland, 234.
*Iverson F, Grant DL, Lacroix J. 1975. Diazinon metabolism in the dog. Bull Environ Contam Toxicol 13(5):611–618.1148418
*Ivey MC, Oehler DD, Claborn HV. 1973. Gas-liquid chromatographic determination of chlorfenvinphos in milk, eggs, and body tissues of cattle and chickens. J Agric Food Chem 21(5):822–824.4733372
*Jelovsek FR, Mattison DR, Chen JJ. 1989. Prediction of risk for human developmental toxicity how important are animal studies for hazard identification. Obstet Gynecol 74(4):624–636.2797639
*Kadenczki L, Zoltan A, Gardi I. 1992. Pesticide and industrial chemical residues. Column extraction of residues of several pesticides from fruits and vegetables: A simple multiresidue analysis method. J Assoc Off Anal Chem Int 75(1):53–61.
*Kawar NS, De Batista GC, Gunther FA. 1973. Pesticide stability in cold stored plant parts soils and dairy products and in cold stored extractives solutions. Residue Rev 48:45–77.4137103
*Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Safety 4:26–38.7379718
*Klaassen CD, Amdur MD, Doull J, eds. 1986. Casarett and Doull’s toxicology. 3rd ed. New York, NY: MacMillian Publishing.
*Klemmer HW, Reichert ER, Yauger WL, Jr. 1978. Five cases of intentional ingestion of 25 percent diazinon with treatment and recovery. Clin Toxicol 12(4):435–444.
*Klys M. 1985. Studies on the applicability of gas chromatography with thermionic detection in systematic toxicological analysis. Part II. Studies on biological material taken from cases of fatal poisonings. Arch Med Sadowej Kryminol 35(1):33–38.
*Koeman JH, Debets FMH, Strik JJTWA. 1980. The porphyrinogenic potential of pesticides with special emphasis on organophosphorous compounds. Field worker exposure during pesticide application, studies in 1980.
*Kojima T, Tsuda S, Shirasu Y. 1992. Non-cholinergic mechanisms underlying the acute lethal effects of P = S type organophosphorus insecticides in rats. J Vet Med Sci 54(3):529–533.1386532
*Kolanowska H. 1977. The nitroblue-tetrazolium reduction test in evaluation of phagocytic activity of neutrophilic granulocytes. Acta Med Pol 18:123–137.883514
*Kolmodin-Hedman B, Eriksson K. 1987. Biological monitoring of exposure to organophosphates - A field study using cholinesterase estimation of whole blood dried on filter paper. Occup Environ Chem Haz 63:529–533.
*Kowalczyk-Bronisz S, Gieldanowski J, Bubak B, . 1992. Studies on effect of pesticide chlorfenvinfos on mouse immune system. Arch Immunol Ther Exp (Warsz) 40(5–6):283–289 1340183
*Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Principles and methods of toxicology. 3rd edition, Wallace Hayes, ed. New York, NY: Raven Press, Ltd.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: Toxicology of chemical mixtures, R.S.A. Yang, ed. áNew York, NY: Academic Press.
*Leoni V, Caricchia AM, Chiavarini S. 1992. Multiresidue method for quantitation of organophosphorus pesticides in vegetable and animal foods. J Assoc Off Anal Chem Int 75(3):511–518.
*Leung H. 1993. Physiologically-based pharmacokinetic modeling. In: General and Applied Toxicology, vol. I. Ballantine B, Marro T, Turner T, eds. New York, NY: Stockton Press, 153–164.
*Lores EM, Bradway DE. 1977. Extraction and recovery of organophosphorus metabolites from urine using an anion exchange resin. J Agric Food Chem 25:75–79.
*Luke MA, Masumoto HT, Chirns T, . 1988. Levels and incidences of pesticide residues in various foods and animal feeds analyzed by the luke multiresidue methodology for fiscal years 1982-1986. J Assoc Off Anal Chem 71:415–420.3384794
*Lyman WJ, Reehl WF, Rosenblatt DH, eds. 1990. Handbook of chemical property estimation methods. Environmental behavior of organic compounds. Washington, DC: American Chemical Society, 5-1 – 5-30.
*MacKay D. 1982. Correlation of Bioconcentration Factors. Environ Sci Technol 6:274–278.
*Maxwell IC, LeQuesne PM. 1982. Neuromuscular effects of chronic administration of two organophosphorus insecticides to rats. Neurotoxicology 3(1):1–10.
*Merck. 1989. The Merck index. Eleventh edition. S Budavari, ed. Merck & Co., Inc., 2084.
*Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
*Miles JRW, Harris CR, Moy P. 1978. Insecticide residues in organic soil of the Holland Marsh, Ontario, Canada, 1972-75. J Econ Entomol 71(1):91–101.
*Miles JRW, Harris CR, Tu CM. 1983. Influence of temperature on the persistence of chlorpyrifos and chlorfenvinphos in sterile and natural mineral and organic soils. J Environ Sci Health, Part B: Pestic Food Contam Agric Wastes 18(6):705–712.
*Miles JRW, Harris CR, Tu CM. 1984. Influence of moisture on the persistence of chlorpyrifos and chlorfenvinphos in sterile and natural mineral and organic soils. J Environ Sci Health B19(2):237–243.
*Miles JRW, Tu CM, Harris CR, . 1979. Persistence of eight organophosporus insecticides in sterile and non-sterile mineral and organic soils. Bull Environ Contam Toxicol 22(3):312–318.465800
*Moris P, Alexandre I, Roger M, . 1995. Chemiluminescence assays of organophosphorus and carbamate pesticides. Anal Chim Acta 302:53–59.
*Moriya M, Ohta T, Watanabe K, . 1983. Further mutagenicity studies on pesticides in bacterial reversion assay systems. Mutat Res 116(3–4):185–216.6339892
Moutschen J, Moutschen-Dahmen M, Degraeve N. 1984. Mutagenicity, carcinogenicity, and teratogenicity of insecticides. Mutagen Carcinog Teratog Ind Pollut 3:127–203.
*Mücke W, Alt KO, Esser HO. 1970. Degradation of 14C-labeled diazinon in the rat. J Argric Food Chem 18(2):208–212.
*Nagayama T, Maki T, Kan K, . 1989. Residues of organophosphorus pesticides in commercial tea and their leaching into tea. J Pestic Sci 14(1):39–46.
*Nakamura Y, Tonogai Y, Sekiguchi Y, . 1994. Multiresidue analysis of 48 pesticides in agricultural products by capillary gas chromatography. J Agri Fd Chem 42(11):2508–2518.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
*Neidert E, Trotman RB, Saschenbrecker PW. 1994. Levels and incidences of pesticide residues in selected agricultural food commodities available in Canada. J Assoc Off Anal Chem Int 77(1):18–33.
*NIOSH. 1992. Recommendations for occupational safety and health, compendium of policy documents and statements. US Department of Health and Human Services, National Institute for Occupational Safety and Health. Cincinnati OH.
*NOES. 1990. National Occupational Exposure Survey (1981-83): Chlorfenvinphos. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Cincinnati, OH.
*OSHA. 1974. Occupational Safety and Health Standards. Code of Federal Regulations. 29 CFR 1910.1000.
*Osicka-Koprowska A, Lipska M, Wysocka-Paruszewska B. 1984. Effects of chlorfenvinphos on plasma corticosterone and aldosterone levels in rats. Arch Toxicol 55(1):68–69.6732507
*Osumi Y, Fujiwara H, Oishi R, . 1975. Central cholinergic activation by chlorfenvinphos, an organophosphate, in the rat. Jpn J Pharmacol 25(1):47–54.807765
*OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Office of Technology Assessment, Washington, DC. OTA-BA-438.
*Ouellette RP, King JA. 1977. Chemical Week Pesticides Register. New York, NY: McGraw-Hill Book Co., 160.
*Pach J, Groszek B, Bogusz M. 1987. Haemoperfusion in treatment of acute poisoning with organophosphate pesticides. Mater Med Pol 19(2):118–121.3448415
*Paterson JE. 1970. Gas chromatographic determination of dioxathion and chlorfenvinphos in emulsifiable formulations and livestock dips. J Assoc Off Anal Chem 53(3):566–568.
*Poklis A, Kutz FW, Sperling JF, . 1980. A fatal diazinon poisoning. Forensic Sci Int 15(2):135–140.7358325
Pruett SB, Ensley DK, Crittenden PL. 1993. The role of chemical-induced stress responses in immunosuppression: A review of quantitative associations and cause-effect relationships between chemical-induced stress responses and immunosuppression. J Toxicol Environ Health 39(2):163–192.
*Puzynska L. 1984. Relationship between dietary protein level and enzymatic changes in acute poisoning of rats with chlorfenvinphos. Nahrung 28(8):779–787.
*Racke KD. 1992. Degradation of organophosphorus insecticides in environmental matrices. In: Chambers JE, Levi PE, eds. Organophosphates: Chemistry, fate, and effects. San Diego, CA: Academic Press, 47–78.
*REFS. 1995. Reference Files System. Chemistry for chlorfenvienphos data report.
Reiff BS, Lambert M, Natoff IL. 1971. Inhibition of brain cholinesterase by organophosphorus compounds in rats. Arch Int Pharmacodyn Therap 192:48–60.5093191
*Ritcey G, McEwen FL, Braun HE, . 1991. Persistence and biological activity of residues of granular insecticides in organic soil and onions with furrow treatment for control of the onion maggot (Diptera: Anthomyiidae). J Econ Entomol 84(4):1339–1343.
Roberts DV. 1976. E.M.G. voltage and motor nerve conduction velocity in organophosphorus pesticide factory workers. Int Arch Occup Environ Health 36:267–274.1254344
*Roberts TR, Stoydin G. 1976. Metabolism of the insecticide SD 8280, 2-chloro-1-(2,4-dichlorophenyl) vinyl dimethyl phosphate, following its application to rice. Pestic Sci 7:135–144.
*Roszkowski J. 1978. Immuno-morphological investigations on the effect of lindane, chlorfenvinphos, and carbaryl on immune reactions. I. Experiments On Rabbits. Bull Vet Inst Pulawy 22(1–2):25–30.
*Rouchaud J, Gustin F, Benoit F, . 1992b. Influence of cow manure and composts on the effects of chlorfenvinphos on field crops. Arch Environ Contam Toxicol 22(1):122–129.1313223
*Rouchaud J, Gustin F, Van de Steene F. 1991. Transport of the insecticides chlorpyrifos, chlorfenvinphos, carbonfuran, carbonsulfan, and furathiocarb from soil into the foilage of cauliflower and brussels sprouts plants grown in the field. Toxicol Environ Chem 30:79–94.
*Rouchaud J, Gustin F, Van de Steene F, . 1989b. Metabolism of chlorfenvinphos in both soil and plant of cauliflower and brussels sprouts field crops. Bull Environ Contam Toxicol 43(6):920–928.2597799
*Rouchaud J, Gustin F, Van de Steene F, . 1989c. Soil metabolism of insecticides and their protection efficiency. Rev Agric (Brussels) 42(6):1309–1326.
*Rouchaud J, Gustin F, Van de Steene F, . 1992a. Influences of the organic fertilizers treatments, the concentrations and chemical structures of soil organic matter, and the insecticides soil persistences and efficiencies in cauliflower crops. Meded Fac Landbouwwet, Univ Gen 57(3B):1173–1183.
*Rouchaud J, Metsue M, Van de Steene F, . 1989a. Influence of continuous monoculture and insecticide treatments on the rate of chlorfenvinphos soil biodegradation in cabbage crops. Bull Environ Contam Toxicol 42(3):409–416.2706351
*Rouchaud J, Roucourt P, Van de Steene F, . 1988. Fate of the insecticide chlorfenvinphos in the soil of cauliflower field crops. Bull Environ Contam Toxicol 40(1):47–53.3345365
*Ruzicka JH, Thomson J, Wheals B. 1967. The gas chromatographic determination of organophosphorus pesticides. J Chromatogr 3:37–47.
*Sasaki K, Suzuki T, Saito Y. 1987. Simplified cleanup and gas chromatographic determination of organophosphorus pesticides in crops. J Assoc Off Anal Chem 70(3):460–464.3610958
*Schattenberg H J III, Hsu J-P. 1992. Pesticide residue survey of produce from 1989 to 1991. J Assoc Off Anal Chem Int 75(5):925–933.
*Schenker MB, Albertson TE, Saiki CL. 1992. Pesticides (chapter 71). In: Rom WN, ed. Environmental and Occupational Medicine. 2nd edition. Boston, MA: Little, Brown and Company, 637–639, 893–894.
*Schlett C. 1991. Multi-residue-analysis of pesticides by HPLC after solid phase extraction. Fresenius J Anal Chem 339(6):344–347.
*Shankar PS. 1967. Pulmonary oedema in diazinon poisoning. Indian J Chest Dis 9(2):106–110.5634269
*Shankar PS. 1978. Diazinon poisoning. Quarterly Medical Review 16:31–43.
Sharma RP, Reddy RV. 1987. Toxic effects of chemicals on the immune system. In: T.J. Haley, W.O. Berndt, eds. Handbook of Toxicology. New york, NY: Hemisphere Publishing Corp., 555–591.
*Shirasu Y. 1973. Significance of mutagenicity testing on pesticides. The Institute of Environmental Toxicology, Suzuki-cho 2-772 Kodaira, Tokyo 187, Japan.
*Shirasu Y, Moriya M, Kato K, . 1976. Mutagenicity screening of pesticides in the microbial system. Mutat res 40:19–30.814455
*Singh AK, Hewetson DW, Jordon KC, . 1986. Analysis of organophosphorus insecticides in biological samples by selective ion monitoring gas chromatography-mass spectrometry. J Chromatogr 369:83–96.3793834
*Skibniewska KA, Smoczynski S. 1985. Influence of storage and thermal processes on stability of certain organophosphate insecticides in milk. Milchwissenschaft 40(2):84–85.
*Skonieczna M, Wierciak M, Scisllowska I, . 1981. Influence of chlorfenvinphos and ipofos on oxido-reducing processes in the rat brain mitochondria during development. Neuropatol Pol 19(2):197–208.7301129
Socko R, Gralewicz S, Gorny R. 1989. Neurotoxicity of chlorphenvinphos an organophosphorus pesticide: Effects on blood and brain cholinesterase activity, open field behavior and response-to-change in a “T” maze in rats. Pol J Occup Med 2(3):294–308.2489432
*Specht W. 1990. Determination of pesticide residues in cosmetics with special reference to matrix sample preparation. Parfuem Kosmet 71(4):234–235, 238, 240.
*Spencer EY. 1982. Chlorfenvinphos. Guide to the Chemicals Used in Crop Protection. Seventh edition. Research Branch, Agriculture Canada, London, Ontario, 106.
*SRC. 1995. AOPWIN. Atmospheric oxidation program for Microsoft Windows 3.1, version 1.65. Meylan W, and Howard P, eds. Syracuse, NY: Syracuse Research Corporation.
*SRI. 1993. 1993 Directory of Chemical Producers, United States of America. Menlo Park, CA: Stanford Research Institute, International, 520, 808.
*Stijve T. 1984. Determination and occurrence of organophosphorus pesticide residues in milk. Spec Publ - R Soc Chem 49:293–302.
*Studdert VP. 1985. Incidence of poisoning in dogs and cats in Melbourne, Australia. Aust vet j 62(4):133–135.4026722
*Suett DL. 1971. Persistence and degradation of chlorfenvinphos, diazinon, fonofos and phorate in soils and their uptake by carrots. Pestic Sci (2):105–112.
*Suett DL. 1974. Uptake of chlorfenvinphos and phorate from soil by carrots as influenced by mode of application and cultivar. Pestic Sci 5(1):57–71.
*Suett DL. 1975a. Factors influencing the accumulation of organophosphorus insecticides by carrots. Environ Qual Saf, Suppl. 3:140–145.
*Suett DL. 1975b. Persistence and degradation of chlorfenvinphos, chlormephos, disulfoton, phorate and pirimiphos-ethyl following spring and late-summer soil application. Pestic Sci 6(4):385–393.
*Suett DL. 1977. Influence of soil tilth and method of application of chlorfenvinphos on its persistence and distribution in soil and uptake by cauliflowers. Meded Fac Landbouwwet Rijksuniv Gent 42(2):1779–1788.
*Susse H, Muller H. 1995. Application of micellar electrokinetic capillary chromatography to the analysis of pesticides. Fresenius J Anal Chem 352:470–473.
*Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters, octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85:17–28.
*Szczepaniak S, Sienkiewitcz E. 1980. [Aminoacid elimination in rat urine following acute intoxication with chlorfenvinphos.] Bromatol Chem Toksykol 13(1):31–36. [Polish]
*Taitelman U. 1992. Organophosphate poisoning. In: J.B. Hall, G.A. Schmidt, L.D.H. Wood, eds. Principles of critical care. New York, NY: McGraw-Hill, Inc., 2176–2182.
*Takahashi H, Kojima T, Ikeda T. 1991. Differences in the mode of lethality produced through intravenous and oral administration of organophosphorus insecticides in rats. Fundam Appl Toxicol 16(3):459–468.1855619
*Takahashi H, Yoshida M, Murao N, . 1994. Different inhalation lethality between micron-sized and submicron-sized aerosols of organophosphorus insecticide, chlorfenvinphos, in rats. Toxicol Lett 73(2):103–111.8048079
*The Agrochemicals Handbook. 1991. Chlorfenvinphos. The Agrochemicals Handbook 3rd edition. Royal Society of Chemistry Information Services, Cambridge, England.
*Thier H-P, Zeumer H. 1987. Organochlorine, organophosphorus, nitrogen-containing and other compounds. Method S19. In: H-P Thier, H Zeumer, eds. Manual of Pesticide Residue Analysis, vol. I. Deutsche Forschungsgemeinschaft. New York, NY: VCH Publishers, 383–400.
*Thomas RG. 1990. Volatilization from water. In: Lyman WS, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. Environmental behavior of organic compounds. Washington, DC: American Chemical Society, 15–16.
*Tsuda S, Iwasaki M, Yoshida M, . 1986. Effect of particle size on inhalation toxicity of chlorfenvinphos. Nippon Juigaku Zasshi 48(4):729–737.3761781
*Veith GD, DeFoe DL, Bergstedt BV. 1979. Measuring and estimating the bioconcentration factor of chemicals in fish. J Fish Res Board Can 36:1040–1048.
*Veith GD, Macek KJ, Petrocelli SR, . 1980. An evaluation of using partition coefficients and water solubility to estimate bioconcentration factors for organic chemicals in fish. J Fish Res Board Can 38:421–430.
*Verschueren K, ed. 1983. Chlorfenvinphos. In: Handbook of Environmental Data on Organic Chemicals, Second edition. New York, NY: Van Nostrand Reinhold Co., 53–54.
*Vestweber JG, Kruckenberg SM. 1972. The effect of selected organophosphorous compounds on plasma and red blood cell cholinesterase in the dog. Vet Med Small Animal Clin 67(7):803–806.
*Vishwanath R, JAMIL k. 1986. Mutagenic and genotoxic activities of certain organophosphorus compounds, using Ames salmonella assay, with and without microsomal induction. Indian J Exp Biol 24:305–308.3533767
*Vitorovic SL. 1982. A simple approach to analysis of organophosphous pesticide residues in toxicology studies. International Union of Pure and Applied Chemistry 101–104.
*Vitorovic SL. 1983. A simple approach to analysis of organophosphorus pesticide residues in toxicology studies. In: R Greenhalgh, N Drescher, eds. Pesticide chemistry: Human welfare and the environment. Volume 4: Pesticide residues and formulation chemistry. New York, NY: Pergamon Press, 101–104.
*Wagner U, Schlebusch H, van der Ven K, . 1990. Detection of phosphate ester pesticides and the triazine herbicide atrazine in human milk, cervical mucus, (and) follicular and sperm fluid. Fresenius’ J Anal Chem 337:77–78.
*Wan MT, Szeto S, Price P. 1994. Organophosphorus insecticide residues in farm ditches of the Lower Fraser Valley of British Columbia. J Environ Sci Health, Part B: Pestic Food Contam Agric 29(5):917–949.
*Wiaderkiewicz R, Walter Z, Reimschussel W. 1986. Sites of methylation of DNA bases by the action of organophosphorus insecticides in vitro. Acta Biochim Pol 33(2):73–85.3766014
*Williams JH. 1975a. Persistence of chlorfenvinphos in soils. Pestic Sci 6(5):501–509.
*Williams JH. 1975b. The role of organic matter in pesticide behavior. Report - Welsh Soils Discussion Group 16:107–119.
*Williams MW, Fuyat HN, Fitzhugh OG. 1959. The subacute toxicity of four organic phosphates to dogs. Toxicol Appl Pharmacol 1:1–7.13625311
*Williams PL, Burson JL, eds. 1985. Industrial toxicology: Safety and health applications in the workplace. New York, NY: Van Nostrand Reinhold Company.
*Woo OF. 1990. Organophosphates. In: Olsen KR, ed. Poisoning and drug overdose. 1st ed. San Francisco Bay Area Regional Poison Control Center. Norwalk, CT: Appleton and Lange, 225–229, 394.
*Worthing CR. 1987. Chlorfenvinphos. The Pesticide Manual 107.
*Worthing CR, ed. 1983. Chlorfenvinphos. In: The Pesticide Manual, A World Compendium, Seventh edition. The British Crop Protection Council.
*Wysocka-Paruszewska BA, Osicka A, Brzezinski J. 1980. An evaluation of the toxicity Of thiuram in combination with other pesticides. Arch Toxicol, Suppl. 4:449–451.
*Wysocki J, Kalina Z, Owczarzy I. 1987. Effect of organophosphoric pesticides on the behaviour of NBT-Dye reduction and E Rosette Formation Tests in Human Blood. Int Arch Occup Environ Health 59:63–71.3793246
*Yess NJ, Houston MG, Gunderson EL. 1991a. Food and Drug Administration pesticide residue monitoring of foods: 1978-1982. J Assoc Off Anal Chem 74(2):265–272.2050608
*Yess NJ, Houston MG, Gunderson EL. 1991b. Food and Drug Administration pesticide residue monitoring of foods: 1983-1986. J Assoc Off Anal Chem 74(2):273–280.2050609
Yoshikawa H, Yoshida M, Hara I. 1990. Electroretinographic changes induced by organophosphorus pesticides in rats. J Toxicol Sci 15(2):87–95.1697627
*Zwiener RJ, Ginsburg CM. 1988. Organophosphate and carbamate poisoning in infants and children. Pediatrics 8(1):121–126.