# 7 REGULATIONS AND ADVISORIES

The national regulations and guidelines regarding chlorfenvinphos in air, food, and other media are summarized in Table 7-1. No international or state regulations were identified for chlorfenvinphos, nor were regulations and guidelines identified for chlorfenvinphos in air or water.

ATSDR has not derived MRLs for inhalation exposure for any duration of exposure.

An acute oral MRL of 0.002 mg/kg/day for chlorfenvinphos has been developed from a LOAEL of 2.4 mg/kg/day, based on adverse neurological effects in rats (Barna and Simon 1973).

An intermediate oral MRL of 0.002 mg/kg/day for chlorfenvinphos has been developed from a LOAEL of 1.5 mg/kg/day, based on adverse immunological/lymphoreticular effects in mice (Kowalczyk-Bronisz et al. 1992).

A chronic oral MRL of 0.0007 mg/kg/day for chlorfenvinphos has been developed from a LOAEL of 0.7 mg/kg/day, based on adverse neurological effects in rats (Ambrose et al. 1970).

No reference concentration or dose exists for chlorfenvinphos, and no IARC or EPA cancer classification exists.

Chlorfenvinphos is one of the chemicals regulated under “The Emergency Planning and Community Right-to-Know Act of 1986” (EPCRA) (EPA 1987). Section 313 of Title III of EPCRA requires owners and operators of certain facilities that manufacture, import, process, or otherwise use the chemicals on this list to report annually their release of those chemicals to any environmental media.

An Occupational Safety and Health Administration (OSHA) permissible exposure limit (PEL) for chlorfenvinphos does not exist, nor is it regulated by the Clean Water Effluent Guidelines contained in Title 40, Sections 400-475, of the Code of Federal Regulations.

Tolerances for chlorfenvinphos in agricultural products have been established (EPA 1982b).

Table 7-1 Regulations and Guidelines Applicable to Chlorfenvinphos

Agency | Description | Information | References
[underlined: INTERNATIONAL]
IARC | Carcinogenic classification | None
[underlined: NATIONAL]
Regulations:
a. Food
FDA | FDA action level | None
EPA OPTS | Tolerances for Related Pesticide Chemicals | Yes | 40 CFR 180.3, EPA 1976
EPA OPTS | Tolerance Range for Agriculture Products | 0.005–0.2 ppm | 40 CFR 180.322, EPA 1982b
b. Other
EPA | Carcinogen Classification | None | IRIS 1995
EPA | Reference Dose (RfD) | None | IRIS 1995
EPA | Reference Concentration (RfC) | None | IRIS 1995
EPAOERR | Threshold Planning Quantity | 500 Ib. | 40 CFR 355, App A, EPA 1987
EPAOERR | Reportable Quantity | 500 Ib. | 40 CFR 355, App A, EPA 1996
EPAOERR | App. B - National Priorities List | Yes | 40 CFR 300, EPA 1992d

EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; LDR = Land Disposal Restrictions; NIOSH = National Institute for Occupational Safety and Health; OERR = Office of Emergency and Remedial Response; OSW = Office of Solid Wastes; REL = Recommended Exposure Limit; TWA = time-weighted average