# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Chlorfenvinphos is a synthetic organophosphorus insecticide that has been used as a soil or foliar insecticide. It was also used to control insect pests on livestock and to control household pests. Information regarding the chemical identity of chlorfenvinphos is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Chlorfenvinphos is a vinyl organophosphate insecticide. The technical material is an amber liquid with a mild odor containing about 80–90% chlorfenvinphos (trans and cis isomers with a typical ratio of 8.5:1). It is sparingly soluble in water, but miscible with most organic solvents. It hydrolyzes slowly in water, but is unstable in alkali (Worthing 1983). Information regarding the physical and chemical properties of chlorfenvinphos is located in Table 3-2.

Table 3-1 Chemical Identity of Chlorfenvinphos

Characteristic | Information | Reference
Chemical name | 2-chloro-1-(2,4-dichlorophenyl) vinyl diethyl phosphate | Worthing 1983
Synonym(s) | Phosphoric acid 2-chloro-1-(2,4-dichlorophenyl)ethenyl diethyl ester; O,O-diethyl O-[2-chloro-1-(2,4-dichlorophenyl)vinyl] phosphate; 2,4-dichloro-α-(chloromethylene)benzyl alcohol diethyl phosphate | Merck 1989
Registered trade name(s) | CVP; SD 7859; Compound 4072; Birlane; Dermaton; Sapecron; Steladone; Supona | Merck 1989
Chemical formula | C_12_H_14_Cl_3_O_4_P | Worthing 1983
Chemical structure | [image] | Worthing 1983
Identification numbers:
CAS Registry | 470-90-6 | Merck 1989
NIOSH RTECS | TB 8750000 | HSDB 1996
EPA Hazardous Waste | No data
OHM/TADS | 810041 | HSDB 1996
DOT/UN/NA/IMCO | UN 2783 Organophosphorus pesticide | HSDB 1996
HSDB | 1540 | HSDB 1996
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Physical and Chemical Properties of Chlorfenvinphos

Property | Information | Reference
Molecular weight | 359.56 | Merck 1989
Color | Amber liquid (Technical) | Merck 1989
Color | Colorless liquid | Hartley 1987
Physical state | Liquid | Merck 1989
Melting point | −19 to −23 °C (Technical) | Worthing 1987
Melting point | −16 to −22 °C | Ouellette 1977
Boiling point at 0.01 mm | 120 °C (Technical) | Merck 1989
Boiling point at 0.5 mm | 167–170 °C (Technical) | Merck 1989
Density at 25 °C | 1.5272 g/mL | Merck 1989
Odor | Mild odor | Merck 1989
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 23 °C | 145 ppm | Merck 1989
Organic solvent(s) | Miscible with acetone, ethanol, propylene glycol, dichloro-methane, hexane, xylene | Merck 1989; Worthing 1983
Partition coefficients:
Log K_ow_ | 3.806 | Bowman and Sans 1983
Log K_oc_ | 2.45 | Kenaga 1980
Vapor pressure at 25 °C | 4×10^−6^ mm Hg | Worthing 1983
Vapor pressure at 25 °C | 7.5×10^−6^ mm Hg | Merck 1989
Vapor pressure at 25 °C | 1.7×10^−7^ mm Hg | Verschueren 1983
Henry’s law constant: at 25 °C | 1.53×10^−8^ atm-m^3^/mol | HSDB 1996
Henry’s law constant: at 25 °C | 2.76×10^−9^ atm-m^3^/mol | Domine et al. 1992
Autoignition temperature | No data
Flashpoint | No data
Flammability limits at 25 °C | No data
Conversion factors (25 °C) | 1 ppm = 14.7 mg/m^3^
Conversion factors (25 °C) | 1 mg/m^3^ = 0.068 ppm
Explosive limits | No data