# APPENDIX A ATSDR MINIMAL RISK LEVEL

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

## Chlorfenvinphos Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Chlorfenvinphos
CAS number: | 470-90-6
Date: | August 21, 1996
Profile status: | Final
Route: | [] Inhalation [x] Oral
Duration: | [x] Acute []Intermediate [] Chronic
Key to figure: | 13
Species: | Rat

MRL: 0.002 [x] mg/kg/day [] ppm [] mg/m^3^

[underlined: Reference:] Barna J, Simon G. 1973. The effect of chlorfenvinphos insecticide in small often repeated dose. Cereal Research Commun. Vol.1, No. 3: 33–44.

[underlined: Experimental design] (human study details or strain, number of animals per exposure/control group, sex, dose administration details):

Two groups (55/group) of adult female albino (Wistar) rats weighing 208 g were orally administered Birlane^®^ (chlorfenvinphos) at dose of 0 or 2.4 mg/kg/day in the diet for 10 days. The study was designed to investigate the effects of oral chlorfenvinphos on body weight increase, the gastrointestinal absorption of glucose, Na^+^, and Ca^2+^, as well as he effects of oral chlorfenvinphos on plasma and erythrocyte cholinesterase activity levels.

[underlined: Effects noted in study and corresponding doses:]

Plasma cholinesterase activity was inhibited by 52% while erythrocyte cholinesterase activity level was inhibited by 30% at a dose of 2.4 mg/kg/day (the only dose tested). Gastrointestinal (g.i.) absorption of glucose was increased by 30% over control values while Na^+^ absorption was decreased by 32% below control values. Gastrointestinal absorption of Ca^2+^ and body weight increases were unaffected by chlorfenvinphos exposure. These changes in the gastrointestinal absorption of glucose and Na^+^ were not considered statistically significant (P>0.05) by the investigators.

[underlined: Dose endpoint used for MRL derivation:]

[] NOAEL [x] LOAEL

2.4 mg/kg/day; 30% decrease in erythrocyte cholinesterase activity in female rats.

[underlined: Uncertainty factors used in MRL derivation:]

[] 1 [] 3 [x] 10 (for use of a LOAEL)

[] 1 [] 3 [x] 10 (for extrapolation from animals to humans)

[] 1 [] 3 [x] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

If so, explain: No, the doses used are author-provided.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure?]

Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

Neurological effects, mediated by cholinesterase inhibition, is the principal and most sensitive toxicological consequence of acute-duration exposure to chlorfenvinphos in humans (Cupp et al. 1975; Pach et al. 1987). Chlorfenvinphos also inhibits noradrenaline in the central nervous system (Brzezinski 1978). Human subjects, exposed to large acute doses of chlorfenvinphos, exhibited severe cholinergic signs. These cholinergic signs were relieved by the administration of atropine and/or pralidoxime, indicating cholinesterase inhibition etiology (Cupp et al. 1975; Pach et al. 1987). In rats, relatively moderate to low doses (2.4–30 mg/kg) of oral chlorfenvinphos significantly inhibited cholinesterase activities in a number of tissue including the brain, erythrocyte, and plasma (Osumi et al. 1975; Osicka-Koprowska et al. 1984; Puzynska 1984). An acute-duration oral study also found alterations in noradrenaline level in rat brain following exposure to chlorfenvinphos. A chlorfenvinphos dose of 13 mg/kg decreased noradrenaline levels in rat brains by 20%, as compared to control rats. According to the investigators, chlorfenvinphos accelerated the rate of NA disappearance from the brain (Brzezinski 1978).

Therefore, it is appropriate to base the acute oral MRL for chlorfenvinphos on cholinesterase inhibition.

It should be noted that a study by Osumi et al. (1975) which determined a NOAEL of 1 mg/kg/day and a LOAEL of 2 mg/kg/day for 38% inhibition of brain cholinesterase in rats was not used to calculate an acute oral MRL because of the gavage (oral) route of administration of the test substance which was deemed less appropriate by the ATSDR MRL Workgroup. An oral feeding study is preferred by the ATSDR MRL Workgroup.

[underlined: Agency Contact (Chemical Manager):] Alfred Dorsey.

## Chlorfenvinphos Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Chlorfenvinphos
CAS number: | 470-90-6
Date: | August 21, 1996
Profile status: | Final
Route: | [] Inhalation [x] Oral
Duration: | [] Acute [x]Intermediate [] Chronic
Key to figure: | 23
Species: | Mouse

MRL: 0.002 [x] mg/kg/day [] ppm [] mg/m^3^

[underlined: Reference:] Kowalczyk-Bronisz S, Gieldanowski J, Bubak, Kotz J. 1992. Studies on the effect of pesticide chlorfenvinfos on mouse immune system. Arc Immunol Ther Exp (Warsz) 40(5–6):283–289.

[underlined: Experimental design] (human study details or strain, number of animals per exposure/control group, sex, dose administration details):

The authors investigated the effect of chlorfenvinphos on mouse immune system. In the study, male and female inbred C57BL/6 mice and (C57BL/6 × DBA/2)F1 (BDF1/Iiw) hybrids mice (6-8 weeks old) were orally dosed with chlorfenvinphos (suspended in 1% methylcellulose solution) and evaluated for 5 days for the effect of chlorfenvinphos exposure on the mouse immune system. The rats were exposed to oral chlorfenvinphos doses of 0, 1.5, 3, and 6 mg/kg (0, 1/100, 1/50, and 1/25 LD_50_) daily for 3 months; control group was given 1% methylcellulose. Then exposed and control mice were immunized by intraperitoneal injections of 0.2 mL 10% SRBC. IgM-PFC (plaque-forming or antibody-producing cells) number in spleen cell suspension was tested on day 4 after immunization and the procedure repeated 3 weeks after the exposure to chlorfenvinphos had been ceased. Exposed and control groups were subjected to immunological tests and hematological examinations. Lymphatic organs were histologically examined.

[underlined: Effects noted in study and corresponding doses:]

A dose-related decrease in number of hemolysin producing cells was observed: plaque-forming cells (PFC) were 58% at the 6 mg/kg dose group and 85% at the 3 mg/kg dose level as compared to control values. Chlorfenvinphos treatment also caused reduction in E rosettes forming cell number by 30% at the 6 mg/kg dose level and by 25% at the 3 mg/kg dose level. Increases in Interlukin-1 (Il-1) activity and DTH reaction were observed 24 hours after challenge. Spleen colonies were stimulated as evidenced by the increase of endogenous spleen colonies and exogenous spleen colonies (CFU-S) increased 190% at the 1.48 mg/kg dose level and 137% at the 6 mg/kg dose level, and 162% at 1.5 mg/kg dose level and 70% at the 6 mg/kg dose level, respectively). When the IgM PFC number was tested 3 weeks latter, after the exposure to chlorfenvinphos in the small dose (1.5 mg/kg), and increase (about 40%) in plaques number was observed. There was a 50% reduction in thymus weight at the 1.5 mg/kg dose level as compared to controls as well as significant involution of thymus was noted.

[underlined: Dose endpoint used for MRL derivation:]

[] NOAEL [x] LOAEL

1.5 mg/kg/day; 190% increase of spleen endogenous colonies; 162% increase of spleen exogenous colonies; 50% reduction in thymus weight.

[underlined: Uncertainty factors used in MRL derivation:]

[] 1 [] 3 [x] 10 (for use of a LOAEL)

[] 1 [] 3 [x] 10 (for extrapolation from animals to humans)

[] 1 [] 3 [x] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

If so, explain: Doses were provided as 1/100, 1/50, and 1/25 of the LD_50_ (148 mg/kg) by the authors, resulting in doses of 1.5, 3, and 6 mg/kg, respectively.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure?]

Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

In other studies, adverse immunolymphoreticular effects has been associated with exposure to oral chlorfenvinphos. In an intermediate-duration dietary study with albino (Wistar) rats, there was a significant and irreversible reduction in relative spleen weight of female rats given $3 mg/kg/day chlorfenvinphos for 12 weeks (Ambrose et al. 1970). A study was undertaken to evaluate selected serological and cytoimmunological reactions in rabbits subjected to a long-term poisoning with subtoxic oral doses (10 mg/kg in a soya oil solution with a small amount of food) of chlorfenvinphos for 90 days. Chlorfenvinphos treatment significantly elevated serum hemagglutinin level (16%) and hemolysin activity (66%, P<0.05) as well as increased the number of nucleated lymphoid cells producing hemolytic antibody to sheep erythrocytes as compared to controls (treated 906, P<0.05 and controls 618). Spleen cytomorphology changes, manifested mainly as transformation of primary follicles into secondary ones with well developed germinal centers, were also observed (Roszkowski 1978).

Therefore, it is appropriate to base the intermediate oral MRL for chlorfenvinphos on immunological effects.

[underlined: Agency Contact (Chemical Manager):] Alfred Dorsey.

## Chlorfenvinphos Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Chlorfenvinphos
CAS number: | 470-90-6
Date: | August 21, 1996
Profile status: | Final
Route: | [] Inhalation [x] Oral
Duration: | [] Acute []Intermediate [x] Chronic
Key to figure: | 34
Species: | Rat

MRL: 0.0007 [x] mg/kg/day [] ppm [] mg/m^3^

[underlined: Reference:] Ambrose AM, Larson PS, Borzelleca JF, Hennigar GR. 1970. Toxicologic studies on diethyl-1-(2,4-dichlorophenyl)-2-chlorovinyl phosphate. Toxicology and Applied Pharmacology, 17:323–336.5471553

[underlined: Experimental design] (human study details or strain, number of animals per exposure/control group, sex, dose administration details):

The authors conducted toxicological studies with chlorfenvinphos in weaning albino (Wistar) rats. In the study, four matched groups of weaning albino (Wistar) rats (30 rats/sex/group) were culled to a narrow starting weight range and fed daily GC-4072 (technical chlorfenvinphos) doses of 0, 0.7, 2.1, 7, or 21 mg/kg/day (males) or 0, 0.8, 2.4, or 8, or 24 mg/kg/day (females) in the diet for 104 weeks. An additional group of non-littermate rats (30/sex) were administered 21 mg/kg/day (males) or 24 mg/kg/day (females) chlorfenvinphos for 104 weeks. Plasma and erythrocyte cholinesterase (ChE) activity levels were obtained from 4 rats of each sex per dose group at 1, 4, 8, and 12 weeks. At 13 weeks, 4 rats/sex/dose group were sacrificed for histopathologic examination. At 13 weeks, 4 rats/sex/dose group were sacrificed for histopathologic examination. The rats in the 21 mg/kg/day (males) and 24 mg/kg/day (females) were sacrificed on the 95th week while all other dose group animals were sacrificed on the end of the study (104 weeks). At each autopsy, relative organ weights were determined for heart and kidneys. All animals sacrificed in moribund condition as well as those sacrificed at week 13, 95, and 104 weeks were examined grossly and microscopically and organs (heart, lungs, liver, kidney, urinary bladder, spleen, stomach, small and large intestine, skeletal muscle, skin, bone marrow, pancreas, thyroid, adrenal, pituitary) from these animals were histopathologically examined. Chlorfenvinphos significantly decreased body weight gain of females at the 8 and 24 mg/kg/day dose groups from the 26th week till towards the end of the study, although, the decreased body weight gain became not statistically significant at the end of the study. Increased relative liver weights were observed in males at the 7 mg/kg/day dose level but no other signs of hepatopathology was reported. No consistent difference in body weight gains in males, survival of the test animals, food consumption, or mortality was evident at all dose levels tested, as compared to undosed controls. Essentially, no gross or microscopic histopathology were evident in all the organs (heart, lungs, liver, kidney, urinary bladder, spleen, stomach, small and large intestine, skeletal muscle, skin, bone marrow, pancreas, thyroid, adrenal, pituitary) tissues examined. No changes in organ-to-body weight were observed in the heart, kidney, spleen and testes (Ambrose et al. 1970).

[underlined: Dose endpoint used for MRL derivation:]

[] NOAEL [x] LOAEL

0.7 mg/kg/day; 45% inhibition of plasma cholinesterase activity; 33% inhibition of erythrocyte cholinesterase activity

[underlined: Uncertainty factors used in MRL derivation:]

[] 1 [] 3 [x] 10 (for use of a LOAEL)

[] 1 [] 3 [x] 10 (for extrapolation from animals to humans)

[] 1 [] 3 [x] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

If so, explain: Doses, provided as food concentrations (10, 30, 100, or 300 ppm), were converted to doses in mg/kg/day using rat daily food intake factor for chronic Wistar rat obtained from EPA (1988).

CALCULATIONS: 10 ppm =10 mg/kg; Male - 10 mg/kg × 0.07 mg/kg/day (chronic male Wistar rat food factor) = 0.7 mg/kg/day; 30 ppm = 2.1 mg/kg/day; 100 ppm = 7 mg/kg/day; 300 ppm = 21 mg/kg/day: Female - 10 mg/kg × 0.08 mg/kg/day (chronic female Wistar rat food factor) = 0.8 mg/kg/day; 30 ppm = 2.4 mg/kg/day; 100 ppm = 7 mg/kg/day; 300 ppm = 24 mg/kg/day.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure?] Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

Although the neurological effects of human prolonged exposure to low oral doses of chlorfenvinphos is not known due to a dearth of studies, acute-duration exposure data indicate that neurological effects, mediated by cholinesterase inhibition, is the most sensitive toxicological consequence of human exposure to chlorfenvinphos (Cupp et al. 1975; Pach et al. 1987; Taitelman 1992). Similarly, chlorfenvinphos significantly inhibited both plasma and erythrocyte cholinesterase activities in Beagle dogs (2/sex) fed daily chlorfenvinphos doses of 0, 0.3, 2, or 10 mg/kg/day (males), or 0, 1.5, 10, or 50 mg/kg/day (females) in the diet (moist) for 104 weeks. Plasma cholinesterase activities were significantly inhibited at all dietary levels through week 39 of the study; 49% inhibition at the 0.3 mg/kg/day (males) and 1.5 mg/kg/day (females) dose levels. Erythrocyte cholinesterase activity was significantly and consistently inhibited (36%) during the first 12 weeks only in the 10 mg/kg/day (males) and 50 mg/kg/day (females) dose levels (Ambrose et al. 1970).

Therefore, it is considered appropriate to use this endpoint for developing a chronic oral MRL for chlorfenvinphos.

[underlined: Agency Contact (Chemical Manager):] Alfred Dorsey.