# 9 REFERENCES

* Cited in text

Abdel-Rahman MS, Scatina J. 1985. The effect of Alcide^®^, a new antimicrobial drug, on rat blood glutathione and erythrocyte osmotic fragility, in vitro. J Appl Toxicol 5(3):178–181.4008865
*Abdel-Rahman MS, Couri D, Bull RJ. 1980a. Kinetics of ClO_2_ and effects of ClO_2_, ClO_2_^−^, and ClO_3_^−^ in drinking water on blood glutathione and hemolysis in rat and chicken. J Environ Pathol Toxicol 3:431–449.6993617
*Abdel-Rahman MS, Couri D, Bull RJ. 1982. Metabolism and pharmacokinetics of alternate drinking water disinfectants. Environ Health Perspect 46:19–23.7151761
*Abdel-Rahman MS, Couri D, Bull RJ. 1984a. The kinetics of chlorite and chlorate in the rat. J Am Coll Toxicol 3(4):261–267.
*Abdel-Rahman MS, Couri D, Bull RJ. 1984b. Toxicity of chlorine dioxide in drinking water. J Am Coll Toxicol 3(4):277–284.
Abdel-Rahman MS, Couri D, Bull RJ. 1985a. The kinetics of chlorite and chlorate in rats. J Environ Pathol Toxicol Oncol 6(1):97–103.4067839
Abdel-Rahman MS, Couri D, Bull RJ. 1985b. Toxicity of chlorine dioxide in drinking water. J Environ Pathol Toxicol Oncol 6(1):105–113.4067828
*Abdel-Rahman MS, Couri D, Jones JD. 1980b. Chlorine dioxide metabolism in rat. J Environ Pathol Toxicol 3:421–430.
*Abdel-Rahman MS, Skowronski GA, Gerges SE, . 1987a. Teratologic studies on Alcide Allay^®^ gel in rabbits. J Appl Toxicol 7(3):161–165.3624774
*Abdel-Rahman MS, Skowronski GA, Turkall RM, . 1987b. Subchronic dermal toxicity studies of Alcide Allay^®^ gel and liquid in rabbits. J Appl Toxicol 7(5):327–333.3680849
Abdel-Rahman MS, Skowronski GA, Turkall RM. 1987c. Subchronic vaginal toxicity studies of Alcide Allay^®^ gel and liquid in guinea pigs. Drug Chem Toxicol 10(3–4):257–274.3428185
*ACGIH. 2001. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists. http://www.osha.gov/comp-links.html. May 9, 2002.
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37618–37634.
*Agency for Toxic Substances and Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Atlanta, GA: Subcommittee on Biomarkers of Organ Damage and Dysfunction.
*Aieta EM, Berg JD. 1986. A review of chlorine dioxide in drinking water treatment. J Am Water Works Assoc 78(6):62–72.
Aieta EM, Roberts PV. 1985. The chemistry of oxo-chlorine compounds relevant to chlorine dioxide generation. In: Jolley RL, Bull RJ, Davis WP, ., eds. Water chlorination - Chemistry, environmental impact and health effects. Vol. 5. Williamsburg, VA: Lewis Publishers, Inc., 783–784.
Aieta EM, Berg JD, Roberts PV, . 1980. Comparison of chlorine dioxide and chlorine in wastewater disinfection. J Water Pollut Control Fed 52(4):810–824.6247518
Akin EW, Hoff JC, Lippy EC. 1982. Waterborne outbreak control: which disinfectant? Environ Health Perspect 46:7–12.7151768
Alliger H, Roozdar H. 1997. Chlorine dioxide skin medicating compositions for preventing irritation. U.S. Patent No. 5,616,347. April 1, 1997.
*Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anderson AC, Reimers RS, DeKernion P. 1982. A brief review of the current status of alternatives to chlorine disinfection of water. Am J Public Health 72(11):1290–1293.7125035
Andrews RC, Ferguson MJ. 1996. Minimizing disinfection by-product formation while ensuring Giardia control. In: Minear RA, Amy GL, eds. Disinfection by-products in water treatment. Chelsea, MI: Lewis Publishers, Inc., 17–55.
*APHA. 1998. Standard methods for the examination of water and wastewater. 20^th^ ed. Baltimore, MD: United Book Press, Inc., 2-39 to 2-42, 4-73 to 4-78.
Astrakianakis G, Svirchev L, Tang C, . 1998. Industrial hygiene aspects of a sampling survey at a bleached-kraft pulp mill in British Columbia. Am Ind Hyg Assoc J 59(10):694–705.9794067
Band PR, Le ND, Fang R, . 1997. Cohort mortality study of pulp and paper mill workers in British Columbia, Canada. Am J Epidemiol 146(2):186–194.9230781
Baribwau H, Prevost M, Desjardins R, . 2002. Chlorite and chlorate ion variability in distribution systems. J Am Water Works Assoc 94(7):96–105.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Bathija AT. 2003. Health Risk to Fetuses, infants and children from stage 1 disinfectants and disinfectant by-products (D/DBPs). Toxicologist 72(S-1):28.
Beitler MK, Chin HB. 1995. Improved determination of chlorite and chlorate in rinse water from carrots and green beans by liquid chromatography and amperometric and conductivity detection. J AOAC Int 78(3):878–883.7756905
Benarde MA, Israel BM, Olivieri VP, . 1965. Efficiency of chlorine dioxide as a bactericide. Appl Microbiol 18(5):776–780.
*Bercz JP, Jones L, Garner L, . 1982. Subchronic toxicity of chlorine dioxide and related compounds in drinking water in the nonhuman primate. Environ Health Perspect 46:47–55.7151767
*Bercz JP, Jones L, Harrington RM, . 1986. Mechanistic aspects of ingested chlorine dioxide on thyroid function: impact of oxidants on iodide metabolism. Environ Health Perspect 69:249–255.3816729
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
*Björkholm E, Hultman A, Rudling J. 1988. Determination of chlorine and chlorine dioxide in workplace air by impinger collection and ion-chromatographic analysis. J Chromatogr 457:409–414.3243890
*Björkholm E, Hultman A, Rudling J. 1990. Evaluation of two diffusive samplers for monitoring chlorine and chlorine dioxide in workplace air. Appl Occup Environ Hyg 5(11):767–770.
*BNA. 2001. Environment and Safety Library on the Web. States and territories. Washington, DC: Bureau of National Affairs, Inc. http//www.esweb.bna.com (http://www.esweb.bna.com). June 7, 2001.
*Bolyard M, Fair PS, Hautman DP. 1993. Sources of chlorate ion in US drinking water. J Am Water Works Assoc 85(9):81–88.
Bright DA, McKague B, Hodson PV, . 1998. Use of chlorine dioxide for the bleaching of pulp: a re-evaluation of ecological risks based on scientific progress since 1993. International Environmental Conference & Exhibit Bk. Atlanta, GA: Tappi Press, 3:1051–1054.
*Brumley CM, Haritos VS, Ahokas JT, . 1996. Metabolites of chlorinated syringaldehydes in fish bile as biomarkers of exposure to bleached eucalypt pulp effluents. Ecotoxicol Environ Saf 33:253–260.8727518
*Carlton BD, Smith MK. 1985. Reproductive effects of alternate disinfectants and their by-products. Water chlorination: chemistry, environmental impact and health effects. In: Proceedings of the fifth conference on water chlorination- environmental impact and health effects, Williamsburg, Virginia, June 3-8, 1984. Chelsea, MI: Lewis Publishers, Inc., 295–305.
*Carlton BD, Basaran AH, Mezza LE, . 1991. Reproductive effects in Long-Evans rats exposed to chlorine dioxide. Environ Res 56:170–177.1769363
*Carlton BD, Habash DL, Basaran AH, . 1987. Sodium chlorite administration in Long-Evans rats: reproductive and endocrine effects. Environ Res 42:238–245.3803340
Chang CY, Hsieh YH, Hsu SS, . 2000a. The formation of disinfection by-products in water treated with chlorine dioxide. J Hazard Mater B 79:89–102.
Chang CY, Hsieh YH, Lin YM, . 2001. The organic precursors affecting the formation of disinfection by-products with chlorine dioxide. Chemosphere 44:1153–1158.11513403
Chang CY, Hsieh YH, Shih IC, . 2000b. The formation and control of disinfection by-products using chlorine dioxide. Chemosphere 41:1181–1186.10901244
*Chang SL. 1982. The safety of water disinfection. Annu Rev Public Health 3:393–418.6756434
*Charles L, Pépin D. 1998. Analysis of oxyhalides in water by ion chromatography-ionspray mass spectrometry. J Chromatogr A 804:105–111.
Chien TW, Chu H. 2000. Removal of SO2 and NO from flue gas by wet scrubbing using an aqueous NaClO2 solution. J Hazard Mater B 80:43–57.
Chow BM, Roberts PV. 1981. Halogenated byproduct formation by ClO_2_ and Cl_2_. J Environ Eng 107(EE4):609–618.
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
CMA. 1991. Initial submission: Letter submitting preliminary information from an acute inhalation study in rats on sodium chlorite with attachment. Chemical Manufacturers Association. CMA/88-920000094.
*CMA. 1996. Sodium chlorite: drinking water rat two-generation reproductive toxicity study. Chemical Manufacturers Association. Quintiles Report Ref. CMA/17/96.
*Colborn T, Clement C, eds. 1992. Chemically-induced alterations in sexual and functional development: The wildlife-human connection. In: Advances in modern environmental toxicology, Vol. XXI, Princeton, NJ: Princeton Scientific Publishing.
Colclough CA, Johnson JD, Christman RF, . 1985. Organic reaction products of chlorine dioxide and natural aquatic fulvic acids. In: Jolley RL, Bull RJ, Davis WP, ., eds. Water chlorination-Environmental impact and health effects. Vol. 4. Pacific Grove, CA: Ann Arbor Science, IV–IX.
Condie LW. 1986. Toxicological problems associated with chlorine dioxide. J Am Water Works Assoc 78(6):73–78.
Condie LW. 1990. Toxicological effects associated with drinking water disinfectants and their by-products. In: Jolley RL, Johnson JD, ., eds. Water chlorination. Chemistry, environmental impact and health effects. Oak Ridge, Tennessee: Lewis Publishers, 281–292.
Connor PM, Moore GS, Calabrese EJ, . 1985. The renal effects of sodium chlorite in the drinking water of C57L/J male mice. J Environ Pathol Toxicol Oncol 6(2):253–260.4078693
*Couri D, Abdel-Rahman MS. 1980. Effect of chlorine dioxide and metabolites on glutathione dependent system in rat, mouse and chicken blood. J Environ Pathol Toxicol 3:451–460.6771359
Couri D, Abdel-Rahman MS, Bull RJ. 1982a. Toxicological effects of chlorine dioxide, chlorite and chlorate. Environ Health Perspect 46:13–17.6759107
*Couri D, Miller CH, Bull RJ, . 1982b. Assessment of maternal toxicity, embryotoxicity and teratogenic potential of sodium chlorite in Sprague-Dawley rats. Environ Health Perspect 46:25–29.7151764
Cowley G. 2000. Disinfection with chlorine dioxide. J New Engl Water Works Assoc 114(4):264–270.
*Dabrowska A, Swietlik J, Nawrocki J. 2003. Formation of aldehydes upon ClO2 disinfection. Water Res 37(5):1161–1169.12553992
*Dalhamn T. 1957. Chlorine dioxide. AMA Arch Ind Health 15(2):101–107.13393816
*Daniel FB, Condie LW, Robinson M, . 1990. Comparative subchronic toxicity studies of three disinfectants. J Am Water Works Assoc, 61–69.
Delves HT, Sieniawska CE, Fell GS, . 1997. Determination of antimony in urine, blood and serum and in liver and lung tissues of infants by inductively coupled plasma mass spectrometry. Analyst 122:1323–1329.9474813
Denis M, Minon G, Masschelein WJ. 1989. Continuous determination of residual chlorite in water. Anal Chim Acta 226(1):121–128.
Dennison S, Bonnick DM. 1995. Stopped-flow thin-layer coulometric method for the determination of disinfectants in water. Anal Proc 32(1):13–15.
*Dernat M, Pouillot M. 1992. Theoretical and practical approach to the disinfection of municipal waste water using chlorine dioxide. Water Sci Technol 25(12):145–154.
Dietrich AM, Ledder TD, Gallagher DL, . 1992. Determination of chlorite and chlorate in chlorinated and chloraminated drinking water by flow injection analysis and ion chromatography. Anal Chem 64:498–502.
Dillner B, Larsson LO, Tibbling P. 1990. Nonchlorine bleaching of pulp produced by the modified continuous cooking process. TAPPI J 73(8):167–172.
*Dluzniewski TJ. 2002. Investigation into carpet odours with ClO2. Chlorine dioxide: The state of science, regulatory, environmental issues, and case histories. Las Vegas, NV: American Water Works Association, 105–130.
*Dobson A, Richard C. 2002. Concise international chemical assessment document 37. Chlorine dioxide (gas). Geneva, Switzerland: World Health Organization, 1–32.
Dreux M, Lafosse M, Gilbert M, . 1985. Analytical determination of inorganic chlorination products in water treatment by an HPLC method. In: Jolley RL, Bull RJ, Davis WP, ., eds. Water chlorination- Chemistry, environmental impact and health effects. Vol. 5. Williamsburg, VA: Lewis Publishers, Inc., 1065–1072.
*Elkins HB. 1959. The chemistry of industrial toxicology. 2^nd^ ed. New York: John Wiley and Sons, 89–90.
*EMMI. 1997. Environmental Monitoring Methods Index. Version 1.1. PC# 4082. U.S. Environmental Protection Agency. Rockville, MD: Government Institutes.
*EPA. 1981. Study of chlorine dioxide and its metabolites in man. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600181068.
*EPA. 1988. Recommendations for and documentation of biological values for use in risk assessment Cincinnati, OH: U.S. Environmental Protection Agency. PB88179874.
*EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
*EPA. 1994. Final draft for the drinking water criteria document on chlorine dioxide, chlorite and chlorate. Washington, DC: U.S. Environmental Protection Agency, Office of Science and Technology, Office of Water. EPA68C20139.
*EPA. 1995. Toxic chemical release inventory. Reporting form R and instructions. Washington DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. EPA745K95051.
*EPA. 1997a. Automated Form R for Windows: User’s guide (RY97). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics.
*EPA. 1997b. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1998. Health risk assessment/characterization of the drinking water disinfection by-products chlorine dioxide and chlorite. Washington, DC: U.S. Environmental Protection Agency, Office of Science and Technology, Office of Water. PB99111361.
*EPA. 2002a. Chemical accident prevention provisions. List of substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 68.130. Table 1. http://ecfr.access.gpo.gov/. April 24, 2002.
*EPA. 2002b. Chemical accident prevention provisions. Table of toxic endpoints. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 68. Appendix A. http://ecfrback.access.gpo.gov. April 24, 2002.
*EPA. 2002c. Chlorine dioxide. U.S. Environmental Protection Agency. Office of Pesticide Programs. http://www.epa.gov/pesticides/factsheets/chlorinedioxidefactsheet.htm. April 24, 2002.
*EPA. 2002d. Information collection rule- ICR query form. U.S. Environmental Protection Agency. http://www.epa.gov/enviro/html/icr/icr-query.html. April 24, 2002.
*EPA. 2002e. National primary drinking water regulations. Maximum contaminant levels for disinfection byproducts. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.64(a). http://ecfrback.access.gpo.gov. April 24, 2002.
*EPA. 2002f. National primary drinking water regulations. Maximum contaminant level goals for disinfection byproducts. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.53. http://ecfrback.access.gpo.gov. April 24, 2002.
*EPA. 2002g. National primary drinking water regulations. Maximum residual disinfectant levels. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.65(a). http://ecfrback.access.gpo.gov. April 24, 2002.
*EPA. 2002h. National primary drinking water regulations. Maximum residual disinfectant level goals for disinfectants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.54. http://ecfrback.access.gpo.gov. April 24, 2002.
*EPA. 2002i. Standards for owners and operators of hazardous waste treatment, storage, and disposal facilities. Examples of potentially incompatible waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix V. http://ecfr.access.gpo.gov. April 24, 2002.
*EPA. 2002j. Tolerances and exemptions from tolerances for pesticide chemicals in food. Sodium chlorite; exemption from the requirement of a tolerance. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.1070. http://ecfrback.access.gpo.gov. April 24, 2002.
*EPA. 2002k. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. 40 CFR 372.65(a). http://ecfr.access.gpo.gov. April 24, 2002.
*Exner-Freisfeld H, Kronenberger H, Meier-Sydow J, . 1986. Intoxication from bleaching with sodium chlorite. The toxicology and clinical course. DTW Dtsch Tierarztl Wochenschr 111:1927–1930. (German with English abstract)
*FDA. 2001a. Indirect food additives: Adhesives and components of coatings. Adhesives. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105. http://www.accessdata.fda.gov. April 24, 2002.
*FDA. 2001b. Indirect food additives: Adjuvants, production aids, and sanitizers. Sanitizing solutions. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 178.1010. http://frwebgate.access.gpo.gov. April 24, 2002.
*FDA. 2001c. Indirect food substances affirmed as generally recognized as safe. Sodium chlorite. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 186.1750. http://frwebgate.access.gpo.gov. April 24, 2002.
*FDA. 2001d. Secondary direct food additives permitted in food for human consumption. Acidified sodium chlorite solutions. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 173.325. http://frwebgate.access.gpo.gov. April 24, 2002.
*FDA. 2001e. Secondary direct food additives permitted in food for human consumption. Chlorine dioxide. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 173.300. http://frwebgate.access.gpo.gov. April 24, 2002.
*FEDRIP. 2003. Federal Research in Progress: Chlorine dioxide. Dialog Information Service, Inc.
*Ferris BG, Burgess WA, Worcester J. 1967. Prevalence of chronic respiratory disease in a pulp mill and a paper mill in the United States. Br J Ind Med 24:26–37.6017136
*Ferris BG, Puleo S, Chen HY. 1979. Mortality and morbidity in a pulp and a paper mill in the United States: a ten-year follow-up. Br J Ind Med 36:127–134.465376
Fleischaker SJ, Randtke SJ. 1983. Formation of organic chlorine in public water supplies. J Am Water Works Assoc 75(3):132–138.
*Fletcher IJ, Hemmings P. 1985. Determination of chlorine dioxide in potable waters using chlorophenol red. Analyst 110(6):695–699.4037356
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant.” In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Fujie K, Aoki T. 1988. Acute cytogenic effect of alternative disinfectants on rat bone marrow cells in vivo. Chem Express 3(11):655–658.
Gates D. 1999a. A balanced view of chlorine dioxide. J Am Water Works Assoc 90(4):8,10.
Gates D. 1999b. Practical suggestions for meeting USEPA compliance monitoring requirements and in-plant operational control of chlorine dioxide in drinking water. Ozone Sci Eng 21:433–445.
Gates D, Harrington R. 1993. Drinking water disinfection practices: Chlorine dioxide in the nineties. In: Disinfection dilemma: Microbiological control versus by-products. Proceedings of the National Conference on Drinking Water, 339–363.
Gates DJ, Harrington RM. 1996. Neuro-reproductive toxicity issues concerning chlorine dioxide and the chlorite ion in public drinking water supplies. In: Proceedings 1995 water quality technology conference, Part I, University of California Berkeley, November 12-16, 1995. Denver, CO: American Water Works Association, 813–830.
*Gerges SE, Abdel-Rahman MS, Skowronski GA, . 1985. Effects of Alcide^®^ Gel on fetal development in rats and mice. II. J Appl Toxicol 5(2):104–109.3998374
*Gill MW, Swanson MS, Murphy SR, . 2000. Two-generation reproduction and developmental neurotoxicity study with sodium chlorite in the rat. J Appl Toxicol 20:291–303.10942904
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
*Gloemme J, Lundgren KD. 1957. Health hazards from chlorine dioxide. AMA Arch Ind Health 16:169–176.13443533
Gordon G. 2000. Chemistry detail of ClO_2_ generation: Impurities and by-products. In: Water quality technology conference proceedings. Oxford, OH: American Water Works Association, 754–762.
*Gordon G. 2001. Is all chlorine dioxide created equal? J Am Water Works Assoc 93(4):163–174.
Gordon G, Tachiyashik S. 1991. Kinetics and mechanisms of formation of chlorate ion from the hypochlorous acid/chlorite ion reaction at pH 6-10. Environ Sci Technol 25:468–474.
Gordon G, Adam L, Bubnis B. 1995. Minimizing chlorate ion formation. J Am Water Works Assoc 87(6):97–106.
*Griese MH, Kaczur JJ, Gordon G. 1992. Combining methods for the reduction of oxychlorine residuals in drinking water. J Am Water Works Assoc 84(11):69–77.
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press, VI–XI.
*Haag HB. 1949. The effect on rats of chronic administration of sodium chlorite and chlorine dioxide in the drinking water. Report to the Mathieson Alkali Works from H.B. Haag of the Medical College of Virginia. http://www.epa.gov/iris/subst/0496.htm.
*Haller JF, Northgraves WW. 1955. Chlorine dioxide and safety. TAPPI 38:199–202.
*Harrington RM, Romano RR, Gates D, . 1995a. Subchronic toxicity of sodium chlorite in the rat. J Am Coll Toxicol 14(1):21–33.
*Harrington RM, Romano RR, Irvine L. 1995b. Developmental toxicity of sodium chlorite in the rabbit. J Am Coll Toxicol 14(2):108–118.
*Harrington RM, Shertzer HG, Bercz JP. 1985. Effects of ClO_2_ on the absorption and distribution of dietary iodide in the rat. Fundam Appl Toxicol 5:672–678.4043591
*Hautman DP, Bolyard M. 1992a. Analysis of oxyhalide disinfection by-products and other anions of interest in drinking water by ion chromatography. J Chromatogr 602(1–2):65–74.1400855
Hautman DP, Bolyard M. 1992b. Using ion chromatography to analyze inorganic disinfection by-products. J Am Water Works Assoc 84(11):88–93.
*Hayashi M, Kishi M, Sofuni T, . 1988. Micronucleus tests in mice on 39 food additives and eight miscellaneous chemicals. Food Chem Toxicol 26(6):487–500.3169648
*HazDat. 2004. Agency for Toxic Substances and Disease Registry. http://toxnet.nlm.nih.gov. June 20, 2004.
*Heffernan WP, Guion C, Bull RJ. 1979a. Oxidative damage to the erythrocyte induced by sodium chlorite, in vitro. J Environ Pathol Toxicol 2(6):1501–1510.
*Heffernan WP, Guion C, Bull RJ. 1979b. Oxidative damage to the erythrocyte induced by sodium chlorite, in vivo. J Environ Pathol Toxicol 2:1478–1499.
*Hekmat M, Smith R, Fung P. 1994. An evaluation of the occupational health and safety administration method for the “determination of chlorine dioxide in workplace atmosphere.” Am Ind Hyg Assoc J 55(11):1087–1089.
Heller-Grossman L, Idin A, Limoni-Relis B, . 1999. Formation of cyanogen bromide and other volatile DBPs in the disinfection of bromide-rich lake water. Environ Sci Technol 33(6):932–937.
*Hoehn RC, Dietrich AM, Farmer WS, . 1990. Household odors associated with the use of chlorine dioxide. J Am Water Works Assoc 82(4):166–172.
Hoehn RC, Ellenberger CS, Gallagher DL, . 2003. ClO2 and by-product persistence in a drinking water system. J Am Water Works Assoc 95(4):141–150.
*Hoehn RC, Long BW, Gates DJ. 2000. Status of chlorine dioxide disinfection technologies. Blacksburg, VA. American Water Works Association, 1888–1906.
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
*Hofmann R, Andrews RC, Ye Q. 1998. Comparison of spectrophotometric methods for measuring chlorine dioxide in drinking water. Environ Technol 19:761–773.
*Hoigne J, Bader H. 1994. Kinetics of reactions of chlorine dioxide (OClO) in water--I. Rate constants for inorganic and organic compounds. Water Res 28(1):45–55.
*Hollowell DA, Gord JR, Gordon G, . 1986. Selective chlorine dioxide determination using gas-diffusion flow injection analysis with chemiluminescent detection. Anal Chem 58:1524–1527.
Hollowell DA, Pacey GE, Gordon G. 1985. Selective determination of chlorine dioxide using gas diffusion flow injection analysis. Anal Chem 57:2851–2854.
*HSDB. 2002. Chlorine Dioxide. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. June 3, 2004.
*Hui C, Gaizhen W, Li Y. 1997. Extraction spectrophotometric determination of trace chlorine dioxide with methylene blue. Anal Lett 30(7):1415–1421.
*IARC. 2002. Sodium chlorite. IARC monographs programme on the evaluation of carcinogenic risks to humans. International Agency for Research on Cancer. http://193.51.164.11/htdocs/Monographs/Vol52/02-Sodium%20chlorite.HTM. April 11, 2002.
*Ingram PR, Homer NZ, Smith RA, . 2003. The interaction of effects in vitro, in mammalian and in microbial cells. Arch Biochem 410(1):121–133.12559984
*IRIS. 2002. Integrated Risk Information System. http://www.epa.gov/iris. April 11, 2002.
*Ishidate M, Sofuni T, Yoshikawa K, . 1984. Primary mutagenicity screening of food additives currently used in Japan. Food Chem Toxicol 22(8):623–636.6381265
*ITA. 2002. U.S. Imports, December 2001, HS 282890. International Trade Administration, U.S. Department of Commerce. http://ita.doc.gov. May 16, 2002.
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Junli H, Li W, Nanqi R, . 1997a. Disinfection effect of chlorine dioxide on bacteria in water. Water Res 31:607–613.
Junli H, Li W, Nanqi R, . 1997b. Disinfection effect of chlorine dioxide on viruses, algae and animal planktons in water. Water Res 31(3):455–460.
*Kaczur JJ, Cawlfield DW. 1993. Chlorine oxygen acids and salts (ClO_2_, HClO_2_). In: Kroschwitz JI, ed. Kirk-Othmer encyclopedia of chemical technology. Vol. 5. New York, NY: John Wiley & Sons, Inc., 969–991.
*Källén BAJ, Robert E. 2000. Drinking water chlorination and delivery outcome—a registry-based study in Sweden. Reprod Toxicol 14:303–309.10908833
*Kanitz S, Franco Y, Patrone V, . 1996. Association between drinking water disinfection and somatic parameters at birth. Environ Health Perspect 104(5):516–520.8743439
Karpel Vel Leitner N, De Laat J, Dore M. 1992. Photodecomposition of chlorine dioxide and chlorite by UV-irradiation- part II. Kinetic study. Water Res 26(12):1665–1672.
Karpel Vel Leitner N, De Laat J, Suty EH. 1991. [Kinetics of the reaction between chlorine and chlorite in dilute aqueous solution]. Environ Technol 12:477–487. (French)
*Kauppinen T, Teschke K, Savela A, . 1997. International data base of exposure measurements in the pulp, paper and paper product industries. Int Arch Occup Environ Health 70(2):119–127.9253640
Kengen SWM, Rikken GB, Hagen WR, . 1999. Purification and characterization of (per)chlorate reductase from the chlorate-respiring strain GR-1. J Bacteriol 181(21):6706–6711.10542172
*Kennedy SM, Enarson DA, Janssen RG, . 1991. Lung health consequences of reported accidental chlorine gas exposure among pulp mill workers. Am Rev Respir Dis 143(1):74–79.1986687
Kim J, Marshall MR, Du WX, . 1999. Determination of chlorate and chlorite and mutagenicity of seafood treated with aqueous chlorine dioxide. J Agric Food Chem 47:3586–3591.10552689
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kross RD. 1997. Method and composition for prevention and treatment of female lower genital tract microbial infections. U.S. Patent No. 5,667.817. September 16, 1997.
Kun Z, Hui C, Guanghe L, . 1998. In situ remediation of petroleum compounds in groundwater aquifer with chlorine dioxide. Water Res 32(5):1471–1480.
*Kurokawa Y, Takamura N, Matsushima Y, . 1984. Studies on the promoting and complete carcinogenic activities of some oxidizing chemicals in skin carcinogenesis. Cancer Lett 24:299–304.6437666
*Kurokawa Y, Takayama S, Konishi Y, . 1986. Long-term in vivo carcinogenicity tests of potassium bromate, sodium hypochlorite, and sodium chlorite conducted in Japan. Environ Health Perspect 69:221–235.3816726
*Lee Y, Kim H, Lee U. 2004. Formation of chlorite and chlorate from chlorine dioxide with Han River Water. Korean J Chem Eng 21(3):647–653.
*Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leitner NKV, De Laat J, Dore M, . 1994. Inorganic and organic byproducts of the reactions between chlorite, activated carbon, and phenolic compounds. Environ Sci Technol 28(2):222–230.22176166
Leitner NKV, Laat JD, Dore M, . 1992. [Comparison of activated carbons for the removal of chlorite.] Environ Technol 13:621–633. (French)
*Leung H-W. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Limoni B, Choshen E, Rav-Acha C. 1984. Determination of oxidants formed upon the disinfection of drinking water with chlorine dioxide. J Environ Sci Health Part A 19(8):943–957.
*Lin JL, Lim PS. 1993. Acute sodium chlorite poisoning associated with renal failure. Ren Fail 15(4):645–648.8290712
*Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
*Logan BE. 1998. A review of chlorate- and perchlorate-respiring microorganisms. Biorem J 2(2):69–79.
Lubbers JR, Bianchine JR. 1984. Effects of the acute rising dose administration of chlorine dioxide, chlorate and chlorite to normal healthy adult male volunteers. J Environ Pathol Toxicol 5(4–5):215–228.
*Lubbers JR, Chauhan S, Bianchine JR. 1981. Controlled clinical evaluations of chlorine dioxide, chlorite and chlorate in man. Fundam Appl Toxicol 1:334–338.7185581
*Lubbers JR, Chauhan S, Miller JK, . 1984a. The effects of chronic administration of chlorine dioxide, chlorite and chlorate to normal healthy adult male volunteers. J Environ Pathol Toxicol Oncol 5-4(5):229–238.
*Lubbers JR, Chauhan S, Miller JK, . 1984b. The effects of chronic administration of chlorite to glucose-6-phosphate dehydrogenase deficient healthy adult male volunteers. J Environ Pathol Toxicol Oncol 5-4(5):239–242.
Luo J, Christensen PK. 1992. Sodium chlorite as an alternative for chlorine dioxide in pulp bleaching. Appita 45(1):38–40.
*Lykins BW, Goodrich JA, Hoff JC. 1990. Concerns with using chlorine-dioxide disinfection in the USA. Aqua 39(6):376–386.
Malmqvist A, Welander T. 1992. Anaerobic removal of chlorate from bleach effluents. Water Sci Technol 25:237–242.
Marabini L, Fumagalli R, Radice S, . 2002. Toxicity evaluation or various drinking water disinfectants in HEPG2 cells. Toxicol Lett 135:S55.
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
*Meggs WJ, Elsheik T, Metzger WJ, . 1996. Nasal pathology and ultrastructure in patients with chronic airway inflammation (RADS and RUDS) following an irritant exposure. Clin Toxicol 34(4):383–396.
*Meier JR, Bull RJ, Stober JA, . 1985. Evaluation of chemicals used for drinking water disinfection for production of chromosomal damage and sperm-head abnormalities in mice. Environ Mutagen 7:201–211.3971958
*Michael GE, Miday RK, Bercz JP, . 1981. Chlorine dioxide water disinfection: A prospective epidemiology study. Arch Environ Health 36:20–27.7469487
*Miller RG, Kopfler FC, Condie LW, . 1986. Results of toxicological testing of Jefferson Parish Pilot plant samples. Environ Health Perspect 69:129–139.
*Mobley SA, Taylor DH, Laurie RD, . 1990. Chlorine dioxide depresses T3 uptake and delays development of locomotor activity in young rats. In: Jolley RL, Bull RJ, Davis WP, ., eds. Water chlorination: chemistry, environmental impact and health effects. Vol. 6. Chelsea, MI: Lewis Publications, 347–358.
Monarca S, Feretti D, Collivignarelli C, . 2000. The influence of different disinfectants on mutagenicity and toxicity of urban wastewater. Water Res 34(17):4261–4269.
*Moore GS, Calabrese EJ. 1980a. G6PD: a potential high-risk group to copper and chlorite ingestion. J Environ Pathol Toxicol 4:271–279.7462905
*Moore GS, Calabrese EJ. 1980b. The effects of chlorine dioxide and sodium chlorite on erythrocytes of A/J and C57L/J mice. J Environ Pathol Toxicol 4(2–3):513–524.7462915
*Moore GS, Calabrese EJ. 1982. Toxicological effects of chlorite in the mouse. Environ Health Perspect 46:31–37.7151765
Moore GS, Calabrese EJ, DiNardi SR, . 1978. Potential health effects of chlorine dioxide as a disinfectant in potable water supplies. Med Hypotheses 4(5):481–496.753950
Moore GS, Calabrese EJ, Forti A. 1984. The lack of nephrotoxicity in the rat by sodium chlorite, a possible byproduct of chlorine dioxide disinfection in drinking water. J Environ Sci Health Part A 19(6):643–661.
Moore GS, Calabrese EJ, Ho SC. 1980a. Groups at potentially high risk from chlorine dioxide treated water. J Environ Pathol Toxicol 4(2–3):465–470.7462914
*Moore GS, Calabrese EJ, Leonard DA. 1980b. Effects of chlorite exposure on conception rate and litters of A/J strain mice. Bull Environ Contam Toxicol 25:689–696.7470643
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
*Musil J, Knotek Z, Chalupa J, . 1964. Toxicologic aspects of chlorine dioxide application for the treatment of water containing phenols. Sb Vys Sk Chem Technol Praze Oddil Fak Technol Paliv Vody 8:327–345.
*NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
NASA-JPL. 1999. Public health assessment for jet propulsion laboratory (NASA), Pasadena, Los Angeles County, California. Region 9, CERCLIS no. CA9800013030. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Division of Health Assessment and Consultation. PB99167470.
Nicoson JS, Margerum DW. 2002. Kinetics and mechanisms of aqueous chlorine reactions with chlorite ion in the presence of chloride ion and acetic acid/acetate buffer. Inorg Chem 41(2):342–347.11800623
*NIOSH. 2002. Chlorine dioxide. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npgd0116.html. April 11, 2002.
Nowack B, Buchs U, Kaiser H-P, . 1999. New methods for the determination of chlorine dioxide species in drinking water. Dübendorf, Switzerland: Swiss Federal Institute for Environmental Science and Technology, 1145–1161.
*NRC. 1980. National Research Council. Drinking water and health. Vol. 3. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 199.
*NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
*Ohura H, Imato T, Yamasaki S. 1999. Simultaneous potentiometric determination of ClO3--ClO2- and ClO3--HClO by flow injection analysis using Fe(III)-Fe(II) potential buffer. Talanta 49:1003–1015.18967677
*O’Neil MJ, Smith A, Heckelman PE, , eds. 2001. The Merck index. 13^th^ ed. Whitehouse Station, NJ: Merck & Co., Inc., 2213, 8869.
*Orme J, Taylor DH, Laurie RD, . 1985. Effects of chlorine dioxide on thyroid function in neonatal rats. J Toxicol Environ Health 15:315–322.4009737
*OSHA. 2002a. Gases, vapors, fumes, dusts, and mists. Safety and health regulations for construction. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. http://www.osha.gov. May 19, 2002.
*OSHA. 2002b. Limits for air contaminants. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.osha.gov. May 19, 2002.
*OSHA. 2002c. List of highly hazardous chemicals, toxics and reactives. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.119. http://www.osha.gov. May 19, 2002.
*OSHA. 2002d. List of highly hazardous chemicals, toxics and reactives. Safety and health regulations for construction. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.64. http://www.osha.gov. May 19, 2002.
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Owens JW, Swanson SM, Birkholz DA. 1994. Environmental monitoring of bleached kraft pulp mill chlorophenolic compounds in a Northern Canadian river system. Chemosphere 29(1):89–109.8044637
Pantsar-Kallio M, Manninen PKG. 1998. Speciation of halogenides and oxyhalogens by ion chromatography-inductively coupled plasma mass spectrometry. Anal Chim Acta 360:161–166.
*Paulet G, Desbrousses S. 1970. On the action of ClO_2_ at low concentrations on laboratory animals. Arch Mal Prof 31:97–106.5518885
*Paulet G, Desbrousses S. 1972. On the toxicology of chlorine dioxide. Arch Mal Prof 33:59–61.5044534
*Paulet G, Desbrousses S. 1974. Action of a discontinuous exposure to chlorine dioxide (ClO_2_) on the rat. Arch Mal Prof 35:797–804.
*Pfaff JD, Brockhoff CA. 1990. Determining inorganic disinfection by-products by ion chromatography. J Am Water Works Assoc 82(4):192–195.
Pfohl B, Taylor D. 1983. Effect of chlorine dioxide on glucose uptake by developing rat brains. Am Zool 23(4):990.
Piccardi G, Barbolani E, Pantani F. 1980. Comparison between colorimetric and electrometric methods for chlorine and its derivative compounds. Water Air Soil Pollut 13:197–205.
Poovey HG, Rando RJ. 1995. Determination of chlorine and chlorine dioxide by non-suppressed ion chromatography and application to exposure assessment in the paper industry. J Liquid Chromatogr 18(2):261–275.
*Quentel F, Elleouet C, Madec C. 1994. Electrochemical determination of low levels of residual chlorine dioxide in tap water. Anal Chim Acta 295:85–91.
Rapson WH, Nazar MA, Butsky VV. 1980. Mutagenicity produced by aqueous chlorination of organic compounds. Bull Environ Contam Toxicol 24:590–596.6991030
Ratcliff PA. 2000. Composition for treating abnormal conditions of the epithelium of bodily orifices. U.S. Patent No. 6, 017, 554. January 25, 2000.
Ratcliff PA. 2001. Method for treating itching of the vagina. U.S. Patent No. 6,280,716 B1. August 28, 2001.
Rav-Acha C. 1984. The reactions of chlorine dioxide with aquatic organic materials and their health effects. Water Res 18(11):1329–1342.
*Rav-Acha C. 1998. Transformation of aqueous pollutants by chlorine dioxide: Reaction, mechanisms and products. In: Handbook of environmental chemistry. Vol. 5. 143–175.
*Rav-Acha C, Choshen E. 1987. Aqueous reactions of chlorine dioxide with hydrocarbons. Environ Sci Technol 21:1069–1074.
Rav-Acha C, Blits R, Choshen E, . 1983. The action of chlorine dioxide on aquatic organic materials during the disinfection of drinking water. J Environ Sci Health A 18(5):651–671.
Richardson SD. 2002. The role of GC-MS in the discovery of drinking water disinfection by-products. Environ Monit Assess 4(1):1–9.
*Richardson SD, Thruston AD, Collette TW, . 1994. Multispectral identification of chlorine dioxide disinfection byproducts in drinking water. Environ Sci Technol 28(4):592–599.22196540
Rubin ES. 1999. Toxic releases from power plants. Environ Sci Technol 33:3062–3067.
Sakemi K, Usami M, Kurebayashi H, . 1999. [Teratogenicity study of sodium chlorite in rats by oral administration.] Kokuritsu Iyakuhin Shokuhin Eisei Kenkyusho Hokoku 117:99–103. (Japanese)
*Saksa DJ, Smart RB. 1985. Chemiluminescent analysis of chlorine dioxide with a membrane flow cell. Environ Sci Technol 19:450–454.22296063
*Scatina J, Abdel-Rahman MS, Gerges SE, . 1983. Pharmacokinetics of Alcide^®^, a germicidal compound in rat. J Appl Toxicol 3(3):150–153.6619502
*Scatina J, Abdel-Rahman MS, Gerges SE, . 1984. Pharmacodynamics of Alcide, a new antimicrobial compound, in rat and rabbit. Fundam Appl Toxicol 4:479–484.6745537
*Seta S, Miyake B, Sato H, . 1991. [Acute oral toxicity and acute irritation test to skin and eye of sodium chlorite.] Kagaku Keisatsu Kenkyusho Hokoku Hokagaku Hen 44(1):7–22. (Japanese)
*Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Shaw JW. 1986. Indoor air quality of swimming pool enclosures. Managing Indoor Air for Health and Energy Conservation: Montreal, CA: Proceedings of the ASHRAE Conference. IAQ ’86, 83–87.
*Shi L, Xie C. 1999. [Experimental observation on acute toxicity and irritative effect of stable chlorine dioxide.] Zhongguo Xiaoduxue Zazhi 16(1):39–40. (Chinese)
Shimoyama T, Hiasa Y, Kitahori Y, . 1985. [Absence of carcinogenic effect of sodium chlorite in rats.] Nara Igaku Zasshi 36(6):710–718. (Japanese)
Siddiqui MS. 1996. Chlorine-ozone interactions: formation of chlorate. Water Res 30(9):2160–2170.
*Skowronski GA, Abdel-Rahman MS, Gerges SE, . 1985. Teratologic evaluation of Alcide^®^ Liquid in rats and mice. I. J Appl Toxicol 5(2):97–103.3998379
Smart RB. 1981. Measurement of chlorine dioxide with a membrane chemiluminescence cell. Anal Lett 14(A3):189–195.
Smart RB, Freese JW. 1982. Measuring chlorine dioxide with a rotating voltammetric membrane electrode. J Am Water Works Assoc 74(10):530–531.
Smith RP, Willhite CC. 1990. Chlorine dioxide and hemodialysis. Regul Toxicol Pharmacol 11(1):42–62.2184465
Sofos JN, Smith GC. 1998. Nonacid meat decontamination technologies: Model studies and commercial applications. Int J Food Microbiol 44:171–188.9851598
Solomon S, Sanders RW, Garcia RR, . 1993. Increased chlorine dioxide over Antarctica caused by volcanic aerosols from Mount Pinatubo. Nature 363:245–248.
*Sperling F. 1959. Oral LD_50_-fasted male Winstar rats, sodium chlorite. Sperling Laboratories’ report to Olin Mathieson Chemical Corp. Dated Oct. 8, 1959.
*SRI. 2001. 2001 Directory of chemical producers. United States. Menlo Park, CA: SRI International, 874–875.
*Stevens AA. 1982. Reaction products of chlorine dioxide. Environ Health Perspect 46:101–110.7151750
Stevens AA, Moore L, Dressman RC, . 1985. Disinfectant chemistry in drinking water-overview of impacts on drinking water quality. In: Rice RG, ed. Safe drinking water: The impact of chemicals on a limited resource. Chelsea, MI: Lewis Publishers, Inc.
Strähle J, Schwenk M, Gabrio T, . 1998. [Determination of inorganic disinfection byproducts oxohalides in the water of indoor and outdoor swimming pools.] Zentralbl Hyg Umweltmed 201(1):96–97. (German)
*Suh DH, Abdel-Rahman MS. 1985. Mechanism of chloroform formation by chlorine and its inhibition by chlorine dioxide. Fundam Appl Toxicol 5:305–313.3988001
*Suh DH, Abdel-Rahman MS, Bull RJ. 1983. Effect of chlorine dioxide and its metabolites in drinking water on fetal development in rats. J Appl Toxicol 3(2):75–79.6886299
Suh DH, Abdel-Rahman MS, Bull RJ. 1984. Biochemical interactions of chlorine dioxide and its metabolites in rats. Arch Environ Contam Toxicol 13(2):163–169.6721581
*Suzuki J, Okumoto C, Katsuki Y, . 1997. Determination of residual chlorite in vegetables and eggs treated with sodium chlorite by UV-ion chromatography and effect of soaking in water. J Food Hyg Soc Jpn 38(1):22–26.
*Sweetin DL, Sullivan E, Gordon G. 1996. The use of chlorophenol red for the selective determination of chlorine dioxide in drinking water. Talanta 43:103–108.18966469
Tanner RS. 1989. Comparative testing and evaluation of hard-surface disinfectants. J Ind Microbiol 4:145–154.
*Taylor DH, Pfohl RJ. 1985. Effects of chlorine dioxide on the neurobehavioral development of rats. In: Jolley RL, Bull RJ, Davis WP, ., eds. Water chlorination: chemistry, environmental impact and health effects. Vol. 6. Chelsea, MI: Lewis Publications, 355–364.
*Teschke K, Ahrens W, Andersen A, . 1999. Occupational exposure to chemical and biological agents in the nonproduction departments of pulp, paper, and paper product mills: an international study. Am Ind Hyg Assoc J 60:73–83.10028618
*Thorell HD, Stenklo K, Karlsson J, . 2003. A gene cluster for chlorate metabolism in Ideonella dechloratans. Appl Environ Microbiol 69(9):5585–5592.12957948
*Toth GP, Long RE, Mills TS, . 1990. Effects of chlorine dioxide on the developing rat brain. J Toxicol Environ Health 31:29–44.2213920
Tratnyek PG, Hoigne J. 1994. Kinetics of reactions of chlorine dioxide (OClO) in water--II. Quantitative structure-activity relationships for phenolic compounds. Water Res 28(1):57–66.
*TRI01. 2003. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access, Offices of Environmental Information, U.S. Environmental Protection Agency. Toxic Release Inventory. http://www.epa.gov/triexplorer/. March 12, 2003.
Tsai LS, Higby R, Schade J. 1995. Disinfection of poultry chiller water with chlorine dioxide: consumption and byproduct formation. J Agric Food Chem 43:2768–2773.
*Tuthill RW, Giusti RA, Moore GS, . 1982. Health effects among newborns after prenatal exposure to ClO2-disinfected drinking water. Environ Health Perspect 46:39–45.7151766
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
*Vogt H, Balej J, Bennett JE, . 1986. Chlorine oxides and chlorine oxygen acids. In: Gerhartz W, Yamamoto YS, Campbell FT, ., eds. Ullman’s encyclopedia of industrial chemistry. Vol. A6. New York, NY: Wiley-VCH, 483–500.
*Wang L, Huang J-L, Li B-X. 2002a. [Mutagenic effect of chlorine dioxide, chlorite and chlorate aqueous solutions.] Huanjing Huaxue 21(4):412–414. (Chinese)
*Wang L, Huang J-L, Li B-X. 2002b. [Micronucleus test of chlorine dioxide and by-products chlorite and chlorate in water.] Harbin Jianzhu Daxue Xuebao 35(1):58–60. (Chinese)
*Weinberg HS, Yamada H. 1998. Post-ion-chromatography derivatization for the determination of oxyhalides at sub-ppb levels in drinking water. Anal Chem 70:1–6.9435465
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Wheeler GL, Lott PF. 1978. A rapid microdetermination of chlorine dioxide in the presence of active chlorine compounds. Microchem J 23:160–164.
*WHO. 2000. Disinfectants and disinfectant by-products. World Health Organization. http://www.inchem.org. April 24, 2000.
*WHO. 2002. Health for All Statistical Database. European Public Health Information Network for Eastern Europe. World Health Organization. http://www.euphin.dk/hfa/Phfa.asp. April 24, 2002.
*Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
*Wolterink AFWM, Jonker AB, Kengen SWM, . 2002. Pseudomonas chloritidismutans sp. nov., a non-denityifying, chlorate-reducing bacterium. Int J Syst Evol Microbiol 52:2183–2190.12508887
Wondergem E, Van Dijk-Looijaard AM. 1991. Chlorine dioxide as a post-disinfectant for Dutch drinking water. Sci Total Environ 102:101–112.2038663
*Xu J, Trimble JJ, Steinberg L, . 2004. Chlorate and nitrate reduction pathways are separately induced in the perchlorate-respiring bacterium Dechlorosoma sp. KJ and the chlorate-respiring bacterium Pseudomonas sp. PDA. Water Res 38:673–680.14723936
*Yokose Y, Uchida K, Nakae D, . 1987. Studies of carcinogenicity of sodium chlorite in B6C3F1 mice. Environ Health Perspect 76:205–210.3447900
Zhang X, Echigo S, Minear RA, . 1999. Characterization and comparison of disinfection by-products from using four major disinfectants. Am Chem Soc Abstr Pap 39:251–254.
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
*Zika RG, Moore CA, Gidel LT, . 1984. Sunlight-induced photodecomposition of chlorine dioxide. In: Jolley RL, Bull RJ, Davis WP, . eds., Water chlorination-Chemistry, environmental impact and health effects. Vol. 5. Williamsburg, VA: Lewis Publishers, Inc., 1041–1063.
Zoeteman BCJ, Hrubec J, de Greef E, . 1982. Mutagenic activity associated with by-products of drinking water disinfection by chlorine, chlorine dioxide, ozone and UV-irradiation. Environ Health Perspect 46:197–205.7151762