# 8 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding chlorine dioxide and chlorite in air, water, and other media are summarized in Table 8-1.

ATSDR has derived an intermediate-duration inhalation MRL of 0.001 ppm (0.003 mg/m^3^) for chlorine dioxide based on a LOAEL of 1 ppm for respiratory effects (peribronchiolar edema and vascular congestion in the lungs) in rats exposed to chlorine dioxide vapors 5 hours/day, 5 days/week for 2 months (Paulet and Desbrousses 1972). The LOAEL was converted to a LOAEL_HEC_ of 0.3 ppm and divided by an uncertainty factor of 300 (3 for interspecies extrapolation using dosimetric adjustments, 10 for the use of a LOAEL, and 10 to account for sensitive populations).

ATSDR has derived an intermediate-duration oral MRL of 0.1 mg/kg/day for chlorite based on a NOAEL of 2.9 mg chlorite/kg/day and a LOAEL of 5.7 mg chlorite/kg/day for neurodevelopmental effects (lowered auditory startle amplitude) in rat pups that had been exposed throughout gestation and lactation via their mothers (CMA 1996; Gill et al. 2000). The NOAEL of 2.9 mg chlorite/kg/day was divided by an uncertainty factor of 30 (10 for interspecies extrapolation and 3 to account for sensitive populations).

ATSDR considered the intermediate-duration oral MRL for chlorite to be applicable to chlorine dioxide as well.

EPA (IRIS 2002) has derived an RfC of 2x10^-4^ mg/m^3^ for chlorine dioxide based on a LOAEL of 2.76 mg/m^3^ (1 ppm) for respiratory effects (peribronchiolar edema and vascular congestion in the lungs) in rats exposed to chlorine dioxide vapors 5 hours/day, 5 days/week for 2 months (Paulet and Desbrousses 1972). The LOAEL was converted to a LOAEL_HEC_ of 0.64 mg/m^3^ and divided by an uncertainty factor of 3,000 (10 for extrapolation of a chronic RfC from a subchronic study, 3 for interspecies extrapolation using dosimetric adjustments, 10 for intrahuman variability, and 10 to account for extrapolation from a LOAEL for mild effects and for the lack of inhalation developmental and reproductive toxicity studies).

EPA (IRIS 2002) has derived an RfD of 3x10^-2^ mg/kg/day for chlorite based on a NOAEL of 3 mg/kg/day for neurodevelopmental effects in rat pups that had been exposed throughout gestation and lactation via their mothers (CMA 1996; Gill et al. 2000). The NOAEL of 3 mg chlorite/kg/day was divided by an uncertainty factor of 100 (10 for interspecies extrapolation and 10 to account for sensitive populations). EPA (IRIS 2002) considered the RfD for chlorite to be applicable to chlorine dioxide as well.

Table 8-1 Regulations and Guidelines Applicable to Chlorine Dioxide and Chlorite

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | | IARC 2002
IARC | Sodium chlorite | Group 3^a^ | IARC 2002
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | 0.1 ppm | ACGIH 2001
ACGIH | TLV-STEL (15-minute TWA) | 0.3 ppm | ACGIH 2001
EPA | Chemical accident prevention | | EPA 2002b; 40CFR68, Appendix A
EPA | Toxic end point | 2.8x10^-3^ mg/L | EPA 2002b; 40CFR68, Appendix A
EPA | Regulated toxic substance for accidental release prevention^b^ | | EPA 2002a; 40CFR68.130, Table 1
EPA | Threshold quantity | 1,000 pounds | EPA 2002a; 40CFR68.130, Table 1
NIOSH | TWA-REL (10-hour TWA) | 0.1 ppm | NIOSH 2002
NIOSH | STEL (15-minute TWA) | 0.3 ppm | NIOSH 2002
NIOSH | IDLH | 5 ppm | NIOSH 2002
OSHA | PEL (8-hour TWA) for general industry | 0.1 ppm | OSHA 2002b; 29CFR1910.1000
OSHA | Highly hazardous chemical for general industry | | OSHA 2002c; 29CFR1910.119, Appendix A
OSHA | Threshold quantity | 1,000 pounds | OSHA 2002c; 29CFR1910.119, Appendix A
OSHA | PEL (8-hour TWA) for construction industry | 0.1 ppm | OSHA 2002a; 29CFR1926.55
OSHA | Highly hazardous chemical for construction industry | | OSHA 2002d; 29CFR1926.64, Appendix A
OSHA | Threshold quantity | 1,000 pounds | OSHA 2002d; 29CFR1926.64, Appendix A
b. Water
EPA | Maximum contaminant level | | EPA 2002e; 40CFR141.64(a)
EPA | Chlorite | 1.0 mg/L | EPA 2002e; 40CFR141.64(a)
EPA | Maximum contaminant level goal | | EPA 2002f; 40CFR141.53
EPA | Chlorite | 0.8 mg/L | EPA 2002f; 40CFR141.53
EPA | Maximum residual disinfectant level | 0.8 mg/L | EPA 2002g; 40CFR141.65(a)
EPA | Maximum residual disinfectant level goal | 0.8 mg/L | EPA 2002h; 40CFR141.54
c. Food
EPA | Exemption from the requirement of a tolerance—sodium chlorite | For residues as a seed - soak treatment in growing Brassica (cole) leafy vegetables and radishes | EPA 2002j; 40CFR180.1070
FDA | Direct food additive permitted in food for human consumption; used as an antimicrobial agent in water used in poultry processing and to wash fruits and vegetables | Not to exceed 3 ppm | FDA 2001e; 21CFR173.300
FDA | Direct food additive permitted in food for human consumption; used as an antimicrobial agent— acidified sodium chlorite | Used at levels from 50–1,500 ppm | FDA 2001d; 21CFR173.325
FDA | Indirect food additive; adjuvants, production aids, and sanitizers | | FDA 2001b; 21CFR178.1010
FDA | Indirect food substance affirmed as generally recognized as safe; used as a slimicide in the manufacture of paper and paperboard that contact food—sodium chlorite | Used at levels from 125–250 ppm | FDA 2001c; 21CFR186.1750
FDA | Substance for use only as components of adhesives—sodium chlorite | | FDA 2001a; 21CFR175.105 (c)(5)
d. Other
EPA | Chlorine dioxide | | IRIS 2002
EPA | Carcinogenicity classification | Group D^c^ | IRIS 2002
EPA | RfC | 2x10^-4^ mg/m^3^ | IRIS 2002
EPA | RfD | 3x10^-2^ mg/kg/day | IRIS 2002
EPA | Chlorite | | IRIS 2002
EPA | Carcinogenicity classification | Group D^c^ | IRIS 2002
EPA | RfC | No data | IRIS 2002
EPA | RfD | 3x10^-2^ mg/kg/day | IRIS 2002
EPA | Toxic chemical release reporting; community right-to-know; effective date for reporting | 01/01/87 | EPA 2002k; 40CFR372.65(a)
[underlined: STATE]
Regulations and Guidelines:
a. Air
Louisiana | Toxic air pollutantd | | BNA 2001
Louisiana | Minimum emission rate | 25 pounds/year | BNA 2001
New Mexico | Toxic air pollutant | | BNA 2001
New Mexico | OEL | 0.3 mg/m^3^ | BNA 2001
New Mexico | Emissions | 0.02 pounds/hour | BNA 2001
Vermont | Hazardous air contaminant | | BNA 2001
b. Water
Maine | Drinking water guideline | | HSDB 2002
Maine | Chlorine dioxide | 60 μg/L | HSDB 2002
Maine | Chlorite | 7 μg/L | HSDB 2002
c. Food | No data
d. Other
Florida | Toxic substance in the workplace | | BNA 2001

a Group 3: not classifiable as to its carcinogenicity to humans

b Basis for listing: toxic gas

c Group D: not classifiable as to human carcinogenicity

d Class II: suspected human carcinogen and known or suspected human reproductive toxin

ACGIH = American Conference of Governmental Industrial Hygienists; BNA = Bureau of National Affairs; CFR = Code of Federal Regulations; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life and health; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; OEL = occupational exposure limit; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; ppm = parts per million; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term exposure limit; TLV = threshold limit value; TWA = time-weighted average