# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of chlorine dioxide and sodium chlorite is located in Table 4-1. Table 4-1 lists common synonyms, trade names, and other pertinent identification information for chlorine dioxide and sodium chlorite.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of chlorine dioxide and sodium chlorite is located in Table 4-2. Table 4-2 lists important physical and chemical properties of chlorine dioxide and sodium chlorite, but is not intended to be all inclusive.

Table 4-1 Chemical Identity of Chlorine Dioxide and Sodium Chlorite

Characteristic | Information
Chemical name | Chlorine dioxide | Sodium chlorite
Synonym(s) | Alcide; Anthium dioxcide; Chlorine(IV) oxide; Chlorine oxide; Chlorine peroxide; Chloroperoxide; Chloriperoxyl; Chloryl radical; Dioxide de cloro [Spanish]; Dioxide de chlore [French]; Caswell No. 179A; Doxcide 50 | Chlorous acid, sodium salt; Textone
Registered trade name(s) | No data | No data
Chemical formula | ClO_2_ | NaClO_2_
Chemical structure | [image] | [image]
Identification numbers:
CAS Registry | 10049-04-4 | 7758-19-2
NIOSH RTECS | FO3000000 | VZ4800000
EPA Hazardous Waste | No data | No data
OHM/TADS | No data | No data
DOT/UN/NA/IMCO | NA 9191 (Frozen Solution) | UN 1496 (solid)/UN 1908 (solution)
HSDB | 517 | 733
NCI | No data | No data

CAS = Chemical Abstracts Services; CIS = Chemical Information System; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Chlorine Dioxide and Sodium Chlorite

Property | Chlorine dioxide | Sodium chlorite
Molecular weight (g/mol) | 67.452^a^ | 90.45^b^
Color | Yellow to reddish-yellow^c^ | White^b^
Physical state | Gas^c^ | Solid^c^
Melting point | -59 °C^c^ | 180–200° C (decomposes)^c^
Boiling point | 11 °C^c^ | Decomposes^c^
Density | 1.640 g/mL (0 °C; liquid)^a^; 1.614 g/mL (10 °C; liquid)^a^ | 2.468 g/mL (solid)^d^
Odor | Pungent, distinctive from chlorine^a^ | No data
Odor threshold:
Water | No data | No data
Air | No data | No data
Taste | No data | No data
Solubility:
Water | 3.01 g/L at 25 °C and 34.5 mm Hg^c^ | 390 g/L at 30 °C^c^
Other solvents | No data | No data
Partition coefficients:
Log K_ow_ | No data | No data
Log K_oc_ | No data | No data
Vapor pressure at 25 °C | >1 atm (gas)^e^ | No data
Photolysis | Unstable in light^e^ | No data
Henry’s law constant at 25 °C | No data | No data
Autoignition temperature | No data | No data
Flashpoint | No data | No data
Flammability limits at 25 °C | No data | No data
Incompatibilities | Organic materials, heat, phosphorus, potassium hydroxide, sulfur, mercury, carbon monoxide; unstable in light; a powerful oxidizer^e^ | Organic matter, sulfur, powdered coal; a powerful oxidizer^b^
Conversion factors (25 °C and 1 atm) | 1 ppm=2.76 mg/m^3e^ | No data
Explosive limits | Explosive at temperatures >-40 °C^a^ and concentrations in excess of 10% v/v at 1 atm^f^ | No data

a Kaczur and Cawfield 1993

b Vogt et al. 1986

c O’Neil 2001

d HSDB 2002

e NIOSH 2002

f Dobson and Cary 2002