# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Chlorine dioxide Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlorine dioxide
CAS Number: | 10049-04-4
Date: | July 2, 2004
Profile Status: | Final Post Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 8
Species: | Rat

[underlined: Minimal Risk Level]: 0.001 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Paulet G, Desbrousses S. 1972. On the toxicology of chlorine dioxide. Arch Mal Prof 33(1–2):59–61.5044534

[underlined: Experimental design and effects noted]: The intermediate-duration inhalation MRL is based on results of a study in which the most significant finding was respiratory effects in adult rats exposed to chlorine dioxide vapors. Groups of eight Wistar rats (sex not reported) were exposed to chlorine dioxide vapors at a concentration of 1 ppm (2.8 mg/m^3^), 5 hours/day, 5 days/week for 2 months. The authors stated that weight gain and erythrocyte and leukocyte levels were not affected, but concurrent control data were not presented. Chlorine dioxide-induced respiratory effects included peribronchiolar edema and vascular congestion in the lungs. No alterations in epithelium or parenchyma were seen. This study identified a LOAEL of 1 ppm (2.8 mg/m^3^) for mild respiratory effects.

[underlined: Dose and end point used for MRL derivation]: 1 ppm; respiratory effects.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

[X] 10 for use of a LOAEL

[X] 3 for interspecies extrapolation since the exposure concentration was dosimetrically adjusted

[X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] Yes

LOAEL_ADJ_ = LOAEL (1 ppm) × 5 hours/24 hours × 5 days/7 days = 0.15 ppm

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

The human equivalent concentration (HEC) for the LOAEL (LOAEL_HEC_) was calculated by multiplying the LOAEL_ADJ_ by the regional gas ratio for the pulmonary region of the respiratory tract (RGDR_PU_) according to the equation:

R G D R_P U_ = (( R G D_P U_ )_A_)/(( R G D_P U_ )_H_) = ([ (Q˙_a l v_)/(S A_P U_) ]_A_)/([ (Q˙_a l v_)/(S A_P U_) ]_H_) ⋅ [ ([ e^− (S A_T B_)/(V˙_E_)^ ]_A_)/([ e^− (S A_T B_)/(V˙_E_)^ ]_H_) ]^K_g T B_^ ⋅ [ ([ e^− (S A_E T_)/(V˙_E_)^ ]_A_)/([ e^− (S A_E T_)/(V˙_E_)^ ]_H_) ]^K_g E T_^

(EPA 1994, Equation 4-28 to be used for pulmonary effects of a Category 1 gas)

RGD | = | Regional Gas Dose
RGDR | = | Regional Gas Dose Ratio

Q_alv_ | = | alveolar ventilation rate (cm^3^/minute)
SA | = | surface area (cm^2^)
V_E_ | = | minute volume (cm^3^/minute)
K_g_ | = | overall mass transport coefficient (cm/minute)

ET | = | extrathoracic (nose and mouth)
TB | = | tracheobronchial (trachea, bronchi, bronchioles to terminal bronchioles)
PU | = | pulmonary (respiratory bronchioles, alveolar region)
A | = | animal
H | = | human

The following values were used for respiratory parameters in the equation above:

Species | Surface area (SA) (EPA 1994, Table 4-4)
Species | ET (cm^2^) | TB (cm^2^) | PU (cm^2^)
Rat | 15.0 | 22.5 | 3,400
Human | 200 | 3,200 | 540,000

Species | Alveolar ventilation rate (Q_alv_, in cm^3^/minute) | Minute volume (VE, in cm^3^/minute)
Rat | 111 (67% of VE per EPA 1988) | 165^*^ (Equation 4-4, EPA 1994)
Human | 9,250 (67% of VE per EPA 1988) | 13,800 (EPA 1994)

* Average body weight of the treated rats in the critical study (Paulet and Desbrousses 1972) was 0.225 kg.

Since the overall mass transport coefficient (K_g_) is not available, the value has been assumed to equal 1.

Therefore:

R G D R_P U_ = ([ (111 c m^3^ / min)/(3400 c m^2^) ]_r a t_)/([ (9250 c m^3^ / min)/(540,000 c m^2^) ]_H_) ⋅ [ ([ e^− (22.5 c m^2^)/(165 c m^3^ / min)^ ]_r a t_)/([ e^− (3200 c m^2^)/(13800 c m^3^ / min)^ ]_H_) ]^1^ ⋅ [ ([ e^− (15 c m^2^)/(165 c m^3^ / min)^ ]_r a t_)/([ e^− (200 c m^2^)/(13800 c m^3^ / min)^ ]_H_) ]^1^ R G D R_P U_ = ([ 0.03265 ]_r a t_)/([ 0.01713 ]_H_) ⋅ [ ([ e^− 0.1364^ ]_r a t_)/([ e^− 0.2319^ ]_H_) ]^1^ ⋅ [ ([ e^− 0.09091^ ]_r a t_)/([ e^− 0.01449^ ]_H_) ]^1^ R G D R_P U_ = 1.9060 ⋅ [ ([ 0.8725 ]_r a t_)/([ 0.7930 ]_H_) ]^1^ ⋅ [ ([ 0.9131 ]_r a t_)/([ 0.9856 ]_H_) ]^1^ R G D R_P U_ = 1 . 9060 × 1 . 1003 × 0 . 9093 = 1 . 9070

Therefore: LOAEL_HEC_ = 0.15 ppm x1.9=0.3 ppm

[underlined: Other additional studies or pertinent information that lend support to this MRL]:

Paulet and Desbrousses (1970) exposed groups of 10 rats/sex (strain not specified) to chlorine dioxide vapors at a concentrations of 0 or 2.5 ppm (6.9 mg/m^3^), 7 hours/day for 30 days. The weekly exposure frequency was not reported. Chlorine dioxide-exposed rats exhibited respiratory effects that included lymphocytic infiltration of the alveolar spaces, alveolar vascular congestion, hemorrhagic alveoli, epithelial erosions, and inflammatory infiltrations of the bronchi. The study authors also reported slightly decreased body weight gain and decreased erythrocyte and increased leukocyte levels, relative to controls. Recovery from the pulmonary lesions was apparent in rats examined after a 15-day recovery period.

A set of other inhalation studies supports the finding of the respiratory system as a major target of toxicity following exposure to chlorine dioxide vapors, although these studies are limited in design (Dalhamn 1957). A single 2-hour inhalation exposure of four rats to a chlorine dioxide concentration of 260 ppm (728 mg/m^3^) resulted in pulmonary edema and nasal bleeding. Respiratory distress was reported in three other rats subjected to 3 weekly 3-minute exposures to decreasing concentrations of airborne chlorine dioxide from 3,400 to 800 ppm (from 9,520 to 2,240 mg/m^3^); bronchopneumonia was observed in two of these rats. In a third rat study, repeated exposure to approximately 10 ppm (28 mg/m^3^) of chlorine dioxide (4 hours/day for 9 days in a 13-day period) resulted in rhinorrhea, altered respiration, and respiratory infection. No indications of adverse effects were seen in rats exposed to approximately 0.1 ppm (0.28 mg/m^3^) of chlorine dioxide 5 hours/day for 10 weeks.

Human data support the animal findings. In a case of accidental inhalation exposure to chlorine dioxide in the paper industry, exposure to 5 ppm (14 mg/m^3^) for an unspecified amount of time resulted in signs of respiratory irritation (Elkins 1959). In another case report, a woman experienced coughing, pharyngeal irritation, and headache while mixing a bleach solution that was then used to bleach dried flowers (Exner-Freisfeld et al. 1986). Nasal abnormalities (including injection, telangectasia, paleness, cobblestoning, edema, and thick mucus) were observed in 13 individuals (1 man and 12 women) who had been accidentally exposed to chlorine dioxide from a leak in a water purification system pipe 5 years earlier (Meggs et al. 1996).

[underlined: Agency Contact (Chemical Manager):] Jessilynn B. Taylor, M.S.

## Chlorite (as sodium salt) Intermediate Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical Name: | Chlorite (as sodium salt)
CAS Number: | 7758-19-2
Date: | July 2, 2004
Profile Status: | Final Post Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 10
Species: | Rat

[underlined: Minimal Risk Level]: 0.1 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Gill MW, Swanson MS, Murphy SR, . 2000. Two-generation reproduction and developmental neurotoxicity study with sodium chlorite in the rat. J Appl Toxicol 20:291–303.10942904

[underlined: Experimental design and effects noted]: The intermediate-duration oral MRL is based on results of a study in which the most significant finding was neurodevelopmental delays (lowered auditory startle amplitude, decreased brain weight) in rat pups that had been exposed throughout gestation and lactation via their mothers. Groups of 30 male and 30 female Sprague-Dawley rats (F_0_) received sodium chlorite in the drinking water at concentrations of 35, 70, or 300 mg/L (approximate chlorite doses of 3, 5.7, and 21 mg/kg/day and 3.9, 7.6, and 29 mg/kg/day for males and females, respectively) for 10 weeks prior to mating and during mating; exposure of females continued throughout gestation and lactation. Groups of F_1_ pups were continued on the same treatment regimen as their parents (chlorite doses of 2.9, 6.0, and 23 mg/kg/day and 3.9, 8.0, and 29 mg/kg/day for F_1_ males and females, respectively). Low-dose female pups exhibited slight, but statistically significant differences in some hematological parameters, relative to controls. No other effects were seen in pups of this exposure level, and the hematological effects were not considered to be adverse. Mid-dose pups exhibited a significant decrease in maximum response to an auditory startle stimulus on postnatal day 24, but not on postnatal day 60. At this exposure level, F_1_ pups also exhibited reduced liver weight. At the high dose, significant effects included reduced absolute and relative liver weight in F_1_ males and females, reduced pup survival, reduced body weight at birth and throughout lactation in F_1_ and F_2_ rats, lowered thymus and spleen weight in both generations, lowered incidence of pups exhibiting normal righting reflex and with eyes open on postnatal day 15, decreased absolute brain weight for F_1_ males and F_2_ females, delayed sexual development in males (preputial separation) and females (vaginal opening) in F_1_ and F_2_ rats, and lowered red blood cell parameters in F_1_ rats.

[underlined: Dose and end point used for MRL derivation]: 2.9 mg/kg/day

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

[X] 10 for interspecies extrapolation

[X] 3 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? The study authors calculated sodium chlorite intakes (in mg/kg/day) from measured water consumption and body weight data. These intakes were multiplied by a factor of 0.75 to adjust for the fraction of chlorite in sodium chlorite, resulting in calculated doses of chlorite in units of mg/kg/day.

[underlined: Was a conversion used from intermittent to continuous exposure]? NA

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: NA

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The principal study is supported by the developmental studies of Orme et al. (1985), Taylor and Pfohl (1985), Mobley et al. (1990), and Toth et al. (1990), in which rats administered chlorite (as sodium salt) or chlorine dioxide at similar dosages in drinking water showed alterations in exploratory and locomotor behavior and reduced brain weights. These studies supported NOAELs and LOAELs of approximately 3 and 14 mg/kg/day, respectively.

Chlorine dioxide in drinking water rapidly degrades to chlorite (Michael et al. 1981). In laboratory animals, orally administered chlorine dioxide is rapidly converted to chlorite and chloride ion (Abdel-Rahman et al. 1980b). Being a strong oxidizer and water soluble, chlorine dioxide is not likely absorbed in the gastrointestinal tract to any great extent. Chlorite is the most likely source of systemic toxicity resulting from oral exposure to either chlorine dioxide or chlorite (soluble salts). Therefore, the intermediate-duration oral MRL derived for chlorite should also be applicable to chlorine dioxide.

[underlined: Agency Contact (Chemical Manager)]: Jessilynn B. Taylor, M.S.