# 8 REFERENCES

*Cited in text

*Abbott BD, Birnbaum LS. 1989a. Cellular alterations and enhanced induction of cleft palate after coadministration of retinoic acid and TCDD. Toxicol Appl Pharmacol 99:287–301.2734792
*Abbott BD, Birnbaum LS. 1989b. TCDD alters medial epithelial cell differentiation during palatogenesis. Toxicol Appl Pharmacol 99:276–286.2734791
*Abbott BD, Birnbaum LS. 1990a. TCDD-induced altered expression of growth factors may have a role in producing cleft palate and enhancing the incidence of clefts after coadministration of retinoic acid and TCDD. Toxicol Appl Pharmacol 106:418–432.2260090
*Abbott BD, Birnbaum LS. 1990b. Effects of TCDD on embryonic ureteric epithelial EGF receptor expression and cell proliferation. Teratol 41:71–84.
*Abbott BD, Birnbaum LS, Dilberto JJ. 1996. Rapid distribution of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) to embryonic tissues in C57BL/6N mice and correlation with palatal uptake in vitro. Toxicol Appl Pharmacol 141:256–263.8917698
*Abbott BD, Birnbaum LS, Perdew GH. 1995. Developmental expression of two members of a new class of transcription factors: I. Expression of aryl hydrocarbon receptor in the C57BL/6N mouse embryo. Develop Dynam 204:133–143.
*Abbott BD, Birnbaum LS, Pratt RM. 1987a. TCDD-induced hyperplasia of the ureteral epithelium produces hydronephrosis in murine fetuses. Teratology 35:329–334.3629513
*Abbott BD, Diliberto JJ, Birnbaum LS. 1989. 2,3,7,8-Tetrachlorodibenzo-p-dioxin alters embryonic palatal medial epithelial cell differentiation in vitro. Toxicol Appl Pharmacol 100:119–131.2763295
*Abbott BD, Harris MW, Birnbaum LS. 1992. Comparisons of the effects of TCDD and hydrocortisone on growth factor expression provide insight into their interaction in the embryonic mouse palate. Teratol 45:35–53.
*Abbott BD, Morgan KS, Birnbaum LS, . 1987b. TCDD alters the extracellular matrix and basal lamina of the fetal mouse kidney. Teratol 35:335–344.
*Abbott BD, Perdew GH, Birnbaum LS. 1994b. Ah receptor in embryonic mouse palate and effects of TCDD on receptor expression. Toxicol Appl Pharmacol 126:16–25.8184424
*Abbott BD, Perdew GH, Buckalew AR, . 1994a. Interactive regulation of Ah and glucocorticoid receptors in the synergistic induction of cleft palate by 2,3,7,8-tetrachlorodibenzo-p-dioxin and hydrocortisone. Toxicol Appl Pharmacol 128:138–150.8079347
*Abbott BD, Probst MR. 1995. Developmental expression of two members of a new class of transcription factors: II. Expression of aryl hydrocarbon receptor nuclear translocator in the C57BL/6N mouse embryo. Develop Dynam 204:144–155
Abernathy DJ, Boreiko CJ. 1987. Promotion of C3H/10T1/2 morphological transformation by polychlorinated dibenzo-p-dioxin isomers. Carcinogenesis 8:1485–1490.3652385
Abernathy DJ, Greenlee WF, Hubard JC, . 1985. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD) promotes the transformation of C3H/10T1/2 cells. Develop Dynam 204:144–155
*Abraham K, Hille A, Ende M, . 1994. Intake and fecal excretion of PCDDs, PCDFs, HCB and PCBs (138,153,180) in a breast-fed and a formula-fed infant. Chemosphere 29:2279–2286.7850375
*Abraham K, Knoll A, Ende M, . 1996. Intake, fecal excretion, and body burden of polychlorinated dibenzo-p-dioxins and dibenzofurans in breast-fed and formula-fed infants. Pediatr Res 40:671–679.8910931
*Abraham K, Krowke R, Neubert D. 1988. Pharmacokinetics and biological activity of 2,3,7,8-tetrachlorodibenzo-p-dioxin: 1. Dose-dependent tissue distribution and induction of hepatic ethoxyresorufin O-deethylase in rats following a single injection. Arch Toxicol 62:359–368.3242446
*Abraham K, Weberrub U, Wiesmuller T, . 1989c. Comparative studies on absorption and distribution in the liver and adipose tissue of PCDDs and PCDFs in rats and marmoset monkeys. Chemosphere 19:887–892.
*Abraham K, Wiesmueller T, Brunner H, . 1989a. Elimination of various polychlorinated dibenzo-p-dioxins and dibenzofurans (PCDDs and PCDFs) in rat feces. Arch Toxicol 63:75–78.2742506
*Abraham K, Wiesmuller T, Brunner H, . 1989b. Absorption and tissue distribution of various polychlorinated dibenzo-p-dioxins and dibenzofurans (PCDDs and PCDFs) in the rat. Arch Toxicol 63:193–202.2764705
*ACGIH. 1990. Threshold limit values and biological exposure indices for 1990û1991. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*Ackermann MF, Gasiewicz TA, Lamm KR, . 1989. Selective inhibition of polymorphonuclear neutrophil activity by 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 101:470–480.2557688
Adams WJ, Blaine KM. 1986. A water solubility determination of 2,3,7,8-TCDD. Chemosphere 15:1397–1400.
*Adams WJ, Degraeve GM, Sabourin TD, . 1986. Toxicity and bioconcentration of 2,3,7,8,-TCDD to fathead minnows (Pimephales promelas). Chemosphere 15:1503–1511.
*Adinolfi M. 1985. The Development of the Human Blood-CSF-Brain Barrier. Developmental Medicine & Child Neurology 27:532–537.4029526
*Adriaens P, Grbic-Galic D. 1994. Reductive dechlorination of PCDD/F by anaerobic cultures and sediments. Chemosphere 29(9–11):2253–2253.
Afghan BK, Carron J, Goulden PD, . 1987. Recent advances in ultratrace analysis of dioxins and related halogenated hydrocarbons. Can J Chem 65:1086–1097.
*Ahlborg UG, Becking GC, Birnbaum LS, . 1994. Toxic equivalency factors for dioxin-like PCBs. Chemosphere 28(6):1049–1067.
*Ahlborg UG, Brouwer A, Fingerhut MA, . 1992. Impact of polychlorinated dibenzo-p-dioxins, dibenzofurans, and biphenyls on human and environmental health, with special emphasis on application of the toxic equivalency factor concept. Europ J Pharmacol 228:179–199.
Ahlborg UG, Hanberg A. 1992. Toxicokinetics of PCDDs and PCDFs of importance to the development of human risk assessment. Toxic Substances Journal 12:197–211.
Ahlborg UG, Waern F, Håkansson H. 1987. Interactive effects of PCDDs and PCDFs occurring in human mother’s milk. Chemosphere 16:1701–1706.
Ahling B. 1979. Destruction of chlorinated hydrocarbons in cement kiln. Environ Sci Technol 13:1377–1379.
Ahling B, Liondskog A, Jansson B, . 1977. Formation of polychlorinated dibenzo-p-dioxins and dibenzofurans during combustion of a 2,4,5-T formulation. Chemosphere 6:461–468.
*Al-Bayati ZA, Wahba ZZ, Stohs SJ. 1988. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD)-induced alterations in lipid peroxidation, enzymes, and divalent cations in rat testis. Xenobiotica 18:1281–1289.3245226
*Alaluusua S, Lukinmaa P-L, Vartiainen T, . 1996. Polychlorinated dibenzo-p-dioxins and dibenzofurans via mother’s milk may cause developmental defects in the child’s teeth. Environ Toxicol Pharmacol 1:193–197.21781681
Albro PW, Crummett WB, Dupuy AE Jr, . 1985. Methods for the quantitative determination of multiple, specific polychlorinated dibenzo-p-dioxin and dibenzofuran isomer in human adipose tissue in the parts-per-trillion range: An interlaboratory study. Anal Chem 57:2717–2725.4073517
Albro PW, Lister MI, Cahe K, . 1979. A radioimmunoassay for chlorinated dibenzo-p-dioxins. Toxicol Appl Pharmacol 50:137–146.386569
Aldred JE. 1978. Report of the Consultative Council on congenital abnormalities in the Yarrom District. Minister of Health. Melbourne, Victoria, Australia.
Alexander LR, Maggio VL, Gill JB, . 1989. Performance of the high sensitivity ion source for PCDD/PCDF analyses in human serum and adipose tissue. Chemosphere 19:241–248.
Alexandrou N, Miao Z, Colquhoun M, . 1992. Supercritical fluid extraction and cleanup with capillary GC-ion trap mass spectrometry for determination of polychlorinated dibenzo-p-dioxins and dibenzofurans in environemental samples. J Chromatogr Sci 30(9):335–382.
*Alexandrou N, Pawliszyn JB. 1990. Supercritical fluid extraction for the rapid determination of polychlorinated dibenzo-p-dioxins and dibenzofurans in municipal incinerator fly ash [Abstract]. New York, NY: 41st Pittsburgh Conference and Exposition on Analytical Chemistry and applied chemistry.
Allen JR, Barsotti DA, Lambrecht LK, . 1979. Reproductive effects of halogenated aromatic hydrocarbons on nonhuman primates. Ann NY Acad Sci 320:419–425.222194
*Allen JR, Barsotti DA, Van Miller JP, . 1977. Morphological changes in monkeys consuming a diet containing low levels of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Food Cosmet Toxicol 15:401–410.413768
*Allen JR, Van Miller JP, Norback DH. 1975. Tissue distribution, excretion and biological effects of [14C]tetrachlorodibenzo-p-dioxin in rats. Food Cosmet Toxicol 13:501–505.1201832
*Altman PK, Dittmer DS. 1974. In: Biological handbooks: Biology data book, Volume III, second edition. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
*Amendola G, Barna D, Blosser R, . 1989. The occurrence and fate of PCDDs and PCDFs in five bleached kraft pulp and paper mills. Chemosphere 18:1181–1188.
*Anaizi NH, Cohen JJ. 1978. The effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin on the renal tubular secretion of phenolsulfonphthalein. J Pharmacol Exp Ther 207:748–755.731430
Andersen ME. 1985. Adjusting exposure limits for long and short exposure periods using a physiological pharmacokinetic model. Am ind Hyg Assoc J 48(4):335–343.
*Andersen ME, Birnbaum LS, Barton HA, . 1997b. Regional hepatic CYP1A1 and CYP1A2 induction with 2,3,7,8-tetrachlorodibenzo-p-dioxin evaluated with a multicompartment geometric model of hepatic zonation. Toxicol Appl Pharmacol 144:145–155.9169078
*Andersen ME, Eklund CR, Mills JJ, . 1997a. A multicompartment geometric model of the liver in relation to regional induction of cytochrome P450s. Toxicol Appl Pharmacol 144:135–144.9169077
*Andersen ME, Krishman K. 1994. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. In: H. Salem, ed. Current concepts and approaches on animal test alternatves. U.S. Army Chemical Research Development and Engineering Center, Aberdeen Proving Ground, Maryland.
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives. U.S. Army Chemical Research Development and Engineering Center, Aberdeen Proving Ground, Maryland.
*Andersen ME, MacNaughton MG, Clewell HJ, . 1987. Adjusting exposure limits for long and short exposure periods using a physiological pharmacokinetic model. Am Ind Hyg Assoc J 48(4):335–343.3591649
*Andersen ME, Mills JJ, Gargas ML, . 1993. Modeling receptor-mediated processes with dioxin: Implications for pharmacokinetics and risk assessment. Risk Analysis 13:25–36.8383868
*Anderson HA, Falk C, Hanrahan L, . 1998. Profiles of Great Lakes critical pollutants: A sentinel analysis of human blood and urine. Environmental Health Perspectives 106(5):279–289.9560354
*Andrews JS Jr, Garret WA, Patterson DG, . 1989. 2,3,7,8-Tetrachlorodibenzo-p-dioxin levels in adipose tissue of persons with no known exposure and in exposed persons. Chemosphere 18:499–506.
Aniline O. 1973. Preparation of chlorodibenzo-p-dioxins for toxicological evaluation. In: Blair EH, ed. Advances in Chemistry Series No. 120: Chlorodioxins-origin and fate. Proceedings of the 162nd Meeting of the American Chemical Society. Washington, DC, 126–135.
*Ankley GT, Niemi GJ, Lodge KB, . 1993. Uptake of planar polychlorinated biphenyls and 2,3,7,8-substituted polychlorinated dibenozfurans and dibenzo-p-dioxins by birds nesting in the Lower Fox River and Green Bay, Wisconsin, USA. Arch Environ Contam Toxicol 24(3):332–344.
Anonymous. 1985. Dioxins in the environment: No consensus on human hazard. Chem Eng News May 27, 41–44.
*Anonymous. 1997. An enlightened approach to screening for dioxins. Environmental Health Perspectives 105(11):1176–1177.
*Antila S, Hietanen E, Vainio H, . 1991. Smoking and peripheral type of cancer are related to high levels of pulmonary cytochrome P450IA in lung cancer patients. Int J Cancer 47:681–685.1848536
*Arthur MR, Frea JL. 1989. 2,3,7,8-Tetrachlorodibenzo-p-dioxin: Aspects of its important properties and its potential biodegradation in soils. J Environ Qual 18:1–11.
*Aschengrau A, Monson RR. 1989. Paternal military service in Vietnam and risk of spontaneous abortion. J Occup Med 31:618–623.2769458
*Aschengrau A, Monson RR. 1990. Paternal military service in Vietnam and the risk of late adverse pregnancy outcomes. Am J Publ Health 80:1218–1223.
*Assennato G, Cervino D, Emmett EA, . 1989. Follow-up of subjects who developed chloracne following TCDD exposure at Seveso. Am J Ind Med 16:119–125.2773943
*ASTER. 1995. ASTER (Assessment Tools for the Evaluation of Risk) ecotoxicity profile. Duluth, MN: Environmental Research Laboratory, U.S. Environmental Protection Agency,
Astle JW, Gobas FAPC, Siu WY, . 1987. Lake sediments as historic records of atmospheric contamination by organic chemicals. Adv Chem Ser 216:57–77.
*Astroff B, Eldridge B, Safe S. 1991. Inhibition of the 17’-estradiol-induced and constitutive expression of the cellular proto-oncogene c-fos by 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in the female rat uterus. Toxicol Lett 56:305–315.1903567
*Astroff B, Safe S. 1990. 2,3,7,8-Tetrachlorodibenzo-p-dioxin as an antiestrogen: Effect on rat uterine peroxidase activity. Biochem Pharmacol 39:485–488.2154986
Atkinson R. 1987. Estimation of OH radical reaction rate constants and atmospheric lifetimes for polychlorobiphenyls, dibenzo-p-dioxins, and dibenzofurans. Environ Sci Technol 21:305–307.22185111
*Atkinson R. 1991. Atmospheric lifetimes of dibenzo-p-dioxins and dibenzofurans. Sci Total Environ 104(1–2):17–33.1871588
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicologicol profiles. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
*ATSDR. 1994. Toxicological profile for chlorinated dibenzofurans (CDFs). Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*ATSDR. 1996. National exposure registry: Dioxin subregistry. Baseline and followups 1 and 2 technical report. U.S. Department of Health & Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry (Atlanta, Georgia).
*ATSDR. 1997. Toxicological profile for polychlorinated biphenyls (update). Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*ATSDR/CDC. 1990. Subcommittee report on biological indicators of organ damage. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention, Atlanta, GA.
Aulerich RJ, Bursian SJ, Napolitano AC. 1988. Biological effects of epidermal growth factor and 2,3,7,8-tetrachlorodibenzo-p-dioxin on developmental parameters of neonatal mink. Arch Environ Contam Toxicol 17:27–31.3257373
*Aust SD. 1984. On the mechanism of anorexia and toxicity of TCDD and related compounds. In: Poland A, Kimbrough RD, eds. Banbury report 18. Cold Spring Harbor Laboratory, 309–319.
Axegard P, Renberg L. 1989. The influence of bleaching chemicals and lignin content on the formation of polychlorinated dioxins and dibenzofurans. Chemosphere 19:661–668.
*Axelson O, Sundell L, Anderson K, . 1980. Herbicide exposure and tumor mortality: An updated epidemiologic investigation on Swedish railroad workers. Scand J Work Environ Health 6:73–79.7384770
*Ayotte P, Carrier G, Dewailly E. 1996. Health risk assessement for Inuit newborns exposed to dioxin-like compounds through breast milk. Chemosphere 32:531–542.8907230
*Ayotte P, Dewailly E, Ryan JJ, . 1997. PCBs and dioxin-like compounds in plasma of adult inuit living in Nunavik (Arctic Quebec). Chemosphere 34(5–7):1459–1468.9134679
Ayres DC. 1981. Destruction of polychlorinated-p-dioxins. Nature 290:323–324.7207625
Ayres SM, Webb KB, Evans RG, . 1985. Is 2,3,7,8-TCDD (dioxin) a carcinogen for humans? Environ Health Perspect 62:329–335.3910419
Baars AJ, Jansen M, Breimer DD. 1978. The influence of phenobarbital, 3-methylcholanthrene and 2,3,7,8-tetra chlorodibenzo-p-dioxin on glutathione S-transferase activity of rat liver cytosol. Biochem Pharmacol 27:2487–2494.728202
*Badesha JS, Maliji G, Flaks B. 1995. Immunotoxic effects of prolonged dietary exposure of male rats to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Eur J Pharmacol 293:429–437.8748696
Balarajan R, Acheson ED. 1984. Soft tissue sarcoma in agriculture and forestry workers. J Epidemiol Community Health 38:113–116.6747508
*Balk JL, Piper WN. 1984. Altered blood levels of corticosteroids in the rat after exposure of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Biochem Pharmacol 33:2531–2534.6466368
*Ball LM, Chhabra RS. 1981. Intestinal absorption of nutrients in rats treated with 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). J Toxicol Environ Health 8:629–638.7338935
Ballschmiter K, Budhert H, Neimczyk R, . 1986. Automobile exhausts versus municipal-waste incineration as sources of the polychloro-dibenzodioxins (PCDD) and furans (PCDF) found in the environment. Chemosphere 15:901–915.
Ballschmiter K, Kraemer W, Magg H, . 1984. Distribution of polychlorodibenzodioxin and furan emissions between particulates, flue gas condensate, and ipenger adsorption in stack gas sampling. Chemosphere 13:1139–1142.
*Banks YB, Birnbaum LS. 1991. Absorption of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) after low dose dermal exposure. Toxicol Appl Pharmacol 107:302–310.1994512
*Banks YB, Brewster DW, Birnbaum LS. 1990. Age-related changes in dermal absorption of 2,3,7,8-tetrachlorodibenzo-p-dioxin and 2,3,4,7,8-pentachlorodibenzofuran. Fund Appl Toxicol 15:163–173.
*Banks YB, Jackson JA, Birnbaum LS. 1993. Maturational changes in dermal absorption of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in Fischer 344 rats. Toxicol Appl Pharmacol. 119:214–220.8480330
*Bannister R, Davis D, Zacharewski Z, . 1987. Aroclor 1254 as a 2,3,7,8-tetrachlorodibenzo-p-dioxin antagonist: Effects on enzyme induction and immunotoxicity. Toxicology 40:29–42.
Barber MC, Suarez LA, Lassiter RR. 1988. Modeling bioconcentration of non polar organic pollutants by fish. Environ Toxicol Chem 7:545–558.
*Barbieri S, Pirovano C, Scarlato G, . 1988. Long-term effects on 2,3,7,8-tetrachlorodibenzo-p-dioxin on the peripheral nervous system: Clinical and neurophysiological controlled study on subjects with chloracne from the Seveso area. Neuroepidemiology 7:29–37.2829044
*Barnes D, Alford-Stevens A, Birnbaum L, . 1991. Toxicity equivalency factors for PCBs? Quality assurance: Good Practice, Regulation, and Law. 1:70–81.
*Barnes D, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barnes DG. 1983. Chlorinated dioxins work group. Washington, DC: U.S. Environmental Protection Agency. 12:645–655.
*Barnes DG. 1991. Toxicity equivalents and EPA’s risk assessment of 2,3,7,8-TCDD. Sci Total Environ 104:73–86.1871591
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. U.S. Environmental Protection Agency. Regul Toxicol Pharmacol 8:471–486.3222488
Barnes JM. 1975. Assessing hazards from prolonged and repeated exposure to low doses of toxic substances. Brit Med Bull 31:196–200.813802
*Barthel E. 1981. Increased risk of lung cancer in pesticide-exposed male agricultural workers. J Toxicol Environ Health 8:1027–1040.7338938
*Bartsch H, Hietanen E, Petruzzelli S, . 1990. Possible prognostic value of pulmonary AH-locus-linked enzymes in patients with tobacco-related lung cancer. Int J Cancer 46:185–188.2384269
*Basharova GR. 1996. Reproduction in families of workers exposed to 2,4,5-T intoxication. Organohalogen Compounds 315–318.
*Bastomsky CH. 1977. Enhanced thyroxine metabolism and high uptake goiters in rats after a single dose of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Endocrinology 101:292–296.862558
Batterman AR, Cook PM, Lodge KB, . 1989. Methodology used for a laboratory determination of relative contributions of water, sediment and food chain routes of uptake for 2,3,7,8-TCDD bioaccumulation by lake trout in Lake Ontario. Chemosphere 19:451–458.
*Baughman RW, Meselson M. 1973. An analytical method for detecting TCDD (dioxin): Levels of TCDD in samples from Vietnam. Environ Health Perspect 5:27–35.4752911
*Becher H, Flesch-Janys D, Kauppinen T, . 1996. Cancer mortality in German male workers exposed to phenoxy herbicides and dioxins. Cancer Causes Control 7:312–321.8734824
*Beck H, Dro A, Eckart K, . 1989d. PCDDs, PCDFs and related compounds in paper products. Chemosphere 19:655–660.
Beck H, Dro A, Mathar W. 1990. Interlaboratory study on PCDDs and PCDFs in coffee filter paper. Chemosphere 20:1307–1312.
Beck H, Eckart K, Kellert M, . 1987. Levels of PCDD’s and PCDF’s in samples of human origin and food in the Federal Republic of Germany. Chemosphere 16:1977–1982.
Beck H, Eckart K, Mathar W, . 1988a. Isomer-specific determination of 2,3,7,8-tetrachlorodibenzo-p-dioxin and related compounds in human fat and food. Biomed Environ Mass Spectrom 16:161–165.3242665
*Beck H, Eckart K, Mathar W, . 1988b. Occurrence of PCDD and PCDF in different kinds of paper. Chemosphere 17:51–57.
*Beck H, Eckart K, Mathar W, . 1989a. PCDD and PCDF body burden from food intake in the Federal Republic of Germany. Chemosphere 18:417–424.
Beck H, Eckart K, Mathar W, . 1989b. Dependence of PCDD and PCDF levels in human milk on various parameters in the Federal Republic of Germany. Chemosphere 18:1063–1066.
*Beck H, Eckart K, Mathar W, . 1989c. Levels of PCDDs and PCDFs in adipose tissue of occupationally exposed workers. Chemosphere 18:507–516.
Beebe LE. 1990. Adenylate cyclase regulation in the spermatogenic cell plasma membrane: Modulating effects of TPA and TCDD [Abstract]. Diss Abstr Int [B] 50:2860
Benthe C, Heinzow B, Jessen H, . 1992. Polychlorinated biphenyls indoor air contamination due to thiokol-rubber sealants in an office building. Eleventh international symposium on chlorinated dioxins and related compounds, Part 2. Research Triangle Park, North Carolina, USA. Chemosphere 25(7–10):1481–1486.
*Berghard A, Gradin K, Pongratz I, . 1993. Cross-coupling of signal transduction pathways: the dioxin receptor mediates induction of cytochrome P-450IA1 expression via a protein kinase C-dependent mechanism. Mol Cell Biol 13:67–689.
*Berry DL, DiGiovanni J, Juchau MR, . 1978. Lack of tumor-promoting ability of certain environmental chemicals in a two-stage mouse skin tumorigenesis assay. Res Commun Chem Pathol Pharmacol 20:101–108.208126
*Berry DL, Slaga TJ, DiGiovanni J, . 1979. Studies with chlorinated dibenzo-p-dioxins, polybrominated biphenyls and polychlorinated biphenyls in a two-stage system of mouse skin tumorigenesis: Potent anticarcinogenic effects. Ann NY Acad Sci 320:405–414.222192
*Berry RM, Luthe CE, Voss RH. 1993. Ubiquitous nature of dioxins: A comparison of the dioxins content of common everyday materials with that of pulps and papers. Environ Sci Technol 27(6):1164–1168.
*Bertazzi PA, Pesatori AC, Consonni D, . 1993. Cancer incidence in a population accidentally exposed to 2,3,7,8-tetrachlorodibenzo-para-dioxin. Epidemiol 4:398–406.
*Bertazzi PA, Zocchetti C, Guercilena S, . 1997. Dioxin exposure and cancer risk: A 15-year mortality study after the “Seveso Accident”. Epidemiology 8:646–652.9345664
*Bertazzi PA, Zocchetti C, Pesatori AC, . 1989a. Mortality in an area contaminated by TCDD following an industrial incident. Med Lav 80:316–329.2593969
*Bertazzi PA, Zocchetti C, Pesatori AC, . 1989b. Ten-year mortality study of the population involved in the Seveso incident in 1976. Am J Epidemiol 129:1187–1200.2729256
*Bestervelt LL, Cai Y, Piper DW, . 1993. TCDD alters pituitary-adrenal function I: Adrenal responsiveness to exogenous ACTH. Neurotoxicol Teratol 15:365–370.8302236
Bestervelt LL, Nolan CJ, Cai Y, . 1991. Altered rat brain mu opiate receptor number after exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) [Abstract 1192]. The Toxicologist 11:08.
*Bestervelt LL, Pitt JA, Nolan CJ, . 1993. TCDD alters pituitary-adrenal function. II. Evidence for decreased bioactivity of ACTH. Neurotoxicol Teratol 15(6):371–376.8302237
*Beurskens JEM, Toussaint M, De Wolf J, . 1995. Dehalogenation of chlorinated dioxins by an anaerobic microbial consortium from sediment. Environmental Toxicology and Chemistry 14(6):939–943.
Beychok MR. 1987. A data base of dioxin and furan emissions from municipal refuse incinerators. Atmos Environ 21:29–36.
Bickel MH. 1982. Polychlorinated persistent compounds. Experientia 38:879.6813132
Biddinger GR, Gloss SP. 1984. The importance of trophic transfer in the bioaccumulation of chemical contaminants in aquatic ecosystems. Res Rev 91:103–146.
*Bingham AG, Edmunds CJ, Graham BWL, . 1989. Determination of PCDDs and PCDFs in car exhaust. Chemosphere 19:669–673.
Birmingham B. 1990. Analysis of PCDD and PCDF patterns in soil samples: Use in the estimation of the risk of exposure. Chemosphere 20(7–9):807–814.
*Birmingham B, Thorpe B, Frank R, . 1989. Dietary intake of PCDD and PCDF from food in Ontario, Canada. Chemosphere 19:507–512.
*Birnbaum LS. 1985. The role of structure in the disposition of halogenated aromatic xenobiotics. Environ Health Perspect 61:11–20.2998745
Birnbaum LS. 1986. Distribution and excretion of 2,3,7,8-tetrachlorodibenzo-p-dioxin in cogenic strains of mice which differ at the Ah locus. Drug Metab Dispos 14:34–40.2868862
*Birnbaum LS. 1994a. The mechanism of dioxin toxicity: Relationship to risk assessment. Environ Health Perspect 102:157–167.
*Birnbaum LS. 1994b. Evidence for the role of the Ah receptor in response to dioxin. In: Receptor-mediated biological process: Implications for evaluating carcinogenesis, 139–154.
*Birnbaum LS, Couture LA. 1988. Disposition of octachlorodibenzo-p-dioxin (OCDD) in male rats. Toxicol Appl Pharmacol. 93:22–30.3353999
*Birnbaum LS, Couture LA, Elwell MR. 1989. Subchronic effects of exposure to octachlorodibenzodioxin (OCDD). Chemosphere 18:389–390.
*Birnbaum LS, Harris MW, Miller CP, . 1986. Synergistic interaction of 2,3,7,8-tetrachlorodibenzo-p-dioxin and hydrocortisone in the induction of cleft palate in mice. Teratol 33:29–35.
*Birnbaum LS, Harris MW, Stocking LM, . 1989. Retinoic acid and 2,3,7,8-tetrachlorodibenzo-p-dioxin selectively enhance teratogenesis in C57BL/6N mice. Toxicol Appl Pharmacol 98:487–500.2718176
*Birnbaum LS, McDonald MM, Blair PC, . 1990. Differential toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in C57Bl/6J mice congenic at the Ah locus. Fundam Appl Toxicol 15:186–197.2373298
*Birnbaum LS, Weber H, Harris MW, . 1985. Toxic interaction of specific polychlorinated biphenyls and 2,3,7,8-tetrachlorodibenzo-p-dioxin: Increased incidence of cleft palate in mice. Toxicol Appl Pharmacol 77:292–302.3919463
*Bisanti L, Bonetti F, Caramaschi F, . 1980. Experiences from the accident of Seveso. Acta Morphologica Acad Sci Hung 28:139–157.
Bishop CM, Jones AH. 1981. Non-Hodgkin’s lymphoma of the scalp in workers exposed to dioxins. Lancet 2:369.
*Bjerke DL, Brown TJ, MacLusky NJ, . 1994b. Partial demasculinization and feminization of sex behavior in male rats by in utero and lactational exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin is not associated with alterations in estrogen receptor binding or volumes of sexually differentiated brain nuclei. Toxicol Appl Pharmacol 127:258–267.8048069
*Bjerke DL, Peterson RE. 1994. Reproductive toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin in male rats: different effects of in utero versus lactational exposure. Toxicol Appl Pharmacol 127:241–249.8048067
*Bjerke DL,Sommer RJ, Moore RW . 1994a. Effects of in utero and lactational 2,3,7,8-tetrachlorodibenzo-p-dioxin exposure on responsiveness of the male rat reproductive system to testosterone stimulation in adulthood. Toxicol Appl Pharmacol 127:250–257.8048068
*Blank JA, Tucker AN, Sweatlock J, . 1987. Naphthoflavone antagonism of 2,3,7,8-tetrachlorodibenzo-p-dioxin-induced murine lymphocyte ethoxyresorufin-O-deethylase activity and immunosuppression. Mol Pharmacol 32:168–172.
*Blankenship AL, Suffia MC, Matsumura F, . 1993. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCCD) accelerated differentiation of murine preimplantation embryos in vitro. Reprod Toxicol 7(3):255–261.8318757
*Blaylock BL, Holladay SD, Comment CE, . 1992. Exposure to tetrachlorodibenzo-p-dioxin (TCDD) alters fetal thymocyte maturation. Toxicol Appl Pharmacol 112:207–213.1531708
*Bobbie BA, Clement RE, Taguchi VY. 1989. Determination of chlorinated dibenzo-p-dioxins (CDD) and dibenzofurans (CDF) in environmental samples by tandem mass spectrometry. Chemosphere 18:155–162.
*Bobet E, Berard MF, Dann T. 1990. The measurement of PCDD and PCDF in ambient air in southwestern Ontario. Chemosphere 20(10–12):1439–1445.
*Bock KW. 1991. Roles of UDP-glucuronyltransferases in chemical carcinogenesis. Crit Rev Biochem Mol Biol 26:129–150.1914494
Bogen G. 1979. Symptoms of Vietnam veterans exposed to Agent Orange. JAMA 242:2391.
*Bombick DW, Jankun J, Tullis K, . 1988. 2,3,7,8-Tetrachlorodibenzo-p-dioxin causes increases in expression of c-erb-A and levels of protein-tyrosine kinases in selected tissues of responsive mouse strains. Proc Natl Acad Sci 85:4128–4132.3380784
Bombick DW, Matsumura F. 1987. TCDD (2,3,7,8-tetrachlorodibenzo-p-dioxin) causes an increase in protein tryosine kinase activities at an early stage of poisoning in vivo in rat hepatocyte membranes. Life Sci 41:429–436.3600186
Bonaccorsi A, Fanelli R, Tognoni G. 1978. In the wake of Seveso. Ambio 7:234–239.
*Bond GG, McLaren EA, Brenner FE, . 1989a. Incidence of chloracne among chemical workers potentially exposed to chlorinated dioxins. J Occup Med 31:771–774.2529357
*Bond GG, McLaren EA, Lipps TE, . 1989b. Update of mortality among chemical workers with potential exposure to the higher chlorinated dioxins. J Occup Med 31:121–123.2709162
*Bond GG, Ott MG, Brenner FE, . 1983. Medical and morbidity surveillance findings among employees potentially exposed to TCDD. Br J Ind Med 40:318–324.6871121
Bookstaff RC, Kamel F, Moore RW, . 1990b. Altered regulation of pituitary gonadotropin-releasing hormone (GnRH) receptor number and pituitary responsiveness to GnRH in 2,3,7,8-tetrachlorodibenzo-p-dioxin-treated male rats. Toxicol Appl Pharmacol 105:78–92.2168101
*Bookstaff RC, Moore RW, Peterson RE. 1990a. 2,3,7,8-Tetrachlorodibenzo-p-dioxin increases the potency of androgens and estrogens as feedback inhibitors of luteinizing hormone secretion in male rats. Toxicol Appl Pharmacol 104:212–224.2363174
*Bopp RF, Gross ML, Tong H, . 1991. A major incident of dioxin contamination: Sediments of New Jersey Estuaries. Environ Sci Technol 25:951–956.
Botre C, Memoli A, Alhaigue F. 1978. TCDD solubilization and photodecomposition in aqueous solutions. Environ Sci Tech 124:335.
Boule P, Hutzinger O. 1987. Photoreactivity of dibenzo-para-dioxins - can chlorodibenzo-para-dioxins be nitrated in the environment. Toxicol Environ Chem 13:229–256.
*Bovey RW. 1980. Uses of phenoxy herbicides and their methods of application. In: Bovey RW, Young AL, eds. The science of 2,4,5-T and associated phenoxy herbicides. New York, NY: John Wiley and Sons, Inc., 49–69.
Bowes GW, Simoneit BR, Burlingame AL, . 1973. The search for chlorinated dibenzofurans and chlorinated dibenzodioxins in wildlife populations showing elevated levels of embryonic death. Environ Health Perspect 5:191–198.4201766
*Bowman RE, Schantz SL, Gross ML, . 1989a. Behavioral effects in monkeys exposed to 2,3,7,8-TCDD transmitted maternally during gestation and for four months of nursing. Chemosphere 18:235–242.
*Bowman RE, Schantz SL, Weerasinghe NCA, . 1989b. Chronic dietary intake of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) at 5 or 25 parts per trillion in the monkey: TCDD kinetics and dose-effect estimate of reproductive toxicity. Chemosphere 18:243–252.
*Bowman RE, Tong HY, Gross ML, . 1990. Controlled exposure of female Rhesus monkeys to 2,3,7,8,-TCDD: concentrations of TCDD in fat of offspring, and its decline over time. Chemosphere 20:1199–1202.
*Boyd JA, Clark GC, Walmer DK, . 1995. Endometriosis and the environment biomarkers of toxin exposure. Abstract of Endometriosis 2000 Workshop, May 15–17.
Bradlaw JA, Casterline JL Jr. 1979. Induction of enzyme activity in cell culture: A rapid screen for detection of planar polychlorinated organic compounds. J Assoc Off Anal Chem 62:904–916.115836
Bradlaw JA, Garthoff LH, Hurley NE, . 1980. Comparative induction of aryl hydrocarbon hydroxylase activity in vitro by analogs of dibenzo-p-dioxin. Food Cosmet Toxicol 18:627–635.7203309
*Branson D, Takahashi T, Parker W, . 1985. Bioconcentration kinetics of 2,3,7,8-tetrachlorodibenzo-p-dioxin in rainbow trout. Environ Toxicol Chem 4:779–788.
Brenner KS. 1986. Pu-foam-plug technique and extractive co-distillation (Bleidner apparatus), versatile tools for stack emission sampling and sample preparation. Chemosphere 15:1917–1922.
*Brewster DW, Matsumura F. 1988. Reduction of adipose tissue lipoprotein lipase activity as a result of in vivo administration of 2,3,7,8-tetrachlorodibenzo-p-dioxin to the guinea pig. Biochem Pharmacol 37:2247–2253.3288212
*Brewster DW, Matsumura F, Akera T. 1987. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin on guinea pig heart muscle. Toxicol Appl Pharmacol 89:408–417.3603569
Bridle TR, Afghan BK, Wilkinson RJ, . 1984. The formation and fate of PCDDs and PCDFs during chlorophenol combustion. Proc - APCA Annu Meet 77:1–15.
Broman D, Naef C, Zebuehr Y, . 1989. The composition, distribution, and flux of PCDDs and PCDFs in settling particulate matter (SPM): A sediment trap study in the northern Baltic. Chemosphere 19:445–450.
*Bronzetti G, Bauer C, Corsi C, . 1983. Mutagenicity study of TCDD and ashes from urban incinerator in vitro and in vivo using yeast D7 strain. Chemosphere 12:549–553.
Brooks GT. 1980. Perspectives on the chemical fate and toxicity of pesticides. J Environ Sci Health B 15:755–793.7002989
*Brown NM, Lamartiniere CA. 1995. Xenoestrogens alter mammary gland differentiation and cell proliferation in the rat. Environ Health Perspect 103:708–713.7588483
*Brown NM, Manzolillo PA, Zhang J-X, . 1998. Prenatal TCDD and predisposition to mammary cancer in the rat. Carcinogenesis 19:1623–1629.9771934
*Brown RP, Cooper KR, Cristini A. 1994. Polychlorinated dibenzo-p-dioxins and dibenzofurans in Mya Arenaria in the Newark/Raritan Bay Estuary. Environ Toxicol Chem 13(3):523–528.
Brown RS, Pettit K, Jones PW. 1989. A GC/GC-MS study of 2,3,7,8-TCDD using a DB-225 column and selected decomposition monitoring a quantitative tool. Chemosphere 19:171–176.
Brownlee LJ, Evans CH, Hollebone BR. 1986. The relative induction of mixed-function oxidase specific activity to carbon-hydrogen and carbon-carbon 1 bond strengths in polychlorinated derivatives of dibenzo-p-dioxin. J Appl Toxicol 6:67–72.3754268
*Brugge JS, Yonemoto W, Darrow D. 1983. Interaction between Rous Sarcoma virus transforming protein and two cellular phosphoproteins: Analysis of the turnover and distribution of this complex. Mol Cell Biol 3: 9–19.6298609
*Bruggeman WA, Opperhuizen A, Wijbenga A, . 1984. Bioaccumulation of super-lipophilic chemicals in fish. Toxicol Environ Chem 7:173–189.
Bryant CJ, Hartle RW, Crandall MS, . 1989. Polychlorinated biphenyl, polychlorinated dibenzo-p-dioxin, and polychlorinated dibenzofuran contamination in PCB disposal facilities. Chemosphere 18:569–576.
Buchert H, Ballschmiter K. 1986. Polychlorodibenzofurans (PCDF) and dioxins (PCDD) as part of the general pollution in environmental samples of urban areas. Chemosphere 15:1923–1926.
Buck M, Kirschmer P. 1988. Concentrations of polychlorinated dibenzo-p-dioxins and dibenzofurans in outdoor air of North-Rhine, Westphalia, Germany. Toxicol Environ Chem 16:173–202.
*Bueno de Mesquita HB, Doornbos G, van der Kuip DAM, . 1993. Occupational exposure to phenoxy herbicides and chlorophenols and cancer mortality in the Netherlands. Am J Industr Med 23:289–300.
*Bumb RR, Crummett WB, Cutie SS, . 1980. Trace chemistries of fire: A source of chlorinated dioxins. Science 210:385–390.6159682
*Bumpus JA, Tien M, Wright D, . 1985. Oxidation of persistent environmental pollutants by a white rot fungus. Science 228:1434–1436.3925550
Burbach KM, Poland A, Bradfield CA. 1992. Cloning of the Ah-receptor cDNA reveals a novel ligand-activated transcription factor. Proc Natl Acad Sci USA 89:8185–8189.1325649
Bureau of Water Protection. 1988. Final 880607 groundwater contaminant cleanup target concentrations, final 880606 table of chemical references (WQ). Bureau of Water Protection, 6/6/88.
Burkhard LP, Kuehl DW. 1986. N-octanol/water partition coefficients by reverse phase liquid chromatography/mass spectrometry for eight tetrachlorinated planar molecules. Chemosphere 15:163–167.
*Burleson GR, Lebrec H, Yang YG, . 1996. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on influenza virus host resistance in mice. Fund Appl Toxicol 29:40–47.
*Burton JE, Michalek JE, Rahe AJ. 1998. Serum dioxin, chloracne, and acne in veterans of Operation Ranch Hand. Arch Environ Health 53:199–204.9814716
Buser HR. 1975. Polychlorinated dibenzo-p-dioxins: Separation and identification of isomers by gas chromatography-mass spectrometry. J Chromatogr 114:95–108.1184711
Buser HR. 1979. Formation and identification of tetra- and pentachlorodibenzo-p-dioxins from photolysis of two isomeric hexachlorodibenzo-p-dioxins. Chemosphere 4:251–257.
*Buser HR. 1987. Brominated and brominated/chlorinated dibenzodioxins and dibenzofurans: Potential environmental contaminants. Chemosphere 16:713–732.
Buser HR. 1988. Rapid photolytic decomposition of brominated and brominated/chlorinated dibenzodioxins and dibenzofurans. Chemosphere 17:889–903.
Buser HR, Bosshardt HP. 1976. Determination of polychlorinated dibenzo-p-dioxins and dibenzofurans in commercial pentachlorophenols by combined gas chromatography-mass spectrometry. J Assoc Off Anal Chem 59:562–569.1270382
Buser HR, Rappe C. 1978. Identification of substitution patterns in polychlorinated dibenzo-p-dioxins (PCDDs) by mass spectrometry. Chemosphere 7:199–211.
Buser HR, Rappe C. 1980. High-resolution gas chromatography of the 22 tetrachlorodibenzo-p-dioxin isomers. Anal Chem 52:2257–2262.7457886
Buser HR, Rappe C. 1984. Isomer-specific separation of 2,3,7,8-substituted polychlorinated dibenzo-p-dioxins by high-resolution gas chromatography/mass spectrometry. Anal Chem 56:442–448.
*Buser HR, Rappe C, Bergqvist P. 1985. Analysis of polychlorinated dibenzofurans, dioxins, and related compounds in environmental samples. Environ Health Perspect 60:293–302.3928355
Buu-Hoi NP, Pham-Huu-Chanh, Sesque G, . 1972. [Organs as targets of dioxin (2,3,7,8-tetrachloro-dibenzo-p-dioxin) intoxication.] Naturwissenschaften 59:174–175. (German)5057571
*Bysshe SE. 1990. Bioconcentration factors in aquatic organisms. In: Lyman WJ, Reehl WF, Rosenblatt DF, eds. Handbook of chemical properties estimation methods. Environmental behavior of organic compounds. Washington, DC: American Chemical Society, 5-1 to 5-30.
*Cai Z, Giblin DE, Ramanujam VMS, . 1994. Mass profile monitoring in trace analysis: Identification of polychlorodibenzothiophenes in crab tissue collected from the Newark/Raritan Bay system. Environ Sci Technol 28(8):1535–1538.22165940
*Calvert GM, Hornung RW, Sweeney MH, . 1992. Hepatic and gastrointestinal effects in an occupational cohort exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Am Med Assoc 267:2209–2214.
*Calvert GM, Sweeney MH, Morris JA, . 1991. Evaluation of chronic bronchitis, chronic obstructive pulmonary disease, and ventilatory function among workers exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Am Rev Resp Dis 144:1302–1306.1741543
*Calvert GM, Wall DK, Sweeney MH, . 1998. Evaluation of cardiovascular outcomes among U.S. workers exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Environ Health Perspect 106 (Suppl 2):635–643.9599711
*Calvert GM, Wille KK, Sweeney MH, . 1996. Evaluation of serum lipid concentrations among U.S. workers exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Arch Environ Health 51:100–107.8638959
*Cambridge Isotope Laboratories. 1995. Environmental Contaminant Standards. Andover, Massachusetts.
Campbell AD, Firestone D, Westly B. 1971. Chick edema factor--toxic dioxins. In: Westley B, ed. International Symposium on identification and measurement of environmental pollutants, Ottawa, Ontario, Canada, June 14-17, 1971. Ottawa, Canada: The Symposium, 105–108.
*Canga L, Levi R, Rifkind AB. 1988. Heart as a target organ in 2,3,7,8-tetrachlorodibenzo-p-dioxin toxicity: Decreased β-adrenergic responsiveness and evidence of increased intracellular calcium. Proc Natl Acad Sci USA 85:905–909.2829210
*Cantoni L, Salmona M, Rizzardini M. 1981. Porphyrogenic effect of chronic treatment with 2,3,7,8-tetrachlorodibenzo-p-dioxin in female rats. Dose-effect relationship following urinary excretion of porphyrins. Toxicol Appl Pharmacol 57:156–163 7222031
Cantor DS, Holder G, Cantor W, . 1994. In utero and postnatal exposure to 2,3,7,8-TCDD in Times Beach, Missouri: 2. Impact on neurophysiological functioning. (unpublished literature)
*Cantor KP. 1982. Farming and mortality from non-Hodgkin’s lymphoma: A case-control study. Int J Cancer 29:239–247.7040259
*Caputo R, Monti M, Ermacora E, . 1988. Cutaneous mainfestations of tetrachlorodebenzo-p-dioxin in children and adolescents: Follow-up 10 years after the Seveso, Italy, accident. J Am Acad Dermatol 19:812–819.2973475
*Caramaschi F, Del Corno G, Favaretti C, . 1981. Chloracne following environmental contamination by TCDD in Seveso, Italy. Int J Epidemiol 10:135–143.6457009
*Carrier G, Brunet RC, Brodeur J. 1995a. Modeling of the toxicokinetics of polychlorinated dibenzo-p-dioxins and dibenzofurans in mammalians, including humans. I. Nonlinear distribution of PCDD/PCDF body burden between liver and adipose tissues. Toxicol Appl Pharmacol 131:253–266.7716767
*Carrier G, Brunet RC, Brodeur J. 1995b. Modeling of the toxicokinetics of polychlorinated dibenzo-p-dioxins and dibenzofurans in mammalians, including humans. II. Kinetics of absorption and disposition of PCDDs/PCDFs. Toxicol Appl Pharmacol 131:267–276.7716768
Carsch S, Thoma H, Hutzinger O. 1986. Leaching of polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans from municipal waste incinerator fly ash by water and organic solvents. Chemosphere 15:1927–1930.
Carter CD, Kimbrough RD, Liddled JA, . 1975. Tetrachlorodibenzodioxin: An accidental poisoning episode in horse arenas. Science 188:738–740.1168366
*Carver LA, Hogenesch JB, Bradfield CA. 1994. Tissue specific expression of the rat Ah receptor and ARNT mRNAs. Nuc Acids Res 22:3038–3044.
Cavallaro A, Bandi G, Invernizzi G, . 1982. Negative ion chemical ionization MS as a structure tool in the determination of small amounts of PCDD and PCDF. Pergamon Ser Environ Sci 5:55–65.
CDC. 1986. Centers for Disease Control statement on breastfeeding. Centers for Disease Control. Vet Hum Toxicol 28:582–583.
*CDC. 1987. Comparison of serum levels of 2,3,7,8-TCDD with indirect estimates of Agent Orange exposure in Vietnam veterans: Final Report Agent Orange Projects. Atlanta, Ga: Centers for Disease Control, Public Health Service, U.S. Department of Health and Human Services.
*CDC. 1988. Serum 2,3,7,8-tetrachlorodibenzo-p-dioxin levels in US Army Vietnam-era veterans. Centers for Disease Control. JAMA 260:1249–1254.2841506
*CELDS. 1994. Computer-environmental legislative data systems database. University of Illinois, Urbana, IL.
*Cerlisi S, DiDomenico A, Ratti S. 1989. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD) persistence in the Seveso (Milan, Italy) soil. Toxicol Environ Safe 18:149–164.
*Chaffin CL, Peterson RE, Hutz RJ. 1996. In utero and lactational exposure of female Holtzman rats to 2,3,7,8-tetrachlorodibenzo-p-dioxin: Modulation of the estrogen signal. Biol Reprod 55:62–67.8793059
*Chaffin CL, Trewin AL, Watanabe G, . 1997. Alterations to the pituitary-gonadal axis in the peripubertal female rat exposed in utero and through lactation to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Biol Reprod 56:1498–1502.9166703
*Chahoud I, Krowke R, Schimmel A. 1989. Reproductive toxicity and pharmacokinetics of 2,3,7,8-tetrachlorodibenzo-p-dioxin: 1. Effects of high doses on the fertility of male rats. Arch Toxicol 63:432–439.2619556
*Chang RR, Jarman WM, Hennings JA. 1993. Sample cleanup by solid phase extraction for the ultratrace determination of polychlorinated dibenzo-p-dioxins and dibenzofurans in biological samples. Anal Chem 65(18):2420–2427.8238936
Chang RR, Jarman WM, King CC, . 1990. Bioaccumulation of PCDDs and PCDFs in food animals: III. A rapid cleanup of biological materials using reverse phase adsorbent columns. Chemosphere 20:881–886.
*Chemical Regulation Reporter. 1997. (7/25/97), page 455.
*Chemical Regulation Reporter. 1997. (8/22/97), page 533.
*Chen H-S, Perdew G. 1994. Subunit composition of the heteromeric cytosolic aryl hydrocarbon receptor complex. J Biol Chem 269: 27554–27558.7961671
Chittim BG, Bunce NJ, HU K, . 1994. Comparison of GC-MS with an in vitro bioassy for PCDDs and related compounds in environmental samples. Chemospere 29(9–11):1783–1788.
Chiu C, Halman R, Lanoy M, . 1987. Refined analytical procedures to detect and measure PCDD/PCDF, PAH, PCB, CB, and CP in environmental samples. Chemosphere 16:1619–1624.
*Chiu C, Thomas RS, Lockwood J, . 1983. Polychlorinated hydrocarbons from power plants, wood burning, and municipal incinerators. Chemosphere 12:607–616.
*Choi EJ, Toscano DJ, Ryan JA, . 1991. Dioxin induces transforming growth factor-alpha in human keratinocytes. J Biol Chem 266:9591–5997.2033054
*Choudhry GG, Hutzinger O. 1982. Photochemical formation and degradation of polychlorinated dibenzofurans and dibenzo-p-dioxins. Residue Reviews 84:113–161.
Choudhry GG, Webster GRB. 1986. Photochemical quantum yields and sunlight half-lives of polychlorodibenzo-p-dioxins in aquatic systems. Chemosphere 15:1935–1940.
*Choudhry GG, Webster GRB. 1987. Quantum yields of polychlorodibenzo-p-dioxins in water-acetonitrile mixtures and their environmental phototransformation rates. In: Zika RG, Cooper WJ, eds. Photochemistry of environmental aquatic systems. Washington, DC: American Chemical Society, 327:61–74.
*Choudhry GG, Webster GRB. 1989. Environmental photochemistry of PCDDs: 2. Quantum yields of the direct phototransformation of 1,2,3,7-tetra-, 1,3,6,8-tetra-, 1,2,3,4,6,7,8-hepta-, and 1,2,3,4,6,7,8,9-octachlorodibenzo-p-dioxin in aqueous acetonitrile and their sunlight half-lives. J Agric Food Chem 37:254–261.
*Christian BJ, Inhorn SL, Peterson RE. 1986a. Relationship of the wasting syndrome to lethality in rats treated with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 82:239–255.3945951
*Christian BJ, Menahan LA, Peterson RE. 1986b. Intermediary metabolism of the mature rat following 2,3,7,8-tetrachlorodibenzo-p-dioxin treatment. Toxicol Appl Pharmacol 83:360–378.3961820
Christmann W, Kloeppel KD, Partscht H, . 1989a. Determination of PCDD/PCDF in ambient air. Chemosphere 19:521–526.
*Christmann W, Kloeppel KD, Partscht H, . 1989b. PCDD/PCDF and chlorinated phenols in wood preserving formulations for household use. Chemosphere 18:861–865.
Christmann W, Kloeppel KD, Partscht H, . 1989c. Tetrachlorobenzoquinones, a source of PCDD/PCDF. Chemosphere 18:789–792.
*Cirnies-Ross C, Stanmore B, Millar G. 1996. Dioxins in diesel exhaust. Nature 381:379.8632793
*Clark DA, Sweeney G, Safe S, . 1983. Cellular and genetic basis for suppression of cytotoxic T cell generation by haloaromatic hydrocarbons. Immunopharmacology 6:143–153.6309701
*Clark GC, Blank JA, Germolec DR, . 1991a. 2,3,7,8-Tetrachlorodibenzo-p-dioxin stimulation of tyrosine phosphorylation in B lymphocytes: potential role in immunosuppression. Mol Pharmacol 39:495–501.1850092
*Clark GC, Taylor MJ, Tritscher AM, . 1991b. Tumor necrosis factor involvement in 2,3,7,8-tetrachlorodibenzo-p-dioxin-mediated endotoxin hypersensitivity in C57BL/6 mice congenic at the Ah locus. Toxicol Appl Pharmacol 111:422–431.1660630
Clement RE. 1988. The analysis and environmental distribution of chlorinated dibenzo-p-dioxins and dibenzofurans [Abstract]. Abstracts of Papers of the American Chemical Society 195:199.
Clement RE, Bolelie B, Taguchi V. 1986. Comparison of instrumental methods for chlorinated dibenzo-p-dioxin (CDD) determination: Interim results of a round-robin study involving GC/MS, MS/MS and high resolution MS. Chemosphere 15:1147–1156.
Clement RE, Suter SA, Reiner E, . 1989a. Concentrations of chlorinated dibenzo-p-dioxins and dibenzofurans in effluents and centrifuged particles from Ontario pulp and paper mills. Chemosphere 19:649–954.
Clement RE, Tashiro C, Reiner E, . 1987a. Chlorinated dibenzofurans (CDFs) in effluents and sludges from pulp and paper mills. In: Proceedings of the Seventh International Symposium on Chlorinated Dioxins and Related Compounds. Las Vegas, NV: University of Nevada.
*Clement RE, Tashiro C, Suter S, . 1989b. Chlorinated dibenzo-p-dioxins (CDDs) and dibenzofurans (CDFs) in effluents and sludges from pulp and paper mills. Chemosphere 18:1189–1197.
Clement RE, Tosine HM. 1988. The gas-chromatography mass-spectrometry determination of chlorodibenzo-p-dioxins and dibenzofurans. Mass Spectrometry Reviews 7:593–636.
*Clement RE, Tosine HM, Ali B. 1985. Levels of polychlorinated dibenzo-p-dioxin and dibenzofuran in woodburning stoves, fireplaces. Chemosphere 14:815.
Clement RE, Tosine HM, Osborne J, . 1988. Gas chromatographic/mass spectrometric determination of chlorinated dibenzo-p-dioxin and dibenzofurans in incinerator stack emissions and fly-ash: A 13-test study. Biomed Environ Mass Spectrom 17:81–96.
Clement RE, Tosine HM, Taguchi V, . 1987b. Investigation of American lobster, Homarus-Americanus, for the presence of chlorinated dibenzo-para-dioxins and dibenzofurans. Bull Environ Contam Toxicol 39:1069–1075.3440145
*Clewell HJ III, Andersen M. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1:111–113.3843496
*Cohen GM, Bracken WM, Iyer RP, . 1979. Anticarcinogenic effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin on benzo(a)pyrene and 7,12-dimethylbenz(a)anthracene tumor initiation and its relationship to DNA binding. Cancer Res 39:4027–4033.113085
Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56:898–908.
*Conacher HBS, Page BD, Ryan JJ. 1993. Industrial chemical contamination of foods. Food Additives and Contaminants 10(1):129–143.8504868
*Connett P, Webster T. 1987. An estimation of the relative human exposure to 2,3,7,8-TCDD emissions via inhalation and ingestion of cow’s milk. Chemosphere 16:2079–2084.
Conso F, Dally S, Cordier S, . 1986. Accidental human exposure to polychlorinated dibenzofurans and polychlorinated dioxins following a transformer fire. Chemosphere 15:1953–1955.
*Cook JC, Dold KM, Greenlee WF. 1987a. An in vitro model for studying the toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin to human thymus. Toxicol Appl Pharmacol 89:256–268.3037728
*Cook JC, Greenlee WF. 1989. Characterization of a specific binding protein for 2,3,7,8-tetrachlorodibenzo-p-dioxin in human thymic epithelial cells. Mol Pharmacol 35:713–719.2542760
*Cook PM, Kuehl DW, Walker MK, . 1991. Bioaccumulation and toxicity of TCDD and related compounds in aquatic ecosystems. In: Gallo MA, Scheuplein JR, Van Der Heijden KA, eds. Banbury Report 35: Biological basis for risk assessment of dioxins and related compounds. Plainview, NY: Banbury Center Meeting Cold Spring Harbor Laboratory Press.
*Cook RR. 1981. Dioxin, chloracne and soft-tissue sarcoma. Lancet 1:681–619.6110912
*Cook RR, Bond GG, Olson RA, . 1986. Evaluation of the mortality experience of workers exposed to the chlorinated dioxins. Chemosphere 15:1769–1776.
*Cook RR, Bond GG, Olson RA, . 1987b. Update of the mortality experience of workers exposed to chlorinated dioxins. Chemosphere 16:2111–2116.
*Cooke M, Hatchel JA, Czuczwa JM, . 1988. Analytical and sampling techniques for the determination of ultratrace quantities of polychlorinated dibenzofurans and dibenzodioxins. In: Proceedings 1987 EPRI PCB Seminar, Kansas City, MO, October 6-9, 1987. Palo Alto, CA: Electric Power Research Institute, 7-1–7-8.
*Corbet RL, Muir D CG, Webster G RB. 1983. Fate of carbon-14 labelled 1,3,6,8-tetrachloro-dibenzo-p-dioxin in an outdoor aquatic system. Chemosphere 12 (4–5):523–528.
Corbet RL, Worobey BL, Webster GRB. 1981. Preliminary analysis and confirmation of the presence of polychlorinated dibenzo-p-dioxin (PCDD) and polychlorinated biphenyls (PCB) in lake sediment. In: Muir DC, ed. Sixteenth Annual Workshop on pesticide residue analysis and ninth annual workshop on the chemistry and biochemistry of herbicides, Winnepeg, Manitoba, Canada: Department of National Health and Welfare, Health Protection Branch, 111–116.
*Coumailleau P, Poellinger L, Gustafsson J-A, . 1995. Definition of a minimal domain of the dioxin receptor that is associated with hsp90 and maintains wild type ligand binding affinity and specificity. J Biol Chem 270: 25291–25300.7559670
*Courtney KD. 1976. Mouse teratology studies with chlorodibenzo-p-dioxins. Bull Environ Contam Toxicol 16:674–681.1016755
*Courtney KD, Putnam JP, Andrews JE. 1978. Metabolic studies with TCDD (dioxin) treated rats. Arch Environ Contam Toxicol 7:385–396.755441
*Couture LA, Abbott BD, Birnbaum LS. 1990. A critical review of the developmental toxicity and teratogenicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin: Recent advances toward understanding the mechanism. Teratol 42:619–627.
*Couture LA, Elwell MR, Birnbaum LS. 1988. Dioxin-like effects observed in male rats following exposure to octachlorodibenzo-p-dioxin (OCDD) during a 13-week study. Toxicol Appl Pharmacol 93:31–46.3354000
Couture-Haws L, Harris MW, McDonald MM, . 1991a. Evaluation of persistence of hydronephrosis induced in mice following in utero and/or lactational exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 107:402–412.2000631
*Couture-Haws L, Harris MW, McDonald MM, . 1991b. Hydronephrosis in mice exposed to TCDD-contaminated breast milk: Identification of the peak period of sensitivity and assessment of potential recovery. Toxicol Appl Pharmacol 107:413–428.2000632
*Cramer G, Bolder M, Henry S, . 1991. USFDA assessment of exposure to 2,3,7,8-TCDD and 2,3,7,8-TCDF from foods contacting bleached paper products. Chemosphere 23(8–10):1537–1550.
Cramer PH, Ayling RE, Thornburg KR, . 1990. Evaluation of an analytical method for the determination of polybrominated dibenzo-p-dioxins/dibenzofurans (PBDD/PBDF) in animal adipose. Chemosphere 20:821–828.
*Creaser CS, Al-Haddad A. 1989. Fractionation of polychlorinated biphenyls, polychlorinated dibenzo-p-dioxins, and polychlorinated dibenzofurans on porous graphitic carbon. Anal Chem 61:1300–1302.2502933
*CRITFC. 1994. A fish consumption survey of the Umatilla, Nez Perce, Yakama, and Warm Springs tribes of the Columbia River basin. Columbia River Inter-Tribal Fish Commission. CRITFC technical report no. 94-3.
*Crosby DG, Moilanen KW, Wong AS. 1973. Environmental generation and degradation of dibenzodioxins and dibenzofurans. Environ Health Perspect 5:259–266.4752908
*Crosby DG, Wong AS. 1976. Photochemical generation of chlorinated dioxins. Chemosphere 5:327–332.
*Crow KD. 1978. Chloracne - an up to date assessment. Ann Occup Hyg 21:297–298.155998
Crummett WB. 1982. Environmental chlorinated dioxins from combustion - the trace chemistries of fire hypothesis. Pergamon Ser Environ Sci 5:253–263.
*Crunkilton RL, Smith LM, Petty JD, . 1987. Residues of 2,3,7,8-tetrachlorodibenzo-p-dioxin in the Spring River, Missouri. Water Air Soil Pollut 32:219–231.
Cuiu C, Halman R, Li K, . 1986. Analytical procedures to assay environmental samples for PCDD/PCDF, PAH, PCB, chlorobenzenes (CB) and chlorophenols (CP). Chemosphere 15:1091–1098.
Cull MR, Dobbs AJ, Goudot M, . 1984. Polychlorodibenzo-p-dioxins and dibenzofurans in technical pentachlorophenol - results of a collaborative analytical exercise. Chemosphere 13:1157–1165.
Cull MR, Dobbs AJ, Williams N. 1983. Polychlorinated dibenzo-p-dioxins (PCDDs) in commercial pentachlorophenol (PCP) used in wood preservation. Chemosphere 12:483–485.
*Cummings AM, Metcalf JL, Birnbaum L. 1996. Promotion of endometriosis by 2,3,7,8-tetrachloro-dibenzo-p-dioxin in rats and mice: Time-dose dependence and species comparison. Toxicol Appl Pharmacol 138:131–139.8658502
*Curtis LR, Kerkvliet NI, Baecher-Steppan L, . 1990. 2,3,7,8-Tetrachlorodibenzo-p-dioxin pretreatment of female mice altered tissue distribution but not hepatic metabolism of a subsequent dose. Fundam Appl Toxicol 14:523–531.2340981
Czeizel E, Kiraly J. 1976. Chromosome examinations in workers producing Klorinal and Buminol. In: Banki L, ed. The development of a pesticide as a complex scientific task. Medicina, Budapest: 239–256.
*Czuczwa J, Katona V, Pitts G, . 1989. Analysis of fog samples for PCDD and PCDF. Chemosphere 18:847–850.
*Czuczwa JM, Hites RA. 1984. Environmental fate of combusion-generated polychlorinated dioxins and furans. Environ Sci Technol 18:444–450.22247947
*Czuczwa JM, Hites RA. 1986. Airborne dioxins and dibenzofurans: Sources and fates. Environmental Science and Technology 20:195–200.22288811
*Czuczwa JM, Hites RA. 1986a. Airborne dioxins and dibenzofurans: Sources and fates. Environ Sci Technol 20:195–200.22288811
*Czuczwa JM, Hites RA. 1986b. Sources and fates of PCDD and PCDF. Chemosphere 15:1417–1420.
*Dahl P, Lindstrom G, Wiberg K, . 1995. Absorption of polychlorinated biphenyls, dibenzo-p-dioxins and dibenzofurans by breast-fed infants. Chemosphere 30:2297–2306.7620852
*Dasenbrock C, Bittmann H, Creutzenberg O, . 1992. Cleft palate and liver weight data of two different mixtures of PCDDs in pregnant mice related to organ dosage. Chemosphere 25:1153–1157.
*Davidson MD and Fujimoto JM. 1987. Increased permeability of the rat biliary tree by 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) treatment and protection by hepatoactive agents. Toxicol Appl Pharmacol 87:57–66.2432693
Davies K. 1988. Concentrations and dietary intake of selected organochlorines, including PCB, PCDDs, and PCDFs in fresh food composites grown in Ontario, Canada. Chemosphere 17:263–276.
*Davis D, Safe S. 1989. Dose-response immunotoxicities of commercial polychlorinated biphenyls (PCBs) and their interaction with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Lett 48:35–43.2501913
*Davis D, Safe S. 1991. Halogenated aryl hydrocarbon-induced suppression of the in vitro plaque-forming cell response to sheep red blood cells is not dependent on the Ah receptor. Immunopharmacology 21:183–190.1655676
*De Heer C, Schuuman H-J, Vos JG, . 1994b. Lymphodepletion of the thymus cortex in rats after a single oral intubation of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Chemosphere 29:2295–2299.7850377
*De Heer C, Schuurman H-J, Liem AKD, . 1995. Toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) to the human thymus after implantation in SCID mice. Toxicol Appl Pharmacol 134:296–304.7570606
*De Heer C, Verlaan APJ, Penninks AH, . 1994a. Time course of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD)-induced thymic atrophy in the Wistar rat. Toxicol Appl Pharmacol 128:97–104.8079361
De Jong APJ, Liem AKD, Den Boer AC, . 1989. Analysis of polychlorinated dibenzofurans and dibenzo-p-dioxins in human milk by tandem hybrid mass spectrometry. Chemosphere 19:59–66.
*De Krey GK, Kerkvliet NI. 1995. Suppression of cytotoxic T lymphocyte activity by 2,3,7,8-tetrachloro-dibenzo-p-dioxin occurs in vivo, but not in vitro, and is independent of corticosterone elevation. Toxicology 97:105–112.7716775
*De Vault D, Dunn W, Bergqvist P, . 1989. Polychlorinated dibenzofurans and polychlorinated dibenzo-p-dioxins in Great Lakes fish: A baseline and interlake comparison. Environ Toxicol Chem 8:1013–1022.
*De Wall EJ, Schuurman H-J, Loeber JG, . 1992. Alterations in the cortical thymic epithelium of rats after in vivo exposure to 2,3,7,8-tetrachlorodibenxo-p-dioxin (TCDD): An (immuno)histological study. Toxicol Appl Pharmacol 115(1):80–88.1631898
*DeCaprio AP, McMartin DM, O’Keefe PW, . 1986. Subchronic oral toxicity of 2,3,7,8-tetrachloro-dibenzo-p-dioxin in the guinea pig: Comparisons with a PCB-containing transformer fluid pyrolysate. Fundam Appl Toxicol 6:454–463.3084328
*Della Porta G, Dragani TA, Sozzi G. 1987. Carcinogenic effects of infantile and long-term 2,3,7,8-tetrachlorodibenzo-p-dioxin treatment in the mouse. Tumori 73:99–107.3576718
*Dencker L, Hassoun E, D’Argy R, . 1985. Fetal thymus organ culture as an in vitro model for the toxicity of 2,3,7,8-TCDD and its congeners. Mol Pharmacol 27:133–140.3965925
Dencker L, Pratt RM. 1981. Association between the presence of the Ah receptor in embryonic murine tissues and sensitivity to TCDD-induced cleft palate. Teratogenesis Carcinog Mutagen 1:399–406.
Denison MS. 1991. Inactivation and dissociation of rat hepatic Ah receptor: evidence for distinct receptor forms? [Abstract 989]. The Toxicologist 11:260.
*Denison MS, Fisher JM, Whitlock JP Jr. 1989. Protein-DNA interactions at recognition sites for the dioxin-Ah receptor complex. J Biol Chem 264:16478–16482.2550446
Denison MS, Vella LM. 1990. The hepatic Ah receptor for 2,3,7,8-tetrachlorodibenzo-p-dioxin: Species differences in subunit dissociation. Arch Biochem Biophys 277:382–388.2155580
Denison MS, Vella LM, Okey AB. 1986b. Structure and function of the Ah receptor for 2,3,7,8-tetrachlorodibenzo-p-dioxin: species difference in molecular properties of the receptors from mouse and rat hepatic cytosols. J Biol Chem 61:3987–3995.
*Denison MS, Wilkinson CF, Okey AB. 1986a. Ah receptor for 2,3,7,8-tetrachlorodibenzo-p-dioxin: Comparative studies in mammalian and nonmammalian species. Chemosphere 15:1665–1672.
*Denomme MA, Homonoko K, Fujita T, . 1985. Effects of substituents on the cytosolic receptor-binding affinities of aryl hydrocarbon hydroxylase induction potencies of 7-substituted 2,3-dichlorodibenzo-p-dioxins. Mol Pharmacol 27:656–661.2987660
Department of Health, New Zealand. 1980. Report to the Minister of Health of an investigation into allegations of an association between human congenital defects and 2,4,5-T spraying in and around teKuiti. New Zealand Med J 314–315.
DeRoos FL, Bicking MKL. 1990. Supercritical fluid extraction for the determination of PCDDs and PCDFs in soil. Chemosphere 20:1355–1362.
*Des Rosiers PE. 1986. Methodologies for materials contaminated with PCDDs and related compounds. Chemosphere 15:1513–1528.
*Des Rosiers PE. 1987. National dioxin study. ACS Sympos Ser 338:34–53.
Des Rosiers PE, Lee A. 1986. PCB fires: Correlation of chlorobenzene isomer and PCB homolog contents of PCB fluids with PCDD and PCDF contents of soot. Chemosphere 15:1313–1323.
Deutsch DG, Goldfarb TD. 1988. PCDD/PCDF contamination following a plastics fire in a university lecture hall building. Chemosphere 17:2423–2431.
*DeVito M, Thomas T, Meeker R, . 1991. The effects of TCDD on estrogen receptor levels in intact, ovariectomized and hypophysectomized mice [Abstract 995]. The Toxicologist 11:262.
*DeVito MJ, Birnbaum LS. 1995. The importance of pharmacokinetics in determining the relative potency of 2,3,7,8-tetrachlorodibenzo-p-dioxin and 2,3,7,8-tetrachlorodibenzofuran. Fund Appl Toxicol 24:145–148.
*DeVito MJ, Birnbaum LS, Farland WH, . 1995. Comparisons of estimated human body burdens of dioxin-like chemicals and TCDD body burdens in experimentally exposed animals. Environ Health Perspect 103:820–831.7498094
*DeVito MJ, Diliberto JJ, Ross DG, . 1997. Dose-response relationships for polyhalogenated dioxins and dibenzofurans following subchronic treatment in mice. I. CYP1A1 and CYP1A2 enzyme activity in liver, lung, and skin. Toxicol Appl Pharmacol 147:267–280.9439722
*DeVito MJ, Ma X, Babish JG, . 1994. Dose-response relationships in mice following subchronic exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin: CYP1A1, CYP1A2, estrogen receptor, and protein tyrosine phosphorylation. Toxicol Appl Pharmacol 124(1):82–90.8291065
DeVito MJ, Maier WE, Diliberto JJ, . 1993. Comparative ability of various PCBs, PCDFs, and TCDD to induced cytochrome P450 1A1 and 1A2 activity following 4 weeks of treatment. Fundam Appl Toxicol 20(1):125–130.8432423
*DeVito MJ, Thomas T, Martin E, . 1992. Antiestrogenic action of 2,3,7,8-tetrachlorodibenzo-p-dioxin: Tissue specific regulation of estrogen receptor in CD1 mice. Toxicol Appl Pharmacol 113(2):284–292.1561637
*Dewailly E, Bruneau S, Ayotte P, . 1993. Health status at birth of Inuit newborn prenatally exposed to organochlorines. Chemosphere 27:359–366.
*Dewailly E, Nantel A, Bruneau S, . 1992. Breast milk contamination of PCDDs, PCDFs and PCBs in Arctic Quebec: A preliminary assessment. Chemosphere 25(7–10):1245–1249.
*Dewailly E, Ryan J, Laliberte C, . 1994. Exposure of remote maritime populations to coplanar PCBs. Environ Health Perspectives S102(1):205–209.
*Dewailly E, Weber J-P, Gingras S, . 1991. Coplanar PCBs in human milk in the Province of Quebec, Canada: Are they more toxic than dioxin for breast fed infants? Bull Environ Contam Toxicol 47:491–498.1786431
*DiBartolomeis MJ, Moore RW, Peterson RE, . 1986. Hypercholesterolemia and the regulation of adrenal steroidogenesis in 2,3,7,8-tetrachlorodibenzo-p-dioxin-treated rats. Toxicol Appl Pharmacol 85:313–323.3764917
*DiBartolomeis MJ, Moore RW, Peterson RE, . 1987. Altered regulation of adrenal steroidogenesis in 2,3,7,8-tetrachlorodibenzo-p-dioxin-treated rats. Biochem Pharmacol 36:59–67.3026405
Dickson LC, Hutzinger M, Karasek F, . 1986. Determination of desorption losses of polychlorinated dibenzo-p-dioxins from municipal incinerator fly ash by gas chromatography/mass spectrometry. Int J Environ Anal Chem 2:55–74.
Dickson LC, Karasek FW. 1987. Mechanism of formation of polychlorinated dibenzo-p-dioxins produced on municipal incinerator fly ash from reactions of chlorinated phenols. J Chromatogr 389:127–137.3571349
*DiGiovanni J, Viaje A, Berry DL, . 1977. Tumor-initiating ability of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) and Arochlor 1254 in the two-stage system of mouse skin carcinogenesis. Bull Environ Contam Toxicol 18:552–556.412534
DiLernia R, Crimaudo C, Pacchetti G. 1982. The study of X-rays and TCDD effects on satellite associations may suggest a simple model for application in environmental mutagenesis. Hum Genet 61:42–47.7129425
*Diliberto JJ, Akubue PI, Luebke RW, . 1995. Dose-response relationships of tissue distribution and induction of CYP1A1 and CYP1A2 enzymatic activities following acute exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in mice. Toxicol Appl Pharmacol 130:197–208.7871533
*Diliberto JJ, Burgin D, Birnbaum LS. 1997. Role of CYP1A2 in hepatic sequestration of dioxin: Studies using CYP1A2 knock-out mice. Biochem Biophys Res Commun 236:431–433.9240455
*Diliberto JJ, Jackson JA, Birnbaum LS. 1996. Comparison of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) disposition following pulmonary, oral, dermal and parenteral exposures to rats. Toxicol Appl Pharmacol. 138:158–168.8658505
*Dimich-Ward H, Hertzman C, Teschke K, . 1996. Reproductive effects of paternal exposure to chlorophenate wood preservatives in the sawmill industry. Scand J Work Environ Health 22:267–273.8881015
Djien Liem AK, Van Zorge JA. 1995. Dioxins and related compounds: Status and regulatory aspects. Environmental Science and Pollution Research International 2(1):46–56.24234472
Dobbs AJ, Cull MR. 1982. Volatilization of chemicals - relative loss rates and the estimation of vapor pressures. Environ Pollut Ser [B] 3:289–298.
*Dobbs AJ, Grant C. 1979. Photolysis of highly chlorinated dibenzo-p-dioxins by sunlight. Nature 278:163–165.
Dobbs AJ, Grant C. 1981. Octachlorodibenzo-p-dioxin in wood treatment materials and treated wood. Chemosphere 10:1185–1193.
*Dolwick KM, Schmidt JV, Carver LA, . 1993. Cloning and expression of a human Ah receptor cDNA. Mol Pharmacol 44:911–917.8246913
*Donnelly JR, Vonnahme TL, Hedin CM, . 1986. Evaluation of RCRA method 8280 for analysis of dioxins and dibenzofurans. In: Rappe C, Choudhary G, Keith LH, eds. Chlorinated dioxins and dibenzofurans in perspective. Chelsea, MI: Lewis Publishers, Inc., 399–435.
*Dooley RK, Morris DL, Holsapple MP. 1990. Elucidation of cellular targets responsible for tetrachlorodibenzo-p-dioxin (TCDD)-induced suppression of antibody responses: II. Role of the T lymphocyte. Immunopharmacology 19:47–58.2307581
DOT. 1989b. List of hazardous substance and reportable quantities. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101.
Doucette WJ, Andren AW. 1987. Correlation of octanol/water partition coefficients and total molecular surface area for highly hydrophobic aromatic compounds. Environ Sci Technol 21:821–824.19995068
*Doucette WJ, Andren AW. 1988. Aqueous solubility of selected biphenyl, furan and dioxin congeners. Chemosphere 17:243–252.
*Dougherty EJ, McPeters AL, Overcash MR, . 1993. Theoretical analysis of a method for in situ decontamination of soil contaning 2,3,7,8-tetrachlorodibenzo-p-dioxin. Environ Sci Technol 27(3):505–515.
DOW Chemical Company. 1978. Assessment of risk and toxicological data. EPA/OTS public files document number 8EHQ-0778-0209.
*Dragan YP, Xu X, Goldsworthy TL, . 1992. Characterization of the promotion of altered hepatic foci by 2,3,7,8-tetrachlorodibenzo-p-dioxin in the female rat. Carcinogenesis (London) 13(8):1389–1395.1354083
*Duarte-Davidson R, Harrad SJ, Allen SC, . 1992. The relative contribution of individual PCBs, PCDDs, and PCDFs to toxic equivalent values derived from bulked human breast milk samples from the UK. Chemosphere 25:1653–1663.
Dulin D, Drossman H, Mill T. 1986. Products and quantum yields for photolysis of chloroaromatics in water. Environ Sci Technol 20:72–77.22300154
*Durrin LK, Whitlock JP Jr. 1989. 2,3,7,8-Tetrachlorodibenzo-p-dioxin: Ah receptor-mediated change in cytochrome P-450 chromatin structure occurs independent of transcription. Mol Cell Biol 9:5733–5737.2573837
*Eadon G, Kaminsky L, Silkworth J, . 1986. Calculation of 2,3,7,8-equivalent concentrations of complex environmental contaminant mixtures. Environ Health Perspect 70:221–227.3830107
*Ebert E, Price P, Keenan R. 1996. Estimating exposures to dioxin-like compounds for subsistence anglers in North American. In: Human exposure, human health risk assessment, and organohalogen compounds, 16th Symposium on Chlorinated Dioxins and Related Compounds, Amsterdam Holland, volume 30, 66–69.
*ECETOC. 1992. Exposure of man to dioxins: A perspective on industrial waste incineration. European Centre for Ecotoxicology and Toxicology of Chemicals. Tech Rep - ECETOC 49:1–88.
Edgerton SA, Czuczwa JM, Rench JD, . 1988. Determination of polychlorinated dibenzo-p-dioxins and dibenzofurans and associated health risks in ambient air in Ohio. Proc APCA Annu Meet 81:16.
*Edgerton SA, Czuczwa JM, Rench JD, . 1989. Ambient air concentrations of polychlorinated dibenzo-p-dioxins and dibenzofurans in Ohio: Sources and health risk assessment. Chemosphere 18:1713–1730.
*Eduljee GH. 1987. Volatility of TCDD and PCB from soil. Chemosphere 16:907–920.
Edwards BH, Paullin JN, Coghlan-Jordan K. 1985. Emerging technologies for the control of hazardous wastes. J Hazard Mater 12:201–205.
*Egeland GM, Sweeney MG, Fingerhut MA, . 1994. Total serum testosterone and gonadotropins in workers exposed to dioxins. Am J Epidemiol 139:272–281.8116602
*Ehrlich R, Wenning RJ, Johnson GW, . 1994. A mixing model for polychlorinated dibenzo-p-dioxins and dibenzofurans in surface sediment from Newark Bay, New Jersey, using polytopic vector analysis. Arch Environ Contam Toxicol 27(4):486–500.
Eiceman GA, Clement RE, Karasek FW. 1979. Analysis of fly ash from municipal incinerators for trace organic compounds. Anal Chem 51:2343–2350.
Eiceman GA, Clement RE, Karasek FW. 1981. Variations in concentrations of organic compounds including PCDDs and polynuclear aromatic hydrocarbons in fly ash from a municipal incinerator. Anal Chem 53:955–959.
*Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38.
*Eitzer BD. 1993. Comparison of point and nonpoint sources of polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans to sediments of the Housatonic River. Environ Sci Technol 27(8):1632–1637.
Eitzer BD, Hites RA. 1986. Concentrations of dioxins and dibenzofurans in the atmosphere. Int J Environ Anal Chem 2:215–229.
Eitzer BD, Hites RA. 1988. Vapor pressures of chlorinated dioxins and dibenzofurans. Environ Sci Technol 22:1362–1364.
Eitzer BD, Hites RA. 1989a. Dioxins and furans in the ambient atmosphere: A baseline study. Chemosphere 18:593–598.
*Eitzer BD, Hites RA. 1989b. Polychlorinated dibenzo-p-dioxins and dibenzofurans in the ambient atmosphere of Bloomington, Indiana. Environ Sci Technol 23:1389–1395.
Eklund G, Pedersen JR, Stromberg B. 1986. Phenol and HCl at 550 degrees yield a large variety of chlorinated toxic compounds. Nature 320:155–156.3951554
*Elferink CJ, Whitlock JP Jr. 1990. 2,3,7,8-Tetrachlorodibenzo-p-dioxin: Ah receptor-mediated bending of enhancer DNA. J Biol Chem 265:5718–5721.2156826
Ema M, Sogawa K, Watanabe N, . 1992. cDNA cloning and structure of mouse putative Ah receptor. Biochem Biophys Res Comm 184:246–253.1314586
*Enan E, Matsumura F. 1995. Regulation by 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) of the DNA binding activity via nuclear protein phosphorylation in guinea pig adipose tissue. Biochem Pharmacol 50:1199–1206.7488234
*Enan E, Matsumura F. 1996. Identification of c-src as the integral component of the cytosolic Ah receptor complex, transducing the signal of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) through the protein phosphorylation pathway. Biochem Pharmacol 52:1599–1612.8937476
Enfield CG, Bengtsson G. 1988. Macromolecular transport of hydrophobic contaminants in aqueous environments. Groundwater 26:64–70.
Engblom JF, Norback DH. 1973. Chlorinated dibenzo-p-dioxin distribution with rat tissues and subfractions of the liver. Fed Proc Fed Amer Soc Exp Biol 32:236.
Engesser KH, Fischer P. 1991. Degradation of haloaromatic compounds. In: Betts WB, ed. Springer series in applied biology, Biodegradation: Natural and synthetic materials. Berlin, Germany, New York, NY: Springer-Verlag, 15–54.
*EPA. 1971a. Hexachlorophene: Tolerance for residues. U.S. Environmental Protection Agency. Federal Register 36:22569.
*EPA. 1971b. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.302.
*EPA. 1973. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136, Appendix A.
*EPA. 1977. Ocean dumping: Constituents prohibited as other than trace contaminants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 227.6.
*EPA. 1978. Pesticide chemicals. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455.
EPA. 1979a. Report of assessment of a field investigation of six-year spontaneous abortion rates in three Oregon areas in relation to forest 2,4,5-T spray practice. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances.
EPA. 1979b. 2,4,5-T and silvex: Introduction to suspensions and notice of intent to cavell. U.S. Environmental Protection Agency. Federal Register 44:15874.
*EPA. 1979c. Toxic pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15.
*EPA. 1981a. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413.02.
*EPA. 1981b. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264.343
*EPA. 1982a. Steam electric power generating point source category. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 423.17.
*EPA. 1982b. Steam electric power generating point source category. U.S. Environmental Protection Agency. Federal Register 47:52304, Appendix A.
EPA. 1982c. Test method: 2,3,7,8-Tetrachlorodibenzo-p-dioxin--method 613. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory.
*EPA. 1983a. Underground injection control program. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 144.1.
*EPA. 1983b. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122.21.
*EPA. 1984a. Ambient water quality criteria document for 2,3,7,8-tetrachlorodibenzo-p-dioxin. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA 440/5-84/194/1.
EPA. 1984b. Health and environmental effects profile for tetra-, penta-, and hexachlorodibenzo-p-dioxins. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Environmental Criteria and Assessment Office. EPA/600/22.
EPA. 1984c. Health assessment document for polychlorinated dibenzo-p-dioxins. U.S. Environmental Protection Agency. Federal Register 49:19408.
*EPA. 1984d. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix IX.
*EPA. 1985a. Drinking water criteria document for 2,3,7,8-tetrachlorodibenzo-p-dioxin. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA Report No. 600/x-84-194-I.
EPA. 1985b. Hazardous waste management system: Dioxin-containing wastes. U.S. Environmental Protection Agency. Federal Register 50:1978.
EPA. 1985c. Health and environmental effects profile for brominated dibenzo-p-dioxins. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Environmental Criteria and Assessment Office. EPA/600/22.
EPA. 1985d. Health assessment document for polychlorinated dibenzo-p-dioxins. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA report no. 600/8-84/014.
EPA. 1985e. Notification requirements: Reportable quantity adjustments. U.S. Environmental Protection Agency. Federal Register 50:13457.
*EPA. 1985f. Pesticide chemicals category effluent limitations guidelines, pretreatment standards and new source performance standards. U.S. Environmental Protection Agency. Federal Register 50:40672–40708.
*EPA. 1985g. U. S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4.
*EPA. 1985h. U. S. Environmental Protection Agency. Code of Federal Regulations CFR 266.23.
*EPA. 1985i. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266.112.
*EPA. 1985j. Health assessment document for polychlorinated dibenzo-p-dioxins. U.S. Environmental Protection Agency. Office of Health and Environmental Assessment. Washington, DC 20460. EPA/800/8-84/014F. September 1985. Final Report. Pages 1.1, 2.1–2.8, 11.19, 11.122, 11.125, 11.126, and 11.30–11.40
EPA. 1986a. Broad scan analysis of the FY82 national human adipose tissue survey specimens. Vol. IV. Polychlorinated dibenzo-p-dioxins (PCDD) and polychlorinated dibenzofurans (PCDF). Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances: EPA report no. 560/5-86/038.
*EPA. 1986b. Electroplating point source category. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413.
*EPA. 1986c. Electroplating point source category. U.S. Environmental Protection Agency. Federal Register 51:40421.
*EPA. 1986d. General pretreatment regulations for existing and new sources of pollution. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 403.2 Appendix B.
*EPA. 1986e. General pretreatment regulations for existing and new sources of pollution. U.S. Environmental Protection Agency. Federal Register 51:20429–20431.
*EPA. 1986f. Hazardous waste management system: Land disposal restriction. U.S. Environmental Protection Agency. Federal Register 51:40572–40623.
*EPA. 1986g. Metal finishing point source category. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 433.
*EPA. 1986h. Metal finishing point source category. U.S. Environmental Protection Agency. Federal Register 51:40421.
EPA. 1986i. Testing and reporting requirements for polyhalogenated dibenzo-p-dioxins/dibenzofurans: Addition of chlorinated and brominated benzenes to list of precursor chemicals. U.S. Environmental Protection Agency. Federal Register 51:37612–37613.
EPA. 1986j. 2,3,7,8-Tetrachlorodibenzo-p-dioxins: Health advisory. Draft. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water, October 16, 1986.
*EPA. 1986k. Test methods for evaluating solid waste (SW 846) volume IB: Laboratory manual physical chemical methods. Method 8280, the analysis of polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans. U. S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, Washington, DC.
*EPA. 1986l. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.50.
EPA. 1987a. EPA contract laboratory program: Statement of work for organic analysis. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1987b. Groundwater monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX.
*EPA. 1987c. Hazardous materials table and hazardous materials communications regulations. U.S. Environmental Protection Agency. Federal Register 52:4825–4843.
*EPA. 1987d. Hexachlorophene: tolerance for residues. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.302.
*EPA. 1987e. Interim procedures for estimating risks associated with exposure to mixtures of chlorinated dibenzo-p-dioxins and dibenzo furans (CDDs and CDFs). Risk Assessment Forum. Washington, DC: U.S. Environmental Protection Agency: EPA report no. 625/3-87/012.
*EPA. 1987f. Listing of hazardous substance and reportable quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1987g. List (phase I) of hazardous constituents for ground-water monitoring. U.S. Environmental Protection Agency. Federal Register 52:25942–25952.
EPA. 1987h. Polychlorinated dibenzo-p-dioxin/dibenzofurans: Testing and reporting requirements. U.S. Environmental Protection Agency. Federal Register 52:21412–21442.
*EPA. 1987i. Reportable quantity adjustments. U.S. Environmental Protection Agency. Federal Register 52:8140.
*EPA. 1987j. 2,3,7,8-TCDD: Health advisory. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water. 1987.
*EPA. 1987k. 2,3,7,8-TCDD: Environmental chemistry. Athens, GA: Environmental Protection Agency, Office of Research and Development, Environmental Research Laboratory. EPA600/D-87/086.
EPA. 1987l. 2,3,7,8-Tetrachlorodibenzo-p-dioxin: Environmental chemistry. ACS Symp Ser 338:82–93.
*EPA. 1987m. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268 Appendix IIII.
*EPA. 1987n. The National Dioxin Study; Tiers 3,5,6, and 7. Office of Water Regulations and Standards. Washington DC EPA 440/4-87-003.
EPA. 1988a. A cancer risk-specific dose estimate of 2,3,7,8-TCDD. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Office of Health Effects Assessment. EPA report no. 600/6-88/007Aa.
EPA. 1988b. A cancer risk-specific dose estimate of 2,3,7,8-TCDD: Appendices A through F. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Office of Health Effects Assessment. EPA report no. 600/6-88/007Ab.
EPA. 1988c. Estimating exposure to 2,3,7,8-TCDD. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Office of Health Effects Assessment. EPA report no. 600/6-88/005A.
*EPA. 1988d. Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII.
*EPA. 1988e. Hazardous waste management system: Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Federal Register 53:13382–13393.
*EPA. 1988f. Land disposal: Waste specified prohibitions--dioxin-containing wastes. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.31.
*EPA. 1988g. Compendium on methods for the determination of toxic organic compounds in ambient air, Method TO-9, method for the determination of polychlornated dibenzo-p-dioxins(PCDDs) in ambient air using high resolution gas chromatography high resolution mass spectrometry. (HRGC/HRMS). EPA 600/4/89/017.
*EPA. 1988h. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 148.11.
EPA. 1989a. Assessment of the potential for transport of dioxins and codisposed materials to groundwater. Washington, DC: U.S. Environmental Protection Agency. EPA 600/S6-89/002.
*EPA. 1989b. Drinking water standards and health advisory table. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water.
*EPA. 1989c. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/8-88-066F.
*EPA. 1989d. Notes of 2/01/89 CRAVE meeting. Memorandum to CRAVE Workgroup, Office Directors from Rita Schoeny. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Environmental Criteria and Assessment Office.
*EPA. 1989e. Interim procedures for estimating risks associated with exposure to mixtures of chlorinated dibenzo-p-dioxins and dibenzofurans (CDDs and CDFs) and 1989 update. Risk Assessment Forum. Washington, DC: U.S. Environmental Protection Agency. EPA 625/3-89/016. NTIS PB90-145756.
*EPA. 1989f. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, Appendix IX.
*EPA. 1990. Standards of performance for volatile organic compounds (VOC) emissions from synthetic organic chemical manufacturing industry (SOCMI) distillation operation. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.667.
*EPA. 1990a. Characterization of municipal waste combustion ash, ash extracts, and leachates. Coalition on Resource Recovery and the Environment. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response. Contract No. 68-01-7310. EPA 530-SW-90-029A.
*EPA. 1990b. Standards for owners and operators of hazardous waste treatment, storage, and disposal facilities. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264.342.
*EPA. 1990c. Dibenzo-para-dioxins/dibenzofurans in bleached wood pulp and paper product referral for action. U. S. Environmental Protection Agency. 55 Federal Register 248:53047–53049.
*EPA. 1990d. Summary report on USEPA/ Industry Cooperative Dioxin Study. “The 104 mills study” Washington, DC Office of Water Regulations and Standards July 1990.
*EPA. 1991a. Health effects assessment summary tables. U.S. Environmental Protection Agency. Prepared by Office of Health and Environmental Assessment, Environmental Assessment and Criteria Office, Cincinnati, OH, for the Office of Solid Waste and Emergency Response, Office of Emergency and Remedial Response, Washington, DC, January 1991. OERR 9200.6-303(91-1).
*EPA. 1991b. Proposed regulation of land application of sludge from pulp and paper mills using chlorine and chlorine derivative bleaching processes. U.S. Environmental Protection Agency. Federal Register 56:21802.
*EPA. 1991c. Public meeting on EPA’s scientific reassessment of dioxin. U.S. Environmental Protection Agency. Federal Register 56:50903–50904.
*EPA. 1991d. Atmospheric transport and deposition of polychlorinated dibenzo-p-dioxins and dibenzofurans. Washington, DC: U.S. Environmental Protection Agency. EPA600/3-91/002 Order No. PB91-144667.
*EPA. 1991e. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.51a.
*EPA. 1991f. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 744.
*EPA. 1991g. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266.103.
*EPA. 1991h. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266.104.
*EPA. 1991i. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.48.
*EPA. 1992. National Study of Chemical Residues in Fish. Volume 1. Office of Science and Technology, Washington D.C. EPA 823-R-92-008a. September 1992.
*EPA. 1993a. Development document for proposed effluent limitation guidelines and standards for the pulp, paper and paperboard point source category. Environmental Protection Agency, Office of Water, Washinton, DC. EPA-821-R-93-019.
*EPA. 1993b. U. S. Environmental Protection Agency. Federal Register. 58 FR 408892. Code of Federal Regulations. 40 CFR 148.
*EPA. 1993c. U. S. Environmental Protection Agency. Federal Register. 58 FR 25706. Code of Federal Regulations. 40 CFR 261.31.
*EPA. 1994a. Method 1613: tetra-through octa chlorinated dioxins and furans by isotope dilution HRGC/HRMS. United States Environmental Protection Agency, Office of Water, Engingering and Analysis Division, Washington DC. EPA 821-B-94-005.
*EPA. 1994b. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.48.
*EPA. 1994c. Polychlorinated dibenzodioxins (PCDDs) and polychlorinated dibenzofurans (PCDFs) by high-resolution gas chromatography/high-resolution mass spectrometry (HRGC/HRMS). Test methods for evaluating solid waste, method 8290. Environmental Protection Agency, Washington, DC.
*EPA. 1994d. National primary drinking water regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.
*EPA. 1994e. Variances and exeptions from the maximum contaminant levels for organic and inorganic chemicals. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 142.62.
*EPA. 1995a. Drinking water regulations and health advisories. Office of Water, U. S. Environmental Protection Agency. Washington DC.
*EPA. 1995b. Emissions guidelines and compliance times for municipal waste combustors. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60, Subpart Cb.
*EPA. 1995c. Guidance for assessing chemical contaminant data for use in fish advisories. Volume 1. Sampling and analysis second edition. Office of Water Washington DC EPA 823-R-95-007 September 1995
*EPA. 1995d. Standards of performance for municipal waste combustors for which construction is commenced after septermer 20, 1994. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60, Subpart Eb.
*EPA. 1995e. National emission standards for wood furniture manufacturing operations. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 63, Subpart JJ.
*EPA. 1995f. Standards of performance for municipal waste combustors for which contruction is commenced after december 20, 1989 and on or before september 20, 1994. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60, Subpart Ea.
*EPA. 1995g. Toxic Chemical Release Inventory Reporting Form R and Instructions (revised 1994 version). Office of Pollution Prevention and Toxics, Washington DC EPA 745-K-95-051.
*EPA. 1996a. Drinking water regulations and health advisories. U. S. Environmental Protection Agency. Office of Water. EPA 822-B-96-002. October 1996.
*EPA. 1996b. National listing of fish and wildlife consumption advisories. Office of Science and Technology, Washington DC EPA 823-C-96-011.
*EPA. 1997a. Large municipal waste combustion units; emission guidelines; final rule. U. S. Environmental Protection Agency. Federal Register. 62 FR 45116. August 25, 1997.
*EPA. 1997b. Standards of perfomance for new stationary sources and emission guidelines for existing sources: hospital/medical/infectious waste incinerators; final rule. U. S. Environmental Protection Agency. Federal Register. 62 FR 48348. September 15, 1997.
*EPA. 1997c. Addition of dioxin and dioxin-like compounds; modification of polychlorinated biphenyls (PCBs) listing; toxic chemical release reporting; community right-to-know. U. S. Environmental Protection Agency. Federal Register. 62 FR 24887.
*EPA. 1997d. Land disposal restrictions-phas IV: treatment standards for wood preserving wstes, paperwork reduction and streamlining, exemptions from RCRA for certain processed materials; and miscellaneous hazardous waste provisions; final rule. U. S. Environmental Protection Agency. Federal Register. 62 FR 25998. May 12, 1997.
*EPA. 1997e. Water quality standards; establishment of numeric criteria for priority toxic pollutants for the state of california; proposed rule. U. S. Environmental Protection Agency. Federal Register. 62 FR 42160. August 5, 1997.
*EPA. 1997f. Emissions guidelines for existing sources and standards of performance for new stationary sources: large municipal waste combustion units; final rule. U. S. Environmental Protection Agency. Federal Register. 62 FR 45124. August 25, 1997.
*EPA. 1997g. Guidelines establishing test procedures for the analysis of pollutants; epa method 1613;l final rule. U. S. Environmental Protection Agency. Federal Register. 62 FR 48394.
*EPA. 1998a. Update: listing of fish and wildlife advisories. U.S. Environmental Protection Agency. Office of Water. Fact Sheet. EPA-823-F-98-009. March 1998.
*EPA. 1998b. Listing of fish and wildlife advisories - 1997. U.S. Environmental Protection Agency Office of Water, Washington, DC.
*EPA. 1998c. National emission standards for hazardous air pollutants; proposed standards for hazardous air pollutants emissions for portlancd cement manufacturing industry; proposed rule. U. S. Environmental Protection Agency. Federal Register. 63 FR 14182. March 24, 1998.
*EPA. 1998d. National primary drinking water regulations: consumer confidence; proposed rule. U. S. Environmental Protection Agency. Federal Register. 63 FR 7606. February 13, 1998.
*EPA. 1998e. Significant new uses of certain chemical substances; final rule. U. S. Environmental Protection Agency. Federal Register. 63 FR 3394. Janyary 22, 1998.
*EPA. 1998f. Effluent limitiaitions guidelines, pretreatment standrds, and new soruce performance standards for the transportaion equipment cleaning point source category; proposed rule. U. S. Environmental Protection Agency. Federal Register. 63 FR 34686. June 25, 1998.
*EPA. 1998g. Effluent limitations guidelines, pretreatment standards, and new source performance standards for the industrial waste combustor subcategory of the waste combustors point source category; proposed rule. U. S. Environmental Protection Agency. Federal Register. 63 FR 6392. February 6, 1998.
*EPA. 1998h. Effluent limitations guideline, pretreatment standards, and new source performance standrds for the landfills point source category; proposed rule. U. S. Environmental Protection Agency. Federal Register. 63 FR 6426. February 6, 1998.
*EPA. 1998i. Hazardous waste combustors; revised standards; final rule. U. S. Environmental Protection Agency. Federal Register. 63 FR 33782. June 19, 1998.
*EPA. 1998j. Source category listing for section 112 (d) (2) rulemaking pursuant to section 112 (c) (6) requirements. U.S. Environmental Protection Agency (EPA) Federal Register 63 FR 17838-17851 (April 10, 1998).
Epling GA, Qiu QW, Kumar A. 1989. Hydride enhanced photoreaction of chlorodibenzodioxins. Chemosphere 18:329–332.
*Erickson JD, Mulinare J, McClain PW, . 1984. Vietnam veterans’ risks for fathering babies with birth defects. JAMA 252:903–912.6748190
Erickson MD, Swanson SE, Flora JD, . 1989. Polychlorinated dibenzofurans and other thermal combustion products from dielectric fluids containing polychlorinated biphenyls. Environ Sci Technol 23:462–470.
*Eriksson M, Hardell L, Adami HO. 1990. Exposure to dioxins as a risk factor for soft tissue sarcoma: A population-based case-control study. J Natl Cancer Inst 82:486–490.2313720
Eriksson M, Hardell L, Berg NO, . 1979. Case-control study on malignant mesenchymal tumors of the soft tissue and exposure to chemical substances. Lakartidningen 76:3872–3875.529930
*Eriksson M, Hardell L, Berg NO, . 1981. Soft-tissue sarcomas and exposure to chemical substances: A case-referent study. Br J Ind Med 38:27–33.7470401
*Ernst M, Flesch-Janys D, Morgenstern I, . 1998. Immune cell functions in industrial workers after exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin: Dissociation of antigen-specific T-cell responses in cultures of diluted whole blood and of isolated peripheral blood mononuclear cells. Environ Health Perspect 106(Suppl 2):701–705.
*Eschenroeder A, Jaeger RJ, Ospital JJ, . 1986. Health risk analysis of human exposures to soil amended with sewage sludge contaminated with polychlorinated dibenzodioxins and dibenzofurans. Vet Hum Toxicol 28:435–442.3776090
*Evans RG, Webb KB, Knutsen AP, . 1988. A medical follow-up of the health effects of long-term exposure to 2,3,7,8-TCDD. Arch Environ Health 43:273–278.3415353
Evers EHG, Ree KCM, Olie K. 1988. Spatial variations and correlations in the distribution of PCDDs, PCDFs and related compounds in sediments for the River Rhine-Western Europe. Chemosphere 17:2271–2288.
*Facchetti S, Balasso A, Fichtner C, . 1986. Studies on the absorption of TCDD by plant species. In: Rappe C, Choudhary G, Keith LH, eds. Chlorinated dioxins and dibenzofurans in perspective. Chelsea, MI: Lewis Publishers, Inc., 225–235.
*Fairless BJ, Bates DI, Hudson J, . 1987. Procedures used to measure the amount of 2,3,7,8-tetrachlorodibenzo-p-dioxin in the ambient air near a Superfund site cleanup operation. Environ Sci Technol 21:550–555.19994974
*Faith RE, Luster MI, Moore JA. 1978. Chemical separation of helper cell function and delayed type hypersensitivity. Cell Immunol 40:275–284.309796
*Faith RE, Moore JA. 1977. Impairment of thymus-dependent immune functions by exposure of developing immune system to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). J Toxicol Environ Health 3:451–464.926199
Falk H, Stehr PA, Stein GF, . 1984. A pilot epidemiology study of health effects due to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) contamination in Missouri. Banbury Rep. Issue Biol Mech Dioxin Action 18:447–460.
*Fan F, Rozman KK. 1995. Short- and long-term biochemical effects of 2,3,7,8-tetrachorodibenzo-p-dioxin in female Long-Evans rats. Toxicol Letters 75:209–216.
*Fan F, Wierda D, Rozman KK. 1996. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin on humoral and cell-mediated immunity in Sprague-Dawley rats. Toxicology 106:221–228.8571394
*Faqi AS, Dalsenter PR, Merker H-J, . 1998. Reproductive toxicity and tissue concentrations of low doses of 2,3,7,8-tetrachlorodibenzo-p-dioxin in male offspring rats exposed throughout pregnancy and lactation. Tox Appl Pharmacol 150:383–392.
Favreau LV, Pickett CB. 1993. Transcriptional regulation of the rat NAD(P)H:quinone reductase gene. Characterization of a DNA-protein interaction at the antioxidant responsive element and induction by 12-O-tetradecoylphorbol 13-acetate. J Biol Chem 268:19875–19881.8396148
FDA. 1983. Statement by SA Miller, Director of Bureau of Foods, FDA: Testimony before the Subcommittee on natural resources, agriculture, research and environment. Washington, DC: U.S. House of Representatives, Food and Drug Administration, June 30.
*FDA. 1995. Requirements for Specifice Standardized Beverages. U. S. Food and Drug Administration. Code of Federal Regulations. 21 CFR165.110.
*FDA. 1998a. Beverages: bottled water; direct final rule. U. S. Food and Drug Administration. Federal Register. 63 FR 25764. May 11, 1998.
*FDA. 1998b. Beverages: bottled water; corrections. U. S. Food and Drug Administration. Federal Register. 63 FR 30620. June 5, 1998.
*FDA. 1998c. Beverage: bottled water; direct final rule; confirmaiton. U. S. Food and Drug Administration. Federal Register. 63 FR 42198. August 6, 1998.
*FEDRIP. 1998. Federal Research In Progress. Dialog Information Service, Inc., Palo Alto, CA. February 1998.
Fehringer NV, Walter SM, Kozara RJ, . 1985. Survey of 2,3,7,8-tetrachlorodibenzo-para-dioxin in fish from the Great Lakes and selected Michigan rivers. J Agric Food Chem 33:626–630.
*Fernandez-Salguero PM, Hilbert DM, Rudikoff S, . 1996. Aryl-hydrocarbon receptor-deficient mice are resistant to 2,3,7,8-tetrachlorodibenzo-p-dioxin-induced toxicity. Toxicol Appl Pharmacol 140:173–179.8806883
*Ferrario J, Byrne C, Lorber M, . 1997. A statistical survey of dioxin-like compounds in United States poultry fat. Organohalogen Compounds 32:64–70.
*Ferrario J, Byrne C, McDaniel D, . 1996. Determination of 2,3,7,8,-chlorine substituted dibenzo-p-dioxins and furans at the part per trillion level in United States beef fat using high resolution gas chromatography/high resolution mass spectrometry. Anal Chem 68:647–652.8999739
Fett MJ, Dunn M, Adena MA, . 1984. Australian veterans health studies: The mortality report. Part I: A retrospective cohort study of mortality among Australian national servicemen of the Vietnam conflict era, and an executive summary of the mortality report. Canberra, Australia: Australian Government Publishing Service.
*Fiedler H, Cooper KR, Bergek S, . 1997. Polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans (PCDD/PCDF) in food samples collected in southern Mississippi, USA. Chemosphere 34(5–7):1411–1419.9134675
Field B, Kerr C. 1979. Herbicide use and incidence of neural tube defects. Lancet 1:1341–1342.
*Filippini G, Bordo B, Crenna P, . 1981. Relationship between clinical and electrophysiological findings and indicators of heavy exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Scand J Work Environ Health 7:257–262.6291143
*Fine JS, Gasiewicz TA, Fiore NC, . 1990a. Prothymocyte activity is reduced by perinatal 2,3,7,8-tetrachlorodibenzo-p-dioxin exposure. J Pharmacol Exp Ther 255:128–132.2213547
*Fine JS, Gasiewicz TA, Silverstone AE. 1989. Lymphocyte stem cell alterations following perinatal exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Mol Pharmacol 35:18–25.2783621
*Fine JS, Silverstone AE, Gasiewicz TA. 1990b. Impairment of prothymocyte activity by 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Immunol 144:1169–1176.2303704
Fingerhut MA, Halperin WE, Honchar PA, . 1984. An evaluation of reports of dioxin exposure and soft tissue sarcoma pathology among chemical workers in the United States. Scand J Work Environ Health 10:299–303.6523094
*Fingerhut MA, Halperin WE, Marlow DA, . 1991. Cancer mortality in workers exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin. N Engl J Med 324:212–218.1985242
*Fingerhut MA, Haring-Sweeney M, Patterson DG Jr, . 1989. Levels of 2,3,7,8-tetrachlorodibenzo-p-dioxin in the serum of U.S. chemical workers exposed to dioxin contaminated products: Interim results. Chemosphere 19:835–840.
Firestone D, Clower M Jr, Borsetti AP, . 1979. Polychlorodibenzo-p-dioxin and pentachlorophenol residues in milk and blood of cows fed technical pentachlorophenol. J Agric Food Chem 27:1171–1177.544646
*Firestone D, Niemann RA, Schneider LF, . 1986. Dioxin residues in fish and other foods. In: Rappe C, Choudhary G, Keith LH, eds. Chlorinated dioxins and dibenzofurans in perspective. Chelsea, MI: Lewis Publishers, Inc., 355–365.
Firestone D, Ress J, Brown NL, . 1972. Determination of polychlordibenzo-p-dioxins and related compounds in commercial chlorophenols. J Assoc Off Anal Chem 55:85–92.4666862
Fishbein L. 1992. Exposure from occupational versus other sources. Scand J Work Environ Health 18(1):5–16.
*Fisher JM, Jones KW, Whitlock JP Jr. 1989. Activation of transcription as a general mechanism of 2,3,7,8-tetrachlorodibenzo-p-dioxin action. Mol Carcinogenesis 1:216–221.
*Fisher JM, Wu L, Denison MS, . 1990. Organization and function of a dioxin-responsive enhancer. J Biol Chem 265:9676–9681.2161840
*Fitzgerald EF, Hwang S-A, Brix KA, . 1995. Fish PCB concentrations and comsumption patterns among Mohawk women at Akwesasne. Journal of Exposure Analysis and Environmental Epidemiology 5(1):1–19.7663146
*Flaws JA, Sommer RJ, Silbergeld EK, . 1997. In utero and lactational exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) induces genital dysmorphogenesis in the female rat. Toxicol Appl Pharmacol 147:351–362.9439730
*Flesch-Janys D, Becher H, Gurn P, . 1996. Elimination of polychlorinated dibenzo-p-dioxins and dibenzofurans in occupationally exposed persons. J Toxicol Environ Health 47:363–378.8600289
*Flesch-Janys D, Berger J, Gurn P, . 1995. Exposure to polychlorinated dioxins and furans (PCDD/F) and mortality in a cohort of workers from a herbicide-producing plant in Hamburg, Federal Republic of Germany. Am J Epidemiol 142:1165–1175.7485063
*Flesch-Janys D, Steindorf K, Gurn P, . 1998. Estimation of the cumulated exposure to polychlorinated dibenzo-p-dioxins/furans and standardized mortality ratio analysis of cancer mortality by dose in an occupationally exposed cohort. Environ Health Perspect 106(Suppl2):655–662.
*Fletcher Cl, McKay WA. 1993. Polychlorinated dibenzo-p-dioxins PCDDs and dibenzofurans PCDFs in the aquatic environment a literature review. Chemosphere 26(6):1041–1069.
Flick DF, Firestone D, Higginbotham GR. 1972. Chick edema disease: 9. Response of chicks fed or singly administered synthetic edema-producing compounds. Poult Sci 51:2026–2034.4660983
*Flodstrom S, Ahlborg UG. 1989. Tumour promoting effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD): Effects of exposure duration, administration schedule and type of diet. Chemosphere 19:779–783.
*Flodstrom S, Ahlborg UG. 1992. Relative tumor promoting activity of some polychlorinated dibenzo-p-dioxin, dibenzofuran-, and biphenyl congeners in female rats. Chemosphere 25:169–172.
*Flodstrom S, Busk L, Kronevi T, . 1991. Modulation of 2,3,7,8-tetrachlorodibenzo-p-dioxin and phenobarbital-induced promotion of hepatocarcinogenesis in rats by the type of diet and vitamin A deficiency. Fund Appl Toxicol 16:375–391.
*Foman SJ. 1966. Body composition of the infant (Part I: The male reference infant). In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Foman, SJ, Haschke F, Ziegler EE . 1982. Body composition of reference children from birth to 10 years. American Journal of Clinical Nutrition 35:1169–1175.7081099
*Forsberg B, Nordstrom S. 1985. Miscarriages around a herbicide manufacturing company in Sweden. Ambio 14:110–111.
*Först C, Stieglitz L, Zwick G. 1988. Isomer-specific determination of PCDD/PCDF in oil extracts from water leachate of a waste landfill. Chemosphere 17:1935–1944.
Fossa AJ, Kerr RS, Columbus AF, . 1987. Air emission characterization of municipal waste combustors in New York State. Proc APCA Annu Meet 80:2–14.
Foster MG, Huneault H, Cosby O, . 1990. Assessment of reference materials for application to PCDD/PCDF analysis. Chemosphere 20:1285–1290.
*Foster WG, Ruka MP, Gareau P, . 1997. Morphologic characteristics of endometriosis in the mouse model: Application to toxicology. Can J Physiol Pharmacol 75:1188–1196.9431442
*Fowler BA, Hook GER, Lucier GW. 1977. Tetrachlorodibenzo-p-dioxin induction of renal microsomal enzyme systems: Ultrastructural effects on pars recta (S3) proximal tubule cells of the rat kidney. J Pharmacol Exp Ther 203:712–721.411914
Frakes RA, Zeeman C QT, Mower B. 1993. Bioaccumulation of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) by fish downstream of pulp and paper mills in Maine. Ecotoxicol Environ Saf 25(2):244–252.7682508
*Frazier DE, Silverstone AE, Gasiewicz TA. 1994. 2,3,7,8-Tetrachlorodibenzo-p-dioxin-induced thymic atrophy and lymphocyte stem cell alterations by mechanisms independent of the estrogen receptor. Biochem Pharmacol 47:2039–2048.8010988
Freeman RA, Hileman FD, Noble RW, . 1987. Experiments on the mobility of 2,3,7,8-tetrachlorodibenzo-p-dioxin at Times Beach, Missouri. ACS Symp Ser 338:114–130.
Freeman RA, Schroy JM. 1985. Environmental mobility of TCDD. Chemosphere 14:873–876.
*Freeman RA, Schroy JM. 1986. Modeling the transport of 2,3,7,8-TCDD and other low volatility chemicals in soils. Environ Progress 5:28–33.
Freeman RA, Schroy JM. 1988. Modeling of chemical movement in soil matrices. Presented at the 195th ACS National Meeting, Toronto, Ontario, Canada, June 5-10, 8.
*Freeman RA, Schroy JM, Hileman FD, . 1986. Environmental mobility of 2,3,7,8-TCDD and companion chemicals in a roadway soil matrix. In: Rappe C, Choudhary G, Keith LH, eds. Chlorinated dioxins and dibenzofurans in perspective. Chelsea, MI: Lewis Publishers, Inc., 171–183.
Friedman JM. 1984. Does Agent Orange cause birth defects? Teratology 29:193–221.6377557
*Friedrich C, Kleiboehmer W. 1997. Supercritical co2-assisted liquid extraction of polycyclic aromatic hydrocarbons and polychlorinated dibenzo-p-dioxins and -furans from solid matrices. Journal of Chromatography A 777(2):289–294.
*Fries GF, Marrow GS. 1975. Retention and excretion of 2,3,7,8-tetrachlorodibenzo-p-dioxin by rats. J Agric Food Chem 23:265–269.1133300
*Fries GF, Paustenbach DJ. 1990. Evaluation of potential transmission of 2,3,7,8-tetrachlorodibenzo-p-dioxin-contaminated incinerator emissions to human via foods. Journal of Toxicology and Environmental Health 29:1–43.2405173
Friesen KJ, Muir DCG, Webster GRB. 1990. Evidence of sensitized photolysis of polychlorinated dibenzo-p-dioxins in natural waters under sunlight conditions. Environ Sci Technol 24:1739–1744.
*Friesen KJ, Sarna LP, Webster GRB. 1985. Aqueous solubility of polychlorinated dibenzo-p-dioxins determined by high pressure liquid chromatography. Chemosphere 14:1267–1274.
Friesen MD, Hass Jr, Harvan D, . 1980. Negative ion chemical ionization mass spectrometry: Determination on chlorinated dibenzo-p-dioxins. Pract Spectrosc 3:324–375.
Frommberger R. 1990. Polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans in cumulative samples of human milk from Baden-Wuerttemberg, FRG. Chemosphere 20:333–342.
*FSTRAC. 1990. Summary of state and federal drinking water standards and guidelines. Federal-State Toxicology and Regulatory Alliance Committee, Chemical Communication Subcommittee.
*Fukunaga BN, Probst MR, Reisz-Porszasz S, . 1995. Identification of functional domains of the aryl hydrocarbon receptor. J Biol Chem 270: 29270–29278.7493958
*Fürst P, Fürst C, Wilmers K. 1992. PCDDs and PCDFs in human milk statistical evaluation of a 6-years survey. 1992. Chemosphere 25(7–10):1029–1038.
*Fürst P, Fürst C, Wilmers K. 1994. Human milk as a bioindicator for body burden of PCDDs, PCDFs, organochlorine pesticides, and PCBs. Environ Health Perspect 102(1):187–193.
*Fürst P, Krause GHM, Hein D, . 1993. PCDD/PCDF in cow’s milk in relation to their levels in grass and soil. Chemosphere 27(8):1349–1357.
Fürst P, Krüger C, Meemken HA, . 1989a. Interaction between sample and packaging material - a potential source of contamination with PCDDs and PCDFs. Chemosphere 18:891–896.
*Fürst P, Krüger C, Meemken HA, . 1989b. PCDD and PCDF levels in human milk - dependence on the period of lactation. Chemosphere 18:439–444.
Fürst P, Meemken HA, Groebel W. 1986. Determination of polychlorinated dibenzodioxins and dibenzofurans in human milk. Chemosphere 15:1977–1980.
Fürst P, Meemken HA, Krüger C, . 1987. Polychlorinated dibenzodioxins and dibenzofurans in human milk samples from Western Germany. Chemosphere 16:1983–1988.
*Gaido KW, Maness SC. 1994. Regulation of gene expression and acceleration of differentiation in human keratinocytes by 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 127:199–208.8048063
*Garrison PM, Tullis K, Aarts JMMJG, . 1996. Species-specific recombinant cell lines as bioassay systems for the detection of 2,3,7,8-tetrachlorodibenzo-p-dioxin-like chemicals. Fund Appl Toxicol 30:194–203.
Garten CT Jr, Trabalka JR. 1983. Evaluation of models for predicting terrestrial food chain behavior of xenobiotics. Environ Sci Technol 17:590–595.22288703
Gasiewicz TA. 1991. Nitro compounds and related phenolic pesticides. In: Hayes WJ, Laws ER, eds. Handbook of pesticide toxicology. Volume 3: Classes of pesticides. New York, NY: Academic Press, Inc., 1191–1269.
*Gasiewicz TA, Elferink CJ, Henry EC. 1991. Characterization of multiple forms of the Ah receptor: Recognition of a dioxin-responsive enhancer involves heteromer formation. Biochemistry 30:2909–2916.1848780
*Gasiewicz TA, Geiger LE, Rucci G, . 1983a. Distribution, excretion, and metabolism of 2,3,7,8-tetrachlorodibenzo-p-dioxin in C57BL/6J, DBA/2J, and B6D2F1/J mice. Drug Metab Dispos 11:397–403.6138222
*Gasiewicz TA, Henry EC, Baggs RB, . 1986. Temporal- and dose-related characteristics of biochemical and morphological alterations in the hamster induced by 2,3,7,8-tetrachlorodibenzo-p-dioxin. Chemosphere 15:1749–1752.
*Gasiewicz TA, Holscher MA, Neal RA. 1980. The effect of total parenteral nutrition on the toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin in the rat. Toxicol Appl Pharmacol 54:469–488.6771887
*Gasiewicz TA, Neal RA. 1979. 2,3,7,8-Tetrachlorodibenzo-p-dioxin tissue distribution, excretion, and effects on clinical parameters in guinea pigs. Toxicol Appl Pharmacol 51:329–339.531895
*Gasiewicz TA, Olson RJ, Geiger LE, . 1983b. Absorption, distribution, and metabolism of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in experimental animals. In: Tucker RE, Young AL, Gray AP, eds. Human and environmental risk of chlorinated dioxins and related compounds. New York, London: Plenum Press, 495–525.
*Gasiewicz TA, Rucci G. 1984. Cytosolic receptor for 2,3,7,8-tetrachlorodibenzo-p-dioxin. Evidence for a homologous nature among various mammalian species. Mol Pharmacol 26:90–98.6087120
*Gasiewicz TA, Rucci G. 1991. Alpha-naphthoflavone acts as an antagonist of 2,3,7,8-tetrachlorodibenzo-p-dioxin by forming an inactive complex with the Ah receptor. Mol Pharmacol 40:607–612.1658599
*Gehrs BC, Riddle MM, Williams WC, . 1997a. Alterations in the developing immune system of the F344 rat after perinatal exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. II. Effects on the fetus and the neonate. Toxicology 122:219–228.9328222
*Gehrs BC, Riddle MM, Williams WC, . 1997b. Alterations in the developing immune system of the F344 rat after perinatal exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. II. Effects on the pup and the adult. Toxicology 122:229–240.9328223
*Geiger LE, Neal RA. 1981. Mutagenicity testing of 2,3,7,8-tetrachlorodibenzo-p-dioxin in histidine auxotrophs of Salmonella typhimurium. Toxicol Appl Pharmacol 59:125–129.7020158
Geyer HJ, Scheunert I, Fiser JG, . 1986a. Bioconcentration potential (BCP) of 2,3,7,8-tetrachlorodibenzo-p-dioxin (2,3,7,8-TCDD) in terrestrial organisms including humans. Chemosphere 15:1495–1502.
Geyer HJ, Scheunert I, Korte F. 1986b. Bioconcentration potential of organic environmental chemicals in humans. Regul Toxicol Pharmacol 6:313–347.3101145
Geyer HJ, Scheunert I, Korte F. 1987. Correlation between the bioconcentration potential of organic environmental chemicals in humans and their n-octanol/water partition coefficients. Chemosphere 16:239–252.
*Geyer HJ, Scheunert I, Rapp K, . 1990. Correlation between acute toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) and total body fat content in mammals. Toxicology 65:97–104.2274972
*Giavini E, Prati M, Vismara C. 1983. Embryotoxic effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin administered to female rats before mating. Environmental Research 31:105–110.6851974
*Giavini E, Prati M, Vismaro C. 1982. Rabbit teratology study: 2,3,7,8-Tetrachlorodibenzo-p-dioxin. Environ Res 27:74–78.7067682
*Gierthy JF, Lincoln DW, Gillespie MB, . 1987. Suppression of estrogen-regulated extracellular tissue plasminogen activator activity of MCF-7 cells by 2,3,7,8-tetrachlorodibenzo-p-dioxin. Cancer Res 47:6198–6203.3119194
*Gierthy JF, Lincoln DW, Kampick SJ, . 1988. Enhancement of 2- and 16-estradiol hydroxylation in MCF-7 human breast cancer cells by 2,3,7,8-tetrachlorodibenzo-p-dioxin. Biochem Biophys Res Comm 157:515–520.3202862
*Gierthy JF, Silkworth JB, Tassinari M, . 1994. 2,3,7,8-Tetrachlorodibenzo-p-dioxin inhibits differentiation of normal diploid rat osteoblasts in vitro. J Cell Biochem 54:231–238.8175897
*Gilbert P, Saint-Ruf G, Poncelet F, . 1980. Genetic effects of chlorinated anilines and azobenzenes on Salmonella typhimurium. Arch Environ Contam Toxicol 9:533–541.7002063
Gilner M, Brittebo EB, Brandt I, . 1987. Uptake and specific binding of 2,3,7,8-tetrachlorodibenzo-p-dioxin in the olfactory mucosa of mice and rats. Cancer Res 47:4150–4159.3038308
Giri AK. 1986. Mutagenic and genotoxic effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin: A review. Mutat Res 168:241–242.3540643
*Gizzi F, Reginato R, Benfenati E, . 1982. PCDDs and PCDFs in emissions from an urban incinerator: I. Average peaks and values. Chemosphere 11:577–583.
Gobas FAPC, Muir DCG, Mackay D. 1988. Dynamics of dietary bioaccumulation and faecal elimination of hydrophobic organic chemicals in fish. Chemosphere 17:943–962.
Gochfeld M, Nygren M, Hansson M, . 1989. Correlation of adipose and blood levels of several dioxin and dibenzofuran congeners in Agent Orange exposed Vietnam veterans. Chemosphere 18:517–524.
*Goetz CG, Bolla KI, Rogers SM. 1994. Neurologic health outcomes and Agent Orange: Institute of Medicine Report. Neurology 44:801–809.8190278
*Goldman LR, Hayward DG, Flattery J, . 1989. Serum, adipose, and autopsy tissue PCDD and PCDF levels in people eating dioxin-contaminated beef and chicken eggs. Chemosphere 19:841–848.
*Goldman PJ. 1973. [Severest acute chloracne. A mass poisoning by 2,3,7,8-tetrachlorodibenzo-p-dioxin.] Hautarzt 24:149–152. (German)4268286
Goldstein JA, Friesen M, Linder RE, . 1977. Effects of pentachlorophenol on hepatic drug-metabolizing enzymes and porphyria related to contamination with chlorinated dibenzo-p-dioxins and dibenzofurans. Biochem Pharmacol 26:1549–1557.901575
Goldstein JA, Friesen M, Scotti TM, . 1978. Assessment of the contribution of chlorinated dibenzo-p-dioxin and dibenzofurans to hexachlorobenzene toxicity, porphyria, changes in mixed function oxygenases, and histopathological changes. Toxicol Appl Pharmacol 46:633–649.106491
*Goldstein JA, Hickman P, Bergman H, . 1973. Hepatic porphyria induced by 2,3,7,8-tetrachlorodibenzo-p-dioxin in the mouse. Res Commun Chem Pathol Pharmacol 6:919–928.4760898
*Goldstein JA, Linko P, Bergman H. 1982. Induction of porphyria in the rat by chronic versus acute exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Biochem Pharmacol 31:1607–1613.7092952
*Goldstein JA, Safe S. 1989. Mechanism of action and structure-activity relationships for the chlorinated dibenzo-p-dioxins and related compounds. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, naphthalenes, dibenzodioxins and related compounds, 2nd ed. Amsterdam: Elsevier Science Publishers B.V., 239–293.
Golor G, Neubert D. 1989. EROD (ethoxyresorufin-o-deethylase) activity in rat liver tissue after application of TCDD and OCDD alone and in combination [Abstract]. Naunyn Schmiedeberg’s Arch Pharmacol 339:10.
Goodman DG, Sauer RM. 1992. Hepatotoxicity and carcinogenicity in female Sprague-Dawley rats treated with 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD): A pathology working group reevaluation. Regul Toxicol Pharmacol 15(3):245–252.1509118
*Gordon CJ, Gray LE, Jr., Monteiro-Riviere NA, . 1995. Temperature regulation and metabolism in rats exposed perinatally to dioxin: Permanent change in regulated body temperature? Toxicol Appl Pharmacol 133:172–176.7597705
*Gorski JR, Muzi G, Weber LW, . 1988a. Elevated plasma corticosterone levels and histopathology of the adrenals and thymuses in 2,3,7,8-tetrachlorodibenzo-p-dioxin-treated rats. Toxicology 53:19–32.3201474
*Gorski JR, Muzi G, Weber LWD, . 1988b. Some endocrine and morphological aspects of the acute toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Toxicologic Pathology 16:313–320.3057589
*Gorski JR, Rozman K. 1987. Dose-response and time course of hypothyroxinemia and hypoinsulinemia and characterization of insulin hypersensitivity in 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD)-treated rats. Toxicology 44:297–307.3554617
*Gorski JR, Rozman T, Greim H, . 1988c. Corticosterone modulates acute toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in male Sprague-Dawley rats. Fundam Appl Toxicol 11:494–502.3220219
*Gorski JR, Weber LWD, Rozman K. 1990. Reduced gluconeogenesis in 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD)-treated rats. Arch Toxicol 64:66–71.2306197
Gorski T. 1981. Presence of polychlorinated dibenzo-p-dioxins in latex nipples. Bull Environ Contam Toxicol 27:68–71.7296039
Gorski T, Konopka L, Brodzki M. 1984. Persistence of some polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans of pentachlorophenol in human adipose tissue. Rocz Panstw Zakl Hig 35:297–301.6522993
Gotz R. 1986. Chlorinated dioxin and dibenzofurans in leachate and sediments of the sanitary landfill in Hamburg-Georgswerder. Chemosphere 15:1981–1984.
*Gough M. 1991. Human exposure from dioxin in soil-a meeting report. J Toxicol Environ Health 32:205–245.1995928
Graham M, Hileman FD, Orth RG, . 1986. Chlorocarbons in adipose tissue from a Missouri population. Chemosphere 15:1595–1600.
Grahmann R, Claus D, Grehl H, . 1993. Electrophysiologic evidence for a toxic polyneuropathy in rats after exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). J Neurol Sci 115(1):71–75.8385708
Grainger J, Reddy VV, Patterson DG Jr. 1988. Analysis of tetra-through octachlorinated dibenzo-p-dioxins by gas chromatography/Fourier transform infrared spectroscopy. Chemosphere 19:249–254.
Gray AP, Cepa SP, Dipinto VM, . 1975. Chlorinated dibenzodioxins and dibenzofurans. In: Hemphill DD, ed. Trace substances in environmental health-IX. Columbia, MO: University of Missouri, 255–263.
*Gray J LE, Ostby JS, Kelce WR. 1997b. A dose-response analysis of the reproductive effects of a single gestational dose of 2,3,7,8-tetrachlorodibenzo-p-dioxin in male Long Evans Hooded rat offspring. Toxicol Appl Pharmacol 146:11–20.9299592
*Gray J LE, Wolf C, Mann P, . 1997a. In utero exposure to low doses of 2,3,7,8-tetrachlorodibenzo-p-dioxin alters reproductive development of female Long Evans Hooded rat offspring. Toxicol Appl Pharmacol 146:237–244.9344891
*Gray LE, Jr., Kelce WR, Monosson E, . 1995. Exposure to TCDD during development permanently alters reproductive function in male Long Evans rats and hamsters: Reduced ejaculated and epididymal sperm numbers and sex accessory gland weights in offspring with normal androgenic status. Toxicol Appl Pharmacol 131:108–118.7878665
*Gray LE, Jr., Ostby JS. 1995. In utero 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) alters reproductive morphology and function in female rate offspring. Tox Appl Pharm 133:285–294.
Green S, Moreland FS. 1975. Cytogenetic evaluation of several dioxins in the rat. Toxicol Appl Pharmacol 33:161.
*Green S, Moreland, Sheu C. 1977. Cytogenic effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin on rat bone marrow cells. Washington, DC: Food and Drug Administration. FDA by-lines 6:292.
*Greenlee WF, Dold KM, Irons RD, . 1985. Evidence for direct action of 2,3,7,8-TCDD on thymic epithelium. Toxicol Appl Pharmacol 79:112–120.2996175
Greenlee WF, Osborne R, Hudson LG, . 1984. Studies on the mechanisms of toxicity of TCDD to human epidermis. Banbury Rep. Biological Mechanisms Dioxin Action 18:365–372.
Greenwald P, Kovasznay B, Collins D, . 1984. Sarcomas of soft tissues after Vietnam service. J Natl Cancer Inst 73:1107–1109.6593486
*Grehl H, Grahmann F, Claus D, . 1993. Histologic evidence for a toxic polyneuropathy due to exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in rats. Acta Neurol Scand 88:354–357.8296535
Greig JB. 1979. The toxicology of 2,3,7,8-tetrachlorodibenzo-p-dioxin and its structural analogues. Ann Occup Hyg 22:411–420.547800
*Greig JB. 1984. Differences between skin and liver toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin in mice. Banbury Rep Biological Mechanisms Dioxin Action 18:391–397.
Greig JB, Francis JE, Kay SJ, . 1984. Incomplete correlation of 2,3,7,8-tetrachlorodibenzo-p-dioxin hepatotoxicity with Ah phenotype in mice. Toxicol Appl Pharmacol 74:17–25.6729820
*Greig JB, Francis JE, Kay SJ, . 1987. Pleiotropic effect of the gene hairless on hepatotoxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin in mice. Arch Toxicol 60:350–354.3662807
Greim H. 1990. Toxicological evaluation of emission from modern municipal waste incinerators. Chemosphere 20:317–331.
*Gross ML, Lay JO Jr, Lyon PA, . 1984. 2,3,7,8-Tetrachlorodibenzo-p-dioxin levels in adipose tissue of Vietnam veterans. Environ Res 33:261–268.6692811
*Guo YL, Lin CJ, Yao WJ, . 1994. Musculoskeletal changes in children prenatally exposed to polychlorinated biphenyls and related compounds (Yu-Cheng children). J Toxicol Environ Health 41:83–93.8277528
*Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: implications for risk assessment. International Life Sciences Institute Press, Washington, D.C.
*Ha M-C, Cordier S, Bard D, . 1996. Agent orange and the risk of gestational trophoblastic disease in Vietnam. Arch Environ Health 51:368–374.8896386
*Haake JM, Safe S, Mayura K, . 1987. Aroclor 1254 as an antagonist of the teratogenicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Lett 38:299–306.2821658
Hagenmaier H. 1986. Determination of 2,3,7,8-TCDD in commercial chlorophenols and related products. Fresenius Z Anal Chem 325:603–606.
Hagenmaier H, Brunner H. 1987. Isomer specific analysis of pentachlorophenol and sodium pentachlorophenate on 2,3,7,8-substituted PCDD and PCDF at sub-ppb levels. Chemosphere 16:1759–1764.
Hagenmaier H, Kraft M, Brunner H, . 1987. Catalytic effects of fly ash from waste incineration facilities on the formation and decomposition of polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans. Environ Sci Technol 21:1080–1084.
Hagenmaier H, Kraft M, Jager W, . 1986. Comparison of various sampling methods for PCDDs and PCDFs in stack gas. Chemosphere 15:1187–1192.
*Hagenmaier H, Wiesmueller T, Golor G, . 1990. Transfer of various polychlorinated dibenzo-p-dioxins and dibenzofurans (PCDDs and PCDFs) via placenta and through milk in a marmoset monkey. Arch Toxicol 64:601–615.2128593
Hahn JL, Von Dem Fange HP, Velzy CO. 1986. Effect of boiler operation and RDF feedstock on emissions of dioxins and furans from an RDF fired spreader-stoker system in Albany, NY. Chemosphere 15:1239–1246.
Hahn JL, Von Dem Fange HP, Westerman G. 1989a. A comparison of ambient and workplace dioxin levels from testing in and around modern resource recovery facilities with predicted ground level concentrations of dioxins from emission testing with corresponding workplace health risks. Chemosphere 19:629–636.
*Hahn ME, Goldstein JA, Linko P, . 1989b. Interaction of hexachlorobenzene with the receptor for 2,3,7,8-tetrachlorodibenzo-p-dioxin in vitro and in vivo: Evidence that hexachlorobenzene is a weak Ah receptor agonist. Arch Biochem Biophys 270:344–355.2539049
*Håkansson H, Hanberg A. 1989. The distribution of [14C]-2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) and its effect of the vitamin A content in parenchymal and stellate cells of rat liver. J Nutr 119:573–580.2703915
*Håkansson H, Johansson L, Ahlborg UG, . 1989a. Hepatic vitamin A storage in relation to paired restriction and to TCDD-treatment. Chemosphere 19:919–920.
*Håkansson H, Johansson L, Manzoor E, . 1989b. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD)-induced alterations in the vitamin A homeostasis and in the 7-ethoxyresorufin O-deethylase (EROD)-activity in Sprague-Dawley rats and Hartley guinea pigs. Chemosphere 18:299–305.
*Håkansson H, Waern F, Ahlborg UG. 1987. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in the lactating rat on maternal and neonatal vitamin A status. J Nutr 117:580–586.3572570
*Hallett DJ, Brooksbank MG. 1986. Trends of TCDD and related compounds in the Great Lakes: The Lake Ontario ecosystem. Chemosphere 15:1405–1416.
Hammel KE, Kalyanaraman B, Kirk TK. 1986. Oxidation of polycyclic aromatic hydrocarbons and dibenzo(p)dioxins by Phanerochaete Chrysosporium Ligninase. J Biol Chem 261:16948–16952.3023375
*Hanberg A, Håkansson H, Ahlborg UG. 1989. “ED50” values for TCDD-induced reduction of body weight gain, liver enlargement, and thymic atrophy in Hartley guinea pigs, Sprague-Dawley rats, C57BL/6 mice, and golden Syrian hamsters. Chemosphere 19:813–816.
*Hanify JA, Metcalf P, Nobbs, CL, . 1981. Aerial spraying of 2,4,5-T and human birth malformations: An epidemiological investigation. Science 212:349–351.7209535
*Hankinson O. 1979. Single-step selection of clones of a mouse hepatoma cell line deficient in aryl hydrocarbon hydroxylase. Proc Natl Acad Sci USA 76:373–376.106390
*Hankinson O. 1995. The aryl hydrocarbon receptor complex. Ann Rev Pharmacol Toxicol 35:307–340.7598497
Hanson DJ. 1987. Science failing to back up veteran concerns about Agent Orange. Chem Eng News. November 9, 7–11, 14.
Hansson M, Rappe C, Gochfeld M, . 1989. Effects of fasting on the blood levels of 2,3,7,8-TCDD and related compounds. Chemosphere 18:525–530.
Haraguchi K, Yamashita T, Shigemori N. 1985. [Sampling and analysis of phosphoric acid triesters in ambient air.] Taiki Osen Gakkaishi 20:407–415. (Japanese).
*Hardell L. 1986. Some aspects of exposure to polychlorinated dibenzo-p-dioxins and dibenzofurans in the ecological system. In: Morris CR, Cabral JRP, eds. Hexachlorobenzene: Proceedings of an International Symposium 77:243–247.
*Hardell L, Erikksson M, Degereman A. 1995. Meta-analysis of four Swedish case-control studies on exposure to pesticides as risk-factor for soft-tissue sarcoma including the relation to tumour localization and histopathological type. Int J Oncol 6:847–851.21556610
*Hardell L, Eriksson M. 1988. The association between soft tissue sarcomas and exposure to phenoxyacetic acids, a new case referent study. Cancer 62:652–656.3390800
*Hardell L, Eriksson M, Axelson O, . 1994. Cancer epidemiology. In: Schecter A, ed. Dioxins and health. Plenum Press, NY, 525–547.
*Hardell L, Eriksson M, Lenner P, . 1981. Malignant lymphoma and exposure to chemicals, especially organic solvents, chlorophenols and phenoxy acids: A case-control study. Br J Cancer 43:169–176.7470379
*Hardell L, Sandstrom A. 1979. Case-control study: Soft-tissue sarcomas and exposure to phenoxyacetic acids and chlorophenols. Brit J Cancer 39:711–717.444410
*Hardin ED, Hayes DA, Shore FL, . 1989. A comparison of analytical methods for the analysis of chlorinated dioxin/dibenzofuran in pyrolyzed transformer oil samples. Chemosphere 18:1093–1100.
Harless RL, Lewis RG. 1989. Identification of bromo/chloro dibenzo-p-dioxins and dibenzofurans in ash samples. Chemosphere 18:201–208.
Harless RL, Lewis RG, McDaniel DD, . 1992. Evaluation of a sampling and analysis method for determination of polyhalogenated dibenzo-p-dioxins and dibenzofurans in ambient air. Chemosphere 25(7–10):1317–1322.
*Harless RL, Oswald EO, Lewis RG, . 1982. Determination of 2,3,7,8-tetrachlorodibenzo-p-dioxin in freshwater fish. Chemosphere 2:193–198.
Harms H, Wittich RM, Sinnwell V, . 1990. Transformation of dibenzo-p-dioxin by Pseudomonas sp. strain HH69. Appl Environ Microbiol 56:1157–1159.16348160
*Harper PA, Prokipcak RD, Bush LE, . 1991. Detection and characterization of the Ah receptor in the human colon adenocarcinoma cell line LS 180. Arch Biochem Biophys 290:27–36.1654865
*Harris M, Piskorska-Pliszczynska J, Zacharewski T, . 1989a. Structure-dependent induction of aryl hydrocarbon hydroxylase in human breast cancer cell lines and characterization of the Ah receptor. Cancer Res 49:4531–4545.2545344
*Harris M, Zacharewski T, Astroff B, . 1989b. Characterization of 6-methyl-1,3,8-trichloro-dibenzofuran (MCDF) as a 2,3,7,8-TCDD antagonist in male rats: Induction of monooxygenases. Chemosphere 19:769–772.
*Harris M, Zacharewski T, Piskorska-Pliszczynska J, . 1990. Structure-dependent induction of aryl hydrocarbon hydroxylase activity in C57BL/6 mice by 2,3,7,8-tetrachlorodibenzo-p-dioxin and related congeners: Mechanistic studies. Toxicol Appl Pharmacol 105:243–253.2219118
*Hashimoto S, Ito H, Morita M. 1992. Elution of polychlorinated dibenzo-p-dioxins and dibenzofurans from coffee filter papers. Chemosphere 25(3):297–305.
Hass JR, Friesen MD, Parker CE, . 1977. Use of negative-ion chemical ionization mass spectrometry in the determination of polychlorodibenzo-p-dioxins at the part-per-trillion level in tissue samples. Environ Health Perspect 20:246.
*Hassan MQ, Mohammadpour H, Hermansky SJ, . 1987. Comparitive effects of BHA and ascorbic acid on the toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in rats. Gen Pharmacol 5:547–550.
*Hassoun E, D’Argy R, Dencker L, . 1984a. Teratogenicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin in BXD recombinant inbred strains. Toxicol Lett 23:37–42.6485016
*Hassoun EA. 1987. In vivo and in vitro interactions of TCDD and other ligands of the Ah-receptor: Effect on embryonic and fetal tissues. Arch Toxicol 61:145–149.2830866
*Hattemer-Frey HA, Travis CC. 1989. Comparison of human exposure to dioxin from municipal waste incineration and background environmental contamination. Chemosphere 18:643–649.
*Hauge PM, Belton TJ, Ruppel BE, . 1994. 2,3,7,8-TCDD and 2,3,7,8-TCDF in Blue crabs and American lobsters from the Hudson-Raritan estuary and the New York Bight. Bull Environ Contam Toxicol 52(5):734–741.8186646
Hawker D. 1990. Description of fish bioconcentration factors in terms of solvatochromic parameters. Chemosphere 20:467–477.
Hay A. 1982. Toxicology of dioxins. In: The chemical scythe: Lessons of 2,4,5-T and dioxin. New York, London: Plenum Press, 41–47.
*Hayashi S, Watanabe J, Nakachi K, . 1994. Interindividual difference in expression of human Ah receptor and related P450 genes. Carcinogenesis 15:801–806.7515333
*HazDat. 1998. Database. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
Heath RG, Harless RL, Gross ML, . 1986. Determination of 2,3,7,8-tetrachlorodibenzo-p-dioxin in human milk at the 0.1-10 parts-per-trillion level: Method validation and survey results. Anal Chem 58:463–468.3963398
*Hebert C, Gamberg M, Mychasiw L, . 1996. Polychlorinated dibenzodioxins, dibenzofurans and non-ortho polychlorinated biphenyls in caribou (Rangifer tarandus) from the Canadian Arctic. Sci Total Environment 185:195–204.
*Hebert CD, Birnbaum LS. 1987. The influence of aging on intestinal absorption of TCDD in rats. Toxicol Lett 37:47–55.3109077
*Hebert CD, Harris MW, Elwell MR, . 1990. Relative toxicity and tumor-promoting ability of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD), 2,3,4,7,8-pentachlorodibenzofuran (PCDF), and 1,2,3,4,7,8-hexachlorodibenzofuran (HDCF) in hairless mice. Toxicol Appl Pharmacol 102:362–377.2300974
*Hebert CE, Norstrom RJ, Simon M, . 1994. Temporal trends and sources of PCDDs and PCDFs in the Great Lakes: Herring gull egg monitoring, 1981-1991. Environmental Science & Technology 28(7):1268–1277.22176318
*Heimler I, Trewin AL, Chaffin CL, . 1998. Modulation of ovarian follicle maturation and effects on apoptotic cell death in Holtzman rats exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in utero and lactationally. Reprod Toxicol 12:69–73.9431574
Heindl A, Hutzinger O. 1986. Search for industrial sources of PCDD/PCDFs: II. Metal chlorides. Chemosphere 15:653–658.
Heindl A, Hutzinger O. 1987. Search for industrial sources of PCDD/PCDF: III. Short-chain chlorinated hydrocarbons. Chemosphere 16:1949–1957.
*Hellou J, Payne JF. 1993. Polychlorinated dibenzo-p-dioxins and dibenzofurans in cod (Gadus morhua) from the Northwest Atlantic. Mar Environ Res 36(2):117–128.
*Henck JW, New MA, Kociba RJ, . 1981. 2,3,7,8-tetrachlorodibenzo-p-dioxin: Acute oral toxicity in hamsters. Toxicol Appl Pharmacol 59:405–407.7256777
*Henderson LO, Patterson DG Jr. 1988. Distribution of 2,3,7,8-tetrachlorodibenzo-p-dioxin in human whole blood and its association with, and extractability from lipoproteins. Bull Environ Contam Toxicol 40:604–611.3370354
*Henriksen GL, Ketchum NS, Michalek JE, . 1997. Serum dioxin and diabetes mellitus in veterans of operation ranch hand. Epidemiology 8:252–258.9115019
*Henriksen GL, Michalek JE, Swaby JA, . 1996. Serum dioxin, testosterone, and gonadotropins in veterans of operation ranch hand. Epidemiology 7:352–357.8793359
*Henry EC, Gasiewicz TA. 1986. Effects of thyroidectomy on the Ah receptor and enzyme inducibility by 2,3,7,8-tetrachlorodibenzo-p-dioxin in the rat liver. Chem-Biol Interact 59:29–42.3019582
*Henry EC, Gasiewicz TA. 1987. Changes in thyroid hormones and thyroxine glucuronidation in hamsters compared with rats following treatment with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 89:165–174.3111013
*Henry EC, Gasiewicz TA. 1993. Transformation of the aryl hydrocarbon receptor to a DNA-binding form is accompanied by release of the 90 kDA heat-shock protein and increased affinity for 2,3,7,8-tetrachlorodibenzo-p-dioxin. Biochem J 294: 95–101.8395819
*Henry EC, Rucci G, Gasiewicz TA. 1994. Purification to homogeneity of the heteromeric DNA-binding form of the Ah receptor from rat liver. Mol Pharmacol 46:1022–1027.7808420
Henry S, Cramer G, Bolger M, . 1991. Exposures and risks of dioxin in the U.S. food supply. Proceedings of the 11th International Symposium on Chlorinated Dioxins and Related Compounds, Research Triangle Park, NC, 1–18.
*Hermansky SJ, Holczlaw TL, Murray WJ, . 1988. Biochemical and functional effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in the heart of female rats. Toxicol Appl Pharmacol 95:175–184.3420610
*Hermansky SJ, Mohammadpour HA, Murray WJ, . 1987. Effect of thyroidectomy on 2,3,7,8-tetrachlorodibenzo-p-dioxin-induced lipid peroxidation. Pharmacology 35(6):301–7.3432353
*Hesso A, Hameila M, Tornaeus J. 1992. Poly chlorinated dioxins, furans and non-ortho polychlorinated biphenyls in blood of exposed laboratory personnel. Chemosphere 25:1053–1059.
*Hilardes RJ, Gray KA, Guzzetta J, . 1994. Radiolytic degradation of 2,3,7,8,-TCDD in artificially contaminated soils. Environ Sci Techol 28(13):2249–2258.
*Hippelein M, Kaupp H, Doerr G, . 1993. Testing of a sampling system and analytical method for determination of semivolatile organic compounds in ambient air. Chemosphere 26(12):2255–2263.
Hiraoka M, Takizawa Y, Masuda Y, . 1987. Investigation of generation of dioxins and related compounds from municipal incinerators in Japan. Chemosphere 16:1901–1906.
Hiremath C, Bayliss D, Bayard S. 1986. Qualitative and quantitative cancer risk assessment of 2,3,7,8-tetrachlorodibenzo-p-dioxin (2,3,7,8-TCDD). Chemosphere 15:1815–1823.
*Hirose K, Morita M, Ema M, . 1996. cDNA cloning and tissue-specific expression of a novel basic helix-loop-helix/PAS factor (Arnt2) with close sequence similarity to the aryl hydrocarbon receptor nuclear translocator (Arnt). Mol Cell Biol 16:1706–1713.8657146
*Hites R, Harless R. 1991. Atmospheric transport and deposition of polychlorinated dibenzo-p-dioxins and dibenzofurans. Office of Research and Development, US Environmental Protection Agency, Research Triangle Park, NC. EPA/600/3-91/002.
Hoang TQ, Dai LC, Hong Thom LT. 1989. Effects of geographical conditions, soil movement and other variables on the distribution of 2,3,7,8-TCDD levels in adipose tissues from Vietnam: Preliminary observations. Chemosphere 18:967–974.
*Hochstein JR, Aulerich RJ, Bursian SJ. 1988. Acute toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin to mink. Arch Environ Contam Toxicol 17:33–37.3337552
*Hodson PV, McWhirter M, Ralph K, . 1992. Effects of bleached draft mill effluent on fish in the St. Maurice River, Quebec. Environ Toxicol Chem 11(11):1635–1651.
*Hoffman R, Stehr-Green PA, Webb KB, . 1986. Health effects of long-term exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. JAMA 255 (15):2031–2038.3959286
*Holcomb M, Yao C, Safe S. 1988. Biologic and toxic effects of polychlorinated dibenzo-p-dioxin and dibenzofuran congeners in the guinea pig: Quantitative structure-activity relationships. Biochem Pharmacol 37:1535–1539.3358783
Holden C. 1979. Agent Orange furor continues to build. Science 205:77–772.
*Holder JW, Menzel HM. 1989. Analysis of 2,3,7,8-TCDD tumor promotion activity and its relationship to cancer. Chemosphere 19:861–868.
*Holladay SD, Lindstrom P, Blaylock BL, . 1991. Perinatal thymocyte antigen expression and postnatal immune development altered by gestational esposure to tetrachlorodibenzo-p-dioxin (TCDD). Teratology 44(4):385–393.1683717
*Holmstedt B. 1980. Prolegomena to Seveso, Ecclesiastes 1:18. Arch Toxicol 44:211–230.6994683
*Holsapple MP, Dooley RK, McNerney PJ, . 1986a. Direct suppression of antibody-responses by chlorinated dibenzodioxins in cultured spleen-cells from (C57BL/6XC3H)F1 and DBA/2 mice. Immunopharmacology 12:175–186.3818259
*Holsapple MP, McCay JA, Barnes DW. 1986b. Immunosuppression without liver induction by subchronic exposure to 2,7-dichlorodibenzo-p-dioxin in adult female B6C3F1 mice. Toxicol Appl Pharmacol 83:445–455.3486501
Holsapple MP, Snyder NK, Wood SC, . 1991. A review of 2,3,7,8-tetrachlorodibenzo-p-dioxin-induced changes in immunocompetence: 1991 Update. Toxicology 69(3):219–256.1949050
*Hong LH, McKinney JD, Luster MI. 1987. Modulation of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD)-mediated myelotoxicity by thyroid hormones. Biochem Pharmacol 36:1361–1365.3036167
*Hong R, Taylor K, Abonour R. 1989. Immune abnormalities associated with chronic TCDD exposure in rhesus. Chemosphere 18:313–320.
*Hooiveld M, Heederil DJJ, Kogevinas M, . 1998. Second follow-up of a Dutch cohort occupationally exposed to phenoxy herbicides, chlorophenols, and contaminants. Am J Epidemiol 147:891–901.9583720
Horaguchi M, Ogawa H, Ose K, . 1989. PCDDs and PCDFs from the MSW incinerator. Chemosphere 18:1785–1797.
*Hortsmann M, McLachlan M. 1994. Textiles as a source of CDD/CDF in human skin and sewage sludge. Environ Science and Pollution Research 1(1):15–20.
*House RV, Lauer LD, Murray MJ. 1990. Examination of immune parameters and host resistance mechanisms in B6C3F1 mice following adult exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Toxicol Environ Health 31:203–215.1700136
Hryhorczuk DO, Orris P, Kominsky JR, . 1986. PCB, PCDF, and PCDD exposure following a transformer fire: Chicago. Chemosphere 15:1297–1303.
*HSDB. 1995. Hazardous Substance Databank. National Library of Medicine, Bethesda, MD. March 13, 1993.
*Hsu C-C, Yu M-LM, Chen Y-CJ, . 1994. The Yu-Cheng rice oil poisoning incident. In: Schecter A, ed. Dioxins and health, New York, NY: Plenum Press, 661–684.
*Huang ZJ, Edery I, Rosbash M. 1993. PAS is a dimerization domain common to Drosophila Period and several transcription factors. Nature 364:256–262.
*Hudson LG, Toscano WA Jr, Greenlee WF. 1985. Regulation of epidermal growth factor binding in human keratinocyte cell line by 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 77:251–259.2579474
Huetter R, Philippi M. 1982. Studies on microbial metabolism of TCDD under laboratory conditions. Pergamon Ser Environ Sci 5:87–93.
Huff JE, Moore JA, Saracci R, . 1980. Long-term hazards of polychlorinated dibenzodioxins and polychlorinated dibenzofurans. Environ Health Perspect 36:221–240.6448744
Huff JE, Salmon AG, Hooper NK, . 1991. Long-term carcinogenesis studies on 2,3,7,8-tetrachlorodibenzo-p-dioxin and hexachlorodibenzo-p-dioxins. Cell Biol Toxicol 7(1):67–94.2054688
Huff JE, Wassom JS. 1973. Perspective on chlorinated dibenzodioxins and dibenzofurans. Environ Health Perspect 5:283–313.4584793
*Huisman M, Koopman-Esseboom C, Fidler V, . 1995a. Perinatal exposure to polychlorinated biphenyls and dioixins and its effect on neaonatal neurological developement. Early Hum Develop 41:111–127.
*Huisman M, Koopman-Esseboom C, Lanting CI, . 1995b. Neurological condition in 18-month-old children perinatally exposed to polychlorinated biphenyls and dioxins. Early Hum Dev 43:165–176.8903761
*Hulster A, Marschner H. 1993. Transfer of PCDD-PCDF from contaminated soils to food and fodder crop plants. Twelfth international symposium on chlorinated dioxins and related compounds. Tampere, Finland. Chemosphere 27(1–3):439–446.
*Hulster A, Muller J, Marschner H. 1994. Soil-Plant trasfer of Polychlorinated dibenzo-p-diozins to vegetables of the cucumber family (Curcurbitaceae) Envir Sci Technol 28(6):1110–1115.
Hung LS, Ingram LL Jr. 1990. Effects of solvents on the photodegradation rates of octachlorodibenzo-p-dioxin. Bull Environ Contam Toxicol 44:380–386.2328345
Hungerford CM. 1988. Comments on behalf of Syntex Agribusiness Inc., in response to Draft Toxicological Profile for 2,3,7,8-Tetrachlorodibenzo-p-dioxin. February 11, 1988.
*Hunt GT, Maisel BE. 1992. Atmospheric concentrations of PCDDs/PCDFs in southern California. J Air Wast Manage Assoc 42(5):672–680.
*Huntley SL, Iannuzzi TJ, Avantaggio JD, . 1997. Combined sewer overflows (CSOs) as sources of sediment contamination in the lower Passaic River, New Jersey : Polychlorinated dibenzo-p-dioxins, polychlorinated dibenzofurans, and polychlorinated biphenyls. Chemosphere 34(2):233–250.
*Hussain S, Ehrenberg L, Lofroth G, . 1972. Mutagenic effects of TCDD on bacterial systems. Ambio 1:32–33.
*Hutzinger O, Blumich MJ, Berg M, . 1985. Sources and fate of PCDDs and PCDFs: An overview. Chemosphere 14:581–600.
Hutzinger O, Fiedler H. 1993. Form source to exposure: Some open questions. Chemosphere 27(ISS 1–3):121–129.
Hutzinger O, Olie K, Lustenhouwer JWA, . 1981. Polychlorinated dibenzo-p-dioxins and dibenzofurans: A bioanalytical approach. Chemosphere 10:19–25.
*Huuskonen H, Undila M, Pohjanvirta R, . 1994. Developmental toxicity of 2,3,7,8-tetrachloro-dibenzo-p-dioxin (TCDD) in the most TCDD-resistant and -susceptible rat strains. Toxicol Appl Pharmacol 124(2):174–80.8122262
*IARC. 1977. IARC monographs on the evaluation of the carcinogenic risk of chemicals to man: Some fumigants, the herbicides 2,4-D and 2,4,5-T, chlorinated dibenzodioxins and miscellaneous industrial chemicals. Lyon, France: World Health Organization, International Agency for Research on Cancer. IARC Monogr 15:41–102.
IARC. 1982. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans: Chemicals, industrial processes, and industries associated with cancer in humans. Lyon, France: World Health Organization, International Agency for Research on Cancer. IARC Monogr Suppl 4:238–243.
*IARC. 1986a. IARC mongraphs on the evaluation of carcingenic risks to humans. Occupational exposures to chlorophenols. Lyon, France: World Health Organization, International Agency for Research on Cancer. IARC Monogr 41:319–337.
*IARC. 1986b. IARC mongraphs on the evaluation of carcingenic risks to humans. Occupational exposures to chlorophenoxy herbicides. Lyon, France: World Health Organization, International Agency for Research on Cancer. IARC Monogr 41:357–377.
*IARC. 1987. IARC mongraphs on the evaluation of carcingenic risks to humans. Overall evaluations of carcinogenicity: an updating of IARC monographs volumes 1 to 42. Lyon, France: World Health Organization, International Agnecy for Research on Cancer. IARC Monogr Suppl F.
*IARC. 1987. IInternational Agency for Research on Cancer. IARC monographs on the evaluation of carcinogenic risks to humans. Overall evaluations of carcinogenicity: an updating of IARC monographs volumes 1 to 41. Supplement 7. Lyone, France. 1987. International Agency for Research on Cancer. World Health Organization.
*IARC. 1997. International Agency for Research on Cancer. IARC Monographs on the Evaluation of Carcinogenic Risks to Humans: Polychorinated Dibenzo-para-dioxins and Polychlorinated Dibenzofurans (vol. 69). Summary Statements. http://www.iarc.fr/publications/vol69.htm. May 8, 1997.
*IARC. 1997. International Agency for Research on Cancer. Monographs database. Polychlorinated Dibenzo-para-Dioxins, http://www.iarc.fr. and http://193.51.164.11/htdocs/monographs/Vol69/dioxin.html. International Agency for Research on Cancer. World Health Organization.
ICRP (International Commission on Radiological Protection). 1981. Report of the Task Group on Reference Man. ICRP Publication No. 23. Pergamon Press.
*Ideo G, Bellati G, Bellobuono A, . 1982. Increased urinary D-glucaric acid excretion by children living in an area polluted with 2,3,7,8-tetrachlorodibenzo-para-dioxin (TCDD). Clin Chim Acta 120:273–283.7074964
*Iida T, Hirakawa H, Matsueda T, . 1991. [Therapeutic trial for promotion of fecal excretion of PCDFs and PCBs by the adminstration of cholestyramine in Yusho patients.] Fukuoka Ishi 82:317–325. (Japanese)
*Ilsen A, Briet JM, Koppe JG, . 1996. Signs of enhanced neuromotor maturation in children due to perinatal load with background levels of dioxins. Chemosphere 33:1317–1326.8799996
*Imamura M, Tung T-C. 1984. A trial of fasting cure for PC-poisoned patients in Taiwan. Am J Ind Med 5:147–153.6422746
*Ireland RC, Li S-Y, Dougherty JJ. 1995. The DNA binding of purified Ah receptor heterodimer is regulated by redox conditions. Arch Biochem Biophys 319:470–480.7786030
*IRIS. 1997. Integrated risk informaiton system. Hexachloradibenzo-p-dioxin, mixture (HxCDD). CASRN 1940-74-3. U. S. Environmental Protection Agency. Integrated risk informaiton system. http://www.epa.gov/ngispgm3/iris/subst/0166.htm. March 1, 1997.
*Isensee AR. 1978. Bioaccumulation of 2,3,7,8-tetrachlorodibenzo-para-dioxin. Ecol Bull. (Stockholm) 27:255–262.
Isensee AR, Jones GE. 1971. Absorption and translocation of root and foliage applied 2,4-dichlorophenol, 2,7-dichlorodibenzo-p-dioxin, and 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Agr Food Chem 19:1210–1214.5167247
Isensee AR, Jones GE. 1975. Distribution of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in aquatic model ecosystems. Environ Sci Technol 9:668–672.
Isnard P, Lambert S. 1988. Estimating bioconcentration factors from octanol-water partition coefficient and aqueous solubility. Chemosphere 17:21–34.
Isnard P, Lambert S. 1989. Aqueous solubility and n-octanol/water partition coefficient correlations. Chemosphere 18:1837–1853.
*Israel DI, Estolano MG, Galeazzi DR, . 1985. Superinduction of cytochrome Pi-450 gene transcription by inhibition of protein synthesis in wild type and variant mouse hepatoma cells. J Biol Chem 260:5648–5653.2985607
*James WH. 1997. The sex ratio of offspring sired by men exposed to wood preservatives contaminated by dioxin. Scand J Work Environ Health 23:69.
*Jansing P-J, Korff R. 1994. Blood levels of 2,3,7,8-tetrachlorodibenzo-p-dioxin and -globulins in a follow-up investigation of employees with chloracne. J Dermatol Sci 8:91–95.7530995
*Jarman WM, Burns SA, Chang RR, . 1993. Determination of PCDDS, PCDFS, and PCBS in California Peregrine falcons (FALCO PEREGRINUS) and their eggs. Environ Toxic Chem 12(1):105–114.
*Jasinski JS. 1989. Multiresidue procedures for the determination of chlorinated dibenzodioxins and dibenzofurans in a variety of foods using capillary gas chromatography-electron-capture detection. J Chromatogr 478:349–367.2600146
*Jennings AM, Wild G, Ward JD, . 1988. Immunological abnormalities 17 years after accidental exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Br J Ind Med 45:701–704.3264183
Jensen AA. 1987. Polychlorobiphenyls (PCBs), polychlorodibenzo-p-dioxins (PCDDs) and polychlorodibenzofurans (PCDFs) in human milk, blood and adipose tissue. Sci Total Environ 64:259–293.3110947
*Jensen DJ, Hummel RA, Mahle NH, . 1981. A residue study on beef cattle consuming 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Agric Food Chem 29:265–268.7229210
*Jirasek L, Kalensky J, Kubec K, . 1976. [Chloracne, porphyria cutanea tarda and other intoxication by herbicides.] Hautarzt 27:328–333. (German)134006
*Jobb B, Uza M, Hunsinger R, . 1990. A survey of drinking water supplies in the Province of Ontario for dioxins and furans. Chemosphere 20(10–12):1553–1558.
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Research 190:3–16.6769537
*Johnson ES. 1993. Important aspects of the evidence for TCDD carcinogenicity in man. Environ Health Perspect 99:383–390.8319655
*Johnson KL, Cummings AM, Birnbaum LS. 1997. Promotion of endometriosis in mice by polychlorinated dibenzo-p-dioxins, dibenzofurans, and biphenyls. Environ Health Perspect 105:750–755.9294722
*Johnson L, Dickerson R, Safe SH, . 1992. Reduced Leydig cell volume and function in adult rats exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin without a significant effect on spermatogenesis. Toxicology 76(2):103–118.1462355
Johnson RL, Gehring PJ, Kociba RJ, . 1973. Chlorinated dibenzodioxins and pentachlorophenol. Environ Health Perspect 5:171–175.4270942
Jones D, Safe E, Morcum E, . 1989. Bioavailability of grain and soil-borne tritiated 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) administered to lactating Holstein cows. Chemosphere 18:1257–1263.
*Jones EL, Krizek HA. 1962. A technique for testing acnegenic potency in rabbits applied to the potent acnegen 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Invest Dermatol 39:511–517.13964713
*Jones K. 1995. Diesel engine emissions and the link to human dioxin exposure. Dioxin 95 Secretariat, Edmonton AB Canada Organohalogen Compounds 24:69–74.
Jones KC, Bennett BG. 1989. Human exposure to environmental polychlorinated dibenzo-p-dioxins and dibenzofurans: An exposure commitment assessment for 2,3,7,8-TCDD. Sci Total Environ 78:99–116.2717930
*Jones KG, Sweeney GD. 1977. Association between induction of aryl hydrocarbon hydroxylase and depression of uroporphyrinogen decarboxylase activity. Res Commun Chem Pathol Pharmacol 17:631–637.897351
*Jones KG, Sweeney GD. 1980. Dependence of the porphyrogenic effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin upon inheritance of aryl hydrocarbon hydroxylase responsiveness. Toxicol Appl Pharmacol 54:42–49.
*Jones KW, Whitlock JP Jr. 1990. Functional analysis of the transcriptional promoter for the CYP1A1 gene. Mol Cell Biol 10:5098–5105.2398886
*Jones PBC, Durrin LK, Galeazzi DR, . 1986. Control of cytochrome Pi-450 gene expression: analysis of a dioxin-responsive enhancer system. Proc Natl Acad Sci USA 83:2802–2806.3010318
*Jones PD, Giesy JP, Newsted JL, . 1994. Accumulation of 2,3,7,8-tetrachlorodibenzo-p-dioxin equivalents by double-crested cormorant (phalacrorax auritus, Pelicaniformes) chicks in the North American Great Lakes. Ecotoxicol Environ Safety 27:192–209.7516285
Jones RE, Chelsky M. 1986. Further discussion concerning porphyria cutanea tarda and TCDD exposure. Arch Environ Health 41:100–103.3521500
Jonsson P, Rappe C, Kjeller L-O. 1993. Pulp-mill related polychlorinated organic compounds in Baltic Sea sediments. Ambio 22(1):37–43.
*Josephson J. 1983. Chlorinated dioxins and furans in the environment. Environ Sci Technol 17:124A–128A.
*Jung D, Berg PA, Edler L, . 1998. Immunologic findings in workers formerly exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin and its congeners. Environ Health Perspect 106(Suppl2):689–695.
*Kahn PC, Gochfeld M, Nygren M, . 1988. Dioxins and dibenzofurans in blood and adipose tissue of Agent Orange-exposed Vietnam veterans and matched controls. JAMA 259:1661–1667.3343772
*Kahr G, Pauliny I, Fercher E. 1990. Destruction of dioxins and furans adsorbed on fly ash in a rotary kiln furnace. Chemosphere 20:1855–1858.
*Kalliokoski P, Kauppinen T. 1990. Complex chlorinated hydrocarbons: Occupational exposure in the sawmill. IARC Sci Publ 104:390–396.
Kaminsky LS, DeCaprio AP, Gierthy JF, . 1985. The role of environmental matrices and experimental vehicles in chlorinated dibenzodioxin and dibenzofuran toxicity. Chemosphere 14:685–695.
*Kang HK, Weatherbee L, Breslin P, . 1987. Soft tissue sarcoma and military service in Vietnam: A case comparison group analysis of hospital patients. J Occup Med 28:1215–1218.
*Kapila S, Yanders AF, Orazio CE, . 1989. Field and laboratory studies on the movement and fate of tetrachlorodibenzo-p-dioxin in soil. Chemosphere 18:1297–1304.
Karasek FW, Dickson LC. 1987. Model studies of polychlorinated dibenzo-p-dioxin formation during municipal refuse incineration. Science 237:754–756.3616606
Karasek FW, Tong HY. 1985. Semi-preparative high-performance liquid chromatographic analysis of complex organic mixtures. J Chromatogr 332:169–179.
*Kawajiri K, Nakachi K, Imai K, . 1990. Identification of genetically high risk individuals to lung cancer by DNA polymorphisms of the cytochrome P450IA1 gene. FEBS Lett 263:131–133.1691986
*Kaye CI, Rao S, Simpson SJ, . 1985. Evaluation of chromosomal damage in males exposed to Agent Orange and their families. J Craniofac Genet Dev Bio 1:259–265.
*KBWP. 1988. Kansas Board of Water Protection. Topeka, KS.
*Kearney PC, Isensee AR, Helling CS, . 1971. Environmental significance of chlorodioxins. In: Chlorodioxins - origin and fate. Advances in Chemistry Series 120:105–111.
Kedderis LB, Andersen ME, Birnbaum LS. 1993b. Effect of dose, time and pretreatment on the biliary excretion and tissue distribution of 2,3,7,8-tetrachlorodibenzo-p-dioxin in the rat. Fundam Appl Toxicol 21(4):405–411.8253293
Kedderis LB, Diliberto JJ, Jackson JA, . 1992. Effects of dose and route of exposure on dioxin disposition. Chemosphere 25(1–2):7–10.
Kedderis LB, Diliberto JJ, Linko P, . 1991a. Disposition of 2,3,7,8-tetrabromodibenzo-p-dioxin and 2,3,7,8-tetrachlorodibenzo-p-dioxin in the rat: Biliary excretion and induction of cytochromes CYP1A1 and CYP1A2. Toxicol Appl Pharmacol 111:163–172.1949032
Kedderis LB, Diliberto JJ, Linko P, . 1991b. Disposition and excretion in intravenous 2,3,7,8-tetrabromodibenzo-p-dioxin (TBDD) in rats. Toxicol Appl Pharmacol 108:397–406.2020967
Kedderis LB, Mills JJ, Anderson ME, . 1993a. A physiologically-based pharmacokinetic model for 2,3,7,8-tetrabromo-dibenzo-p-dioxin (TBDD) in the rat: Tissue distribution and CYP1A induction. Toxicol Appl Pharmacol 121:87–98.8337704
Keenan RE, Sullivan MJ. 1989. Assessing potential health risks of dioxin in paper products. Environ Sci Technol 23:643–644.
*Kelling CK, Christian BJ, Inhorn SL, . 1985. Hypophagia-induced weight loss in mice, rats, and guinea pigs treated with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Fundam Appl Toxicol 5:700–712.4043592
*Kelling CK, Menahan LA, Peterson RE. 1987. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin treatment on mechanical function of the rat heart. Toxicol Appl Pharmacol 91:497–501.3424379
*Kelly TJ, Czuczwa JM, Sticksel PR, . 1991. Atmospheric and tributary inputs of toxic substances to Lake Erie. J Gt Lakes Res 17(4):504–516.
*Kennedy SW, Lorenzen A, Norstrom RJ. 1996. Chicken embryo hepatocyte bioassay for measuring cytochrome P4501A-based 2,3,7,8-tetrachlorodibenzo-p-dioxin equivalent concentrations in environmental samples. Environ Sci Technol 30:706–715.
*Kerger B, Corbett G, El-Sururi S, . 1995. Validating dermal exposure assessment techniques for dioxin using body burden data and pharmacokinetic modeling. Organohalogen Compounds 25:137–141.
*Kerkvliet NI. 1994. Immunotoxicology of dioxins and related chemicals. In: Schecter A, ed. Dioxins and health. New York, NY: Plenum Press, 199–225.
*Kerkvliet NI. 1995. Immunological effects of chlorinated dibenzo-p-dioxins. Environ Health Perspect 103:47–53.
*Kerkvliet NI, Baecher-Steppan L, Shepherd DM, . 1996. Inhibition of TC-1 cytokine production, effector cytotoxic T lymphocyte development and alloantibody production by 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Immunol 157:2310–2319.8805628
*Kerkvliet NI, Baecher-Steppan L, Smith BB, . 1990b. Role of the Ah locus in suppression of cytotoxic T lymphocyte activity by halogenated aromatic hydrocarbons (PCBs and TCDD): Structure-activity relationships and effects in C57Bl/6 mice congenic at the Ah locus. Fundam Appl Toxicol 14:532–541.2111257
Kerkvliet NI, Brauner JA. 1984. Humoral immune suppression by contaminants of technical grade pentachlorophenol with special reference to 1,2,3,4,6,7,8-heptachlorodibenzo-p-dioxin. J Leukoc Biol 36:392.
Kerkvliet NI, Brauner JA. 1987. Mechanisms of 1,2,3,4,6,7,8-heptachlorodibenzo-p-dioxin (HpCDD)-induced humoral immune suppression: Evidence of primary defect in T-cell regulation. Toxicol Appl Pharmacol 87:18–31.3492063
Kerkvliet NI, Brauner JA, Matlock JP. 1985. Humoral immunotoxicity of polychlorinated diphenyl ethers, phenoxyphenols, dioxins and furans present as contaminants of technical grade pentachlorophenol. Toxicology 36:307–324.4049436
*Kerkvliet NI, Steppan LB, Brauner JA, . 1990a. Influence of the Ah locus on the humoral immunotoxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD): evidence for Ah receptor-dependent and Ah receptor independent mechanisms of immunosuppression. Toxicol Appl Pharmacol 105:26–36.2168100
Kew GA, Schaum JL, White P, . 1989. Review of plant uptake of 2,3,7,8-TCDD from soil and potential influence of bioavailability. Chemosphere 18:1313–1318.
*Khera KS, Ruddick JA. 1973. Polychlorodibenzo-p-dioxins: Perinatal effects and the dominant lethal test in Wistar rats. Advances in Chemistry Series 12C:70–84.
*Kieatiwong S, Nguyen LV, Herbert VR, . 1990. Photolysis of chlorinated dioxins in organic solvents and on soils. Environ Sci Technol 24:1575–1580.
Kimbrough RD. 1972. Toxicity of chlorinated hydrocarbons and related compounds. A review including chlorinated dibenzodioxins and chlorinated dibenzofurans. Arch Environ Health 25:125–131.4262558
Kimbrough RD. 1974. The toxicity of polychlorinated polycyclic compounds and related chemicals. CRC Crit Rev Toxicol 2:445–498.4207108
*Kimbrough RD, Carter CD, Liddle JA, . 1977. Epidemiology and pathology of a tetrachlorodibenzodioxin poisoning episode. Arch Environ Health 77–85.557961
*Kimbrough RD, Falk H, Stehr P, . 1984. Health implications of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) contamination of residential soil. J Toxicol Environ Health 14:47–93.6389894
Kimbrough RD, Houk VN. 1987. Effects of chlorinated dibenzodioxins. ACS Symposium Series 338:68–79.
King ME, Shefner AM, Bates RR. 1973. Carcinogenesis bioassay of chlorinated dibenzodioxins and related chemicals. Environ Health Perspect 5:163–170.4752902
King TL, Uthe JF, Musial CJ. 1993. Rapid screening of fish tissue for polychlorinated dibenzo-p-dioxins and dibenzofurans. Analyst 118(10):1269–1275.8273910
*Kissel JC, Robarge GM. 1988. Assessing the elimination of 2,3,7,8-TCDD from humans with a physiologically based pharmacokinetic model. Chemosphere 17:2017–2027.
Kitunen VH, Salkinoja-Salonen MS. 1989. Occurrence of PCDDs and PCDFs in pulp and board products. Chemosphere 19:721–726.
*Klawans HL. 1987. Dystonia and tremor following exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Movement Disorders 2:255–261.2849055
*Klee AJ. 1988. New approaches to the decontamination of hazardous wastes. In: Abbou R, ed. Hazardous waste: Detection, control, treatment. Amsterdam, The Netherlands: Elsevier Science Publishers B.V., 721–729.
*Kleeman JM, Moore RW, Peterson RE. 1990. Inhibition of testicular steroidogenesis in 2,3,7,8-tetrachlorodibenzo-p-dioxin-treated rats: Evidence that the key lesion occurs prior to or during pregnenolone formation. Toxicol Appl Pharmacol 106:112–125.2251676
*Kleeman JM, Olson JR, Chen SM, . 1986a. Metabolism and disposition of 2,3,7,8-tetrachlorodibenzo-p-dioxin in rainbow trout. Toxicol Appl Pharmacol 83:391–401.3705069
*Kleeman JM, Olson JR, Chen SM, . 1986b. 2,3,7,8-Tetrachlorodibenzo-p-dioxin metabolism and disposition in yellow perch. Toxicol Appl Pharmacol 83:402–411.3705070
Kleinveld AJ, Verhoeve P, Nielen MWF. 1989. Evaluation of clean-up methods for the determination of chlorinated aromatic hydrocarbons in fly ash by capillary gas chromatography and mass selective detection. Chemosphere 18:1401–1412.
Kleopfer RD. 1985. 2,3,7,8-TCDD contamination in Missouri. Chemosphere 14:739–744.
Klicius R, Finkelstein A, Hay D. 1988. The national incinerator testing and evaluation program: Air pollution control technology assessment results. Hazard Waste Hazard Mater 5:53–64.
Knutsen AP. 1984. Immunologic effects of TCDD exposure in humans. Bull Environ Contam Toxicol 33:673–681.6394071
*Knutsen AP, Roodman ST, Evans RG, . 1987. Immune studies in dioxin-exposed Missouri residents: Quail Run. Bull Environ Contam Toxicol 39:481–489.3499197
Knutson JC, Poland A. 1980. Keratinization of mouse teratoma cell line XB produced by 2,3,7,8-tetrachlorodibenzo-p-dioxin: an in vitro model of toxicity. Cell 22:27–36.6159102
*Knutson JC, Poland A. 1982. Response of murine epidermis to 2,3,7,8-tetrachlorodibenzo-p-dioxin: interaction of the Ah and hr loci. Cell 30:225–234.6290078
*Ko HP, Okino ST, Ma Q, . 1996. Dioxin-induced CYP1A1 transcription in vivo: The aromatic hydrocarbon receptor mediates transactivation, enhancer-promoter communication, and changes in chromatin structure. Mol Cell Biol 16:430–436.8524325
*Kociba RJ, Keyes DG, Beyer JE, . 1978a. Results of a two-year chronic toxicity and oncogenicity study of 2,3,7,8-tetrachlorodibenzo-p-dioxin in rats. Toxicol Appl Pharmacol 46:279–303.734660
Kociba RJ, Keyes DG, Beyer JE, . 1978b. Toxicologic studies of 2,3,7,8-tetrachloro-dibenzo-p-dioxin (TCDD) in rats. Toxicol Occup Med (De Toxicol Environ Sci) 4:281–287.
Kociba RJ, Keyes DG, Beyer JE, . 1979. Long-term toxicologic studies of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in laboratory animals. Ann NY Acad Sci 320:397–404.287397
Kociba RJ, Schwetz BA. 1982. Toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Drug Metab Rev 13:387–406.6213397
*Koester CJ, Harless RL, Hites RA. 1992. Comparative analysis of dioxins and furans in ambient air by high resolution and electron capture mass spectrometry. Chemosphere 24(4):421–426.
Koester CJ, Hites RA. 1988. Calculated physical properties of polychlorinated dibenzo-p-dioxins and dibenzofurans. Chemosphere 17:2355–2362.
*Koester CJ, Hites RA. 1992. Photo degradation of polychlorinated dioxins and dibenzofurans adsorbed to fly ash. Environ Sci Technol 26(3):502–507.
Kogan MD, Clapp RW. 1985. Mortality among Vietnam veterans in Massachusetts, 1972-1983. Boston, MA: Massachusetts Office of the Commissioner of Veterans Services, Agent Orange Program, Massachusetts Department of Public Health, Division of Health Statistics and Research.
*Kogevinas M, Becher H, Benn T, . 1997. Cancer mortality in workers exposed to phenoxy herbicides, chlorophenols, and dioxins. Am J Epidemiol 145:1061–1075.9199536
*Kogevinas M, Kauppinen T, Winkelmann R, . 1995. Soft tissue sarcoma and non-Hodgkin’s lymphoma in workers exposed to phenoxy herbicides, chlorophenols, and dioxins: two nested case-control studies. Epidemiol 6:396–402.
*Kogevinas M, Saracci R, Winkelmann R, . 1993. Cancer incidence and mortality in women occupationally exposed to chlorophenoxy herbicides, chlorophenols, and dioxins. Cancer Causes and Control 4:547–553.8280832
*Kohn MC, Lucier GW, Clark GC, . 1993. A mechanistic model of effects of dioxin on gene expression in the rat liver. Toxicol Appl Pharmacol 120:138–154.8511776
*Kohn MC, Sewall CH, Lucier GW, . 1996. A mechanistic model of effects of dioxin on thyroid hormones in the rat. Toxicol Appl Pharmacol 165:29–48.
*Kolenda J, Gass H, Wilken M, . 1994. Determination and reduction of PCDD/F emissions from wood burning facilities. Chemosphere 29(9–11):1927–1938.
Kominsky JR, Kwoka CD. 1989. Background concentrations of polychlorinated dibenzofurans (PCDFs) and polychlorinated dibenzo-p-dioxins (PCDDs) in office buildings in Boston, Massachusetts. Chemosphere 18:599–608.
Kominsky JR, Slade WT, Mooring R. 1988. Background concentrations of polychlorinated biphenyls, polychlorinated dibenzo-p-dioxins, and polychlorinated dibenzofurans in office buildings in Santa Fe, New Mexico. Electr Power Res Inst (Rep), 7-15 – 7-26.
*Komori M, Nishio K, Kitada M . 1990. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry 29:4430–4433.2350547
*Koope JG, Pluim HJ, Olie K. 1991. Breast milk, dioxins and the possible effects on health of newborn infants. Sci Tot Environ 106:33–41.
*Koopman-Esseboom C, Morse DC, Weisglas-Kuperus N, . 1994. Effects of dioxins and polychlorinated biphenyls on thyroid hormaone status of pregant women and their infants. Pediatr Res 36:468–473.7816522
*Koppe JG. 1995. Nutrition and breast-feeding. European Journal of Obstetrics & Gynecology and Reproductive 61(1):73–78.
Korcher CW, Mahle NH, Hummels RA, . 1978. A search for the presence of 2,3,7,8-tetrachlorodibenzo-p-dioxin in beef fat. Bull Environ Contam Toxicol 19:229–236.
Korfmacher WA, Hansen EBJR, Rowland KL. 1986. Use of bullfrogs (Rana catesbeiana) as biological markers for 2,3,7,8-tetrachlorodibenzo-p-dioxin contamination in the environment. Sci Total Environ 57:257–262.3492763
*Korfmacher WA, Rushing LG, Nestorick DM, . 1985. Analysis of dust and surface swab samples for octachlorodibenzo-p-dioxin and heptachlorodibenzo-p-dioxins by fused silica capillary GC with EC detection. Journal of High Resolution Chromatography and Chromatography Communications 8:12–19.
Korte M, Renscher C, Luebbe U. 1989. TCDD liver concentrations and biological activity in cross-fostered rat offspring after maternal treatment. Naunyn-Schmiedeberg’s Abstract R10. Arch Pharmacol 339 Suppl.
*Koshakji RP, Harbison RD, Bush MT. 1984. Studies on the metabolic fate of [14C]2,3,7,8-tetra-chlorodibenzo-p-dioxin (TCDD) in the mouse. Toxicol Appl Pharmacol 73:69–77.6710517
Koshioka M, Kanazawa J, Lizuka H, . 1987. Photodegradation of decachlorobiphenyl. Bull Environ Contam Toxicol 38:409–415.3101775
Koshioka M, Yamada T, Kanazawa J, . 1989a. Photodegradation products of tetrachlorodibenzo-p-dioxins under xenon lamp irradiation. J Pesticide Sci 14:175–179.
*Koshioka M, Yamada T, Kanazawa J, . 1989b. Photolysis of tetrachlorodibenzo-p-dioxins. Chemosphere 19:681–684.
*Koshioka M, Yamada T, Kanazawa J, . 1989c. Wavelength-dependence of photodegradation of tetrachlorodibenzo-p-dioxins. Journal of Pesticide Science 14:181–187.
*Kouri RE, Ratrie H, Whitmire CE. 1974. Genetic control of susceptibility to 3-methylcholanthrene-induced lung subcutaneous sarcomas. J Cancer 13:714–720.
*Kouri RE, Rude TH, Joglekar R, . 1978. 2,3,7,8-Tetrachlorodibenzo-p-dioxin as cocarcinogen causing 3-methylcholanthrene-initiated subcutaneous tumors in mice genetically “nonresponsive” at Ah locus. Cancer Res 38:2777–2783.679184
*Kramer CM, Johnson KW, Dooley RK, . 1987. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD) enhances antibody production and protein kinase activity in murine B cells. Biochem Biophys Res Comm 145:25–32.3496088
*Kreuzer PE, Csanady GA, Baur C, . 1997. 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) and congeners in infants. A toxicokinetic model of human lifetime body burden by TCDD with special emphasis on its uptake by nutrition. Arch Toxicol 71:383–400.9195020
*Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Hayes W, ed. Principles and methods of toxicology. 3rd edition. New York, NY: Raven Press, Ltd.
*Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Hayes W, ed. Principles and methods of toxicology. 3rd edition. New York, NY: Raven Press, Ltd.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: Yang RSA, ed. Toxicology of chemical mixtures. New York, NY: Academic Press.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: Yang RSA, ed. Toxicology of chemical mixtures. New York, NY: Academic Press.
*Krishnan V, Porter W, Santostefano M, . 1995. Molecular mechanism of inhibition of estrogen-induced cathepsin D gene expression by 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in MCF-7 cells. Mol Cell Biol 15: 6710–6719.8524236
*Krishnan V, Safe S. 1993. Polychlorinated biphenyls (PCBs), dibenzo-p-dioxins (PCDDs), and dibenzofurans (PCFDs) as antiestrogens in MCF-7 human breast cancer cells: Quantitative structure-activity relationships. Toxicol Appl Pharmacol 120:55–61.7685553
*Krowke R. 1986. Studies on distribution and embryotoxicity of different PCDD and PCDF in mice and marmosets. Chemosphere 15:2011–2022.
*Krowke R, Chahoud I, Baumann-Wilschke I, . 1989. Pharmacokinetics and biological activity of 2,3,7,8-tetrachlorodibenzo-p-dioxin: 2. Pharmacokinetics in rats using a loading-dose/maintenance-dose regime with high doses. Arch Toxicol 63:356–360.2818199
*Kuehl DW, Butterworth BC, DeVita WM, . 1987a. Environmental contamination by polychlorinated dibenzo-p-dioxins and dibenzofurans associated with pulp and paper mill discharge. Biomed Environ Mass Spectrom 14:443–447.2957005
*Kuehl DW, Butterworth BC, Marquis PJ. 1994. A national study of chemical residues in fish: III Study results. Chemosphere 29(3):523–535.
*Kuehl DW, Butterworth BC, McBride A, . 1989. Contamination of fish by 2,3,7,8-tetrachlorodibenzo-p-dioxin: A survey of fish from major watersheds in the United States. Chemosphere 18:1997–2014.
*Kuehl DW, Cook PM, Batterman AR. 1985. Studies on the bioavailability of 2,3,7,8-TCDD from municipal incinerator fly ash to freshwater fish. Chemosphere 14:871–872.
*Kuehl DW, Cook PM, Batterman AR, . 1987b. Bioavailability of polychlorinated dibenzo-p-dioxins and dibenzofurans from contaminated Wisconsin River sediment to carp. Chemosphere 16:667–679.
*Kuehl DW, Cook PM, Batterman AR, . 1987c. Isomer dependent bioavailability of polychlorinated dibenzofurans from municipal incinerator fly ash to carp. Chemosphere 16:657–666.
*Kuwata K, Yamashita Y, Nakashima S, . 1993. Practical method for monitoring polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans in the atmosphere. J Chromatogr 643(1–2):25–33.
Kuykendal WB, Lamason WH, Miles AJ, . 1989. Ash data from combustion sources: Results of tier 4 of the national dioxin study. Chemosphere 18:1227–1234.
*LaFleur L, Bousquet T, Ramage K, . 1990. Analysis of TCD and TCDF on the ppq-level in milk and food sources. Chemosphere 20(10–12):1657–1662.
*LaGoy P. 1987. Estimated soil ingestion rates for use in risk assessment. Risk Analysis 7:355–359.3317565
*Lai Z-W, Pineau T, Esser C. 1996. Identification of dioxin-responsive elements (DREs) in the 5’ regions of putative dioxin-inducible genes. Chem-Biol Interact 100:97–112.8646792
*Lakshmanan MR, Campbell BS, Chirtel SJ, . 1986. Studies on the mechanism of absorption and distribution of 2,3,7,8-tetrachlorodibenzo-p-dioxin in the rat. J Pharmacol Exp Ther 239:673–677.3795035
Lamb JC IV, Harris MW, McKinney JD, . 1986. Effects of thyroid hormones on the induction of cleft palate by 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in C57BL/6N mice. Toxicol Appl Pharmacol 84:115–124.3715858
*Lamb JC IV, Moore JA. 1981. Development and viability of offspring of male mice treated with chlorinated phenoxy acids and 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Toxicol Environ Health 8:835–844.7338945
Lamparski LL, Mahle NH, Shadoff LA. 1978. Determination of pentachlorophenol, hexachloro-dibenzo-p-dioxin, and octachloro-dibenzo-p-dioxin in bovine milk. J Agric Food Chem 26:1113–1116.
Lamparski LL, Nestrick TJ. 1980. Determination of tetra-, hexa-, hepta- and octachlorodibenzo-p-dioxin isomers in particle samples at parts-per-trillion range. Anal Chem 52:2045–2054.
Lamparski LL, Nestrick TJ. 1988. Accuracy in the determination of chlorinated dibenzo-p-dioxins and dibenzofurans in environmental samples. Journal and Research of the National Bureau of Standards 93:241–242.
Lamparski LL, Nestrick TJ, Frawley NN, . 1986. Perspectives of a large scale environmental study for chlorinated dioxins: Water analysis. Chemosphere 15:1445–1452.
Lamparski LL, Nestrick TJ, Stehl RH. 1979a. Determination of part per trillion concentrations of 2,3,7,8-tetra chlorodibenzo-p-dioxin in fish. Anal Chem 51:1453–1458.484863
Lamparski LL, Stehl RJ, Johnson RL. 1979b. Photolysis of pentachlorophenol-treated wood: Chlorinated dibenzo-p-dioxin formation. Environ Sci Technol 14:196–200.
Lampi P, Vertianen T, Tuomisto J. 1990. Population exposure to chlorophenols, dibenzo-p-dioxins and dibenzofurans after a prolonged groundwater pollution by chlorophenols. Chemosphere 20:625–634.
*Landers JP, Bunce NJ. 1991. The Ah receptor and the mechanism of dioxin toxicity. Biochem J 276:273–287.1646595
*Landers JP, Piskorska-Pliszczynska J, Zacharewski T, . 1989. Photoaffinity labeling of the nuclear Ah receptor from mouse Hepa-1c1c7 cells using 2,3,7,8-[3H]tetrachlorodibenzo-p-dioxin. J Biol Chem 264:18463–1841.2553709
*Lang DS, Becker S, Clark GC, . 1994. Lack of direct immunosuppressive effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on human peripheral blood lymphocyte subsets in vitro. Arch Toxicol 68:296–302.8085940
Langhorst ML, Shadoff LA. 1980. Determination of parts-per-trillion concentrations of tetra-, hexa-, hepta-, and octachlorodibenzo-p-dioxins in human milk samples. Anal Chem 52:2037–2044.7447018
*Lans MC, Klasson-Wehler E, Willemsen M, . 1993. Structure-dependent, competitive interaction of hydroxy-polychlorobiphenyls, -dibenzo-p-dioxins and -dibenzofurans with human transthyretin. Chem Biol Interactions 88:7–21.
*Lans MC, Spiertz C, Brouwer A. 1994. Different competition of thyroxine binding to transthyretin and thyroxine-binding globulin by hydroxy-PCBs, PCDDs and PCDFs. Environ Toxicol Pharmacol 270:129–136.
Lapeza CR Jr, Patterson DG Jr, Liddle JA. 1986. Automated apparatus for the extraction and enrichment of 2,3,7,8-tetrachlorodibenzo-p-dioxin in human adipose tissue. Anal Chem 58:713–716.3706743
Lathrop GD, Wolfe WH, Albanese RA, . 1984. An epidemiological investigation of health effects in Air Force personnel following exposure to herbicides: Baseline morbidity study results. USAF School of Aerospace Medicine, Brooks Air Force Base, Texas.
Lawn RE. 1988. Some aspects of the determination of polychlorodibenzo-p-dioxins and polychlorodibenzofurans in environmental and biological samples. Anal Proc 25:49–50.
*Lawrence BP, Kerkvliet NI. 1997. Role of altered arachidonic acid metabolism in 2,3,7,8-tetrachloro-dibenzo-p-dioxin-induced immune suppression in C57BI/6 mice. Toxicol Sci 42:13–22.
Lawrence J, Onuska F, Wilinson R, . 1986. Methods in research: Determination of dioxins in fish and sediment. Chemosphere 15:1085–1090.
*LeBel, GL, Williams DT, Benoit FM. 1992. Chlorinated dibenzodioxins and dibenzofurans in consumer paper products. Chemopshere 25(11):1683–1690.
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: implications for practice. Pediatric Clinics of North America 44:55–77.9057784
*Leung H. 1993. Physiologically-based pharmacokinetic modeling. In: Ballantine B, Marro T, Turner T, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
*Leung H-W, Ku RH, Paustenbach DJ, . 1988. A physiologically based pharmacokinetic model for 2,3,7,8-tetrachlorodibenzo-p-dioxin in C57BL/6J and DBA/2J mice. Toxicol Letters 42:15–28.
*Leung H-W, Paustenbach DJ, Murray FJ, . 1990b. A physiological pharmacokinetic description of the tissue distribution and enzyme-inducing properties of 2,3,7,8-tetrachlorodibenzo-p-dioxin in the rat. Toxicol Appl Pharmacol 103:399–410.2160135
*Leung H-W, Wendling JM, Orth R, . 1990a. Relative distribution of 2,3,7,8-tetrachlorodibenzo-p-dioxin in human hepatic and adipose tissues. Toxicol Lett 50:275–282.2309246
*Levy CJ. 1988. Agent Orange exposure and post-traumatic stress disorder. J Nerv Ment Dis 176:242–245.2965215
*Li X, Johnson DC, Rozman KK. 1995a. Reproductive effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in female rats: Ovulation, hormonal regulation, and possible mechanisms. Toxicol Appl Pharmacol 133:321–327.7645029
*Li X, Johnson DC, Rozman KK. 1995b. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on estrous cyclicity and ovulation in female Sprague-Dawley rats. Toxicol Lett 78:219–222.7624893
*Li X, Rozman KK. 1995. Subchronic effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) and their reversibility in male Sprague-Dawley rats. Toxicology 97:133–140.7716779
*Li X, Weber LWD, Rozman KK. 1995c. Toxicokientics of 2,3,7,8-tetrachlorodibenzo-p-dioxin in female Sprague-Dawley rats including placental and lactational transfer to fetuses and neonates. Fund Appl Toxicol 27:70–76.
Liberti A, Ciccioli P, Brancaleoni E, . 1982. Determination of polychlorodibenzo-p-dioxins and polychlorodibenzofurans in environmental samples by gas chromatography-mass spectrometry. J Chromatogr 242:111–118.
*Liem A, Hoogerbrugge R, Koostra PR, . 1991. Occurrence of dioxins in cow’s milk in the vicinity of municipal waste incinerators and a metal reclamation plant in the Netherlands. Chemosphere 23(11–12):1675–1684.
Liem AKD, De Jong APJM, Marsman JA, . 1990. A rapid clean-up procedure for the analysis of polychlorinated dibenzo-p-dioxins and dibenzofurans in milk samples. Chemosphere 20:843–850.
*Ligon WV Jr, Dorn SB, May RJ, . 1989. Chlorodibenzofuran and chlorodibenzodioxins levels in Chilean mummies date about 2800 years before the present. Environ Sci Technol 23(10):1286–1290.
Ligon WV Jr, May RJ. 1986. Determination of selected chlorodibenzofurans and chlorodibenzodioxins using two-dimensional gas chromatography/mass spectrometry. Anal Chem 58:558–561.
*Lim M, Jacobson-Kram D, Bowman RE, . 1987. Effect of chronic exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin on sister chromatid exchange levels in peripheral lymphocytes of the Rhesus monkey. Cell Biol Toxicol 3:279–284.3507259
*Lin FH, Clark G, Birnbaum LS, . 1991a. Influence of the Ah locus on the effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin on the hepatic epidermal growth factor receptor. Mol Pharmacol 39:307–313.1848654
*Lin FH, Stohs SJ, Birnbaum LS, . 1991. The effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on the hepatic estrogen and glucocorticoid receptors in congenic strains of Ah responsive and Ah nonresponsive C57Bl/6J mice. Toxicol Appl Pharmacol 108:129–139.1672475
*Lin W-Q, White KL. 1993. Production of complement component C3 in vivo following 2,3,7,8-tetrachlorodibenzo-p-dioxin exposure. J Toxicol Environ Health 39:273–285.8501770
Lin WQ, White KL Jr. 1991. In vivo and in vitro suppression of C3 production by TCDD [Abstract 51]. The Toxicologist 11:37.
Lindberg JJ. 1988. Polychlorinated dioxins and dibenzofurans in the pulp and paper industry. Papieri ja Puu-Paper and Timber 70:713–715, 717, 719.
Lindstroem G, Rappe C. 1988. Analytical method for analysis of polychlorinated dibenzo-p-dioxins and dibenzofurans in milk. Chemosphere 17:921–935.
Lindstroem G, Rappe C. 1990. Analytical procedure operating on 0.1-1 ppt level applied in toxicological studies on PCDFs/PCDDs. Chemosphere 20:851–856.
Lindstroem GUM, Sjoestroem MS, Stephen E, . 1988. Multivariate statistical approach to a data set of dioxin and furan contaminations in human milk. Bull Environ Contam Toxicol 40:641–646.3382780
Lodge KB, Cook PM. 1989. Partitioning studies of dioxin between sediment and water: The measurement of Koc for Lake Ontario sediments. Chemosphere 19:439–444.
*Lofroth G, Zebuhr Y. 1992. Polychlorinated dibenzo-p-dioxins (PCDDs and dibenzofurans (PCDFs) in mainstream and sidestream cigarette smoke. Bull Environ Contam Toxicol 48:789–794.1568054
*Loonen H, Tonkes M, Parsons JR, . 1993. Relative contributions of water and food to the bioaccumulation of a mixture of polychlorinated dibenzoi-p-dioxins and polychlorinated dibenzofurans in guppies. Sci Total Environ (S):491–498.
*Loprieno N, Sbrana I, Rusciano D, . 1982. In vivo cytogenic studies on mice and rats exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). In: Hutzinger O, Frei RW, Merian E, ., eds. Chlorinated dioxins and related compounds: Impact on the environment. New York, NY: Pergamon Press, 419–428.
*Lorber M, Cleverly D, Schaum J, . 1994. Development and validation of an air-to-beef food chain model for dioxin-like compounds. Sci Total Enviro 156:39–65.
*Lorber M, Saunders P, Ferrario J, . 1997. A statistical survey of dioxin-like compounds in United States pork fat. Organohalogen Compounds 32:80–86.
*Lorber MN, Winters DL, Griggs J, . 1998. A national survey of dioxin-like compounds in the United States milk supply. Organohalogen Compounds 38:87–97.
*Lorenzen A, Okey AP. 1991. Detection and characterization of Ah receptor in tissue and cells from human tonsils. Toxicol Appl Pharmacol 107:203–214.1847246
Lower WR, Yanders AF, Orazio Ce, . 1989. A survey of 2,3,7,8-tetrachlorodibenzo-p-dioxin residues in selected species from Times Beach, Missouri. Chemosphere 18:1079–1088.
*Lu CH, Baggs RB, Redmond D, . 1986. Toxicity and evidence for metabolic alterations in 2,3,7,8-tetrachlorodibenzo-p-dioxin-treated guinea pigs fed by total parenteral nutrition. Toxicol Appl Pharmacol 84:439–453.3088772
Lucier G, Clark G, Hiermath C, . 1993a. Carcinogenicity of TCDD in laboratory animals: Implications for risk assessment. Toxicol Ind Health 9:631–668.8296316
*Lucier GW, Portier CJ, Gallo MA. 1993b. Receptor mechanisms and dose-response models for the effects of dioxins. Environ Health Perspect 101:36–44.8390353
*Lucier GW, Rumbaugh RC, McCoy Z, . 1986. Ingestion of soil contaminated with 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) alters hepatic enzyme activities in rats. Fundam Appl Toxicol 6:364–371.3084326
*Lucier GW, Tritscher A, Goldsworthy T, . 1991. Ovarian hormones enhance 2,3,7,8-tetrachloro-dibenzo-p-dioxin-mediated increases in cell proliferation and preneoplastic foci in a two-stage model for rat hepatocarcinogenesis. Cancer Res 51:1391–1397.1671757
*Lundberg K, Dencker L, Gronvik KO. 1990. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) treatment in vivo on thymocyte functions in mice after activation in vitro. Int J Immunopharmacol 12:459–466.1975249
Lundgren K, Andries M, Thompson C, . 1986. Dioxin treatment of rats results in increased in vitro induction of sister chromatid exchanges by -naphthoflavone: An animal model for human exposure to halogenated aromatics. Toxicol Appl Pharmacol 85:189–195.3764905
*Lustenhouwer JWA, Olie K, Hutzinger O. 1980. Chlorinated dibenzo-p-dioxins and related compounds in incinerator effluents. Chemosphere 9:501–522.
*Luster MI, Clark G, Lawson LD, . 1979. Effects of brief in vitro exposure to 2,3,7,8-tetrachloro-dibenzo-p-dioxin (TCDD) on mouse lymphocytes. J Environ Pathol Toxicol 2:965–977.312892
Luster MI, Dean JH, Boorman GA. 1982. Altered immune functions in rodents treated with 2,3,7,8-tetrachlorodibenzo-p-dioxin, phorbol-12-myristate-13-acetate, and benzo[a]pyrene. Banbury Rep. Iss Environmental Factors in Human Growth and Development 11:199–213.
*Luster MI, Germolec DR, Clark G, . 1988. Selective effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin and corticosteroid on in vitro lymphocyte maturation. J Immunol 140:928–935.3257509
Luster MI, Hong LH, Boorman GA, . 1985. Acute myelotoxic responses in mice exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Toxicol Appl Pharmacol 81:156–165.2996177
*Luster, MI, Hong LH, Osborne R, . 1986. I-Amino-3,7,8-trichlorodibenzo-p-dioxin: A specific antagonist for TCDD-induced myelotoxicity. Biochem Biophys Res Commun 139:747–756.3021141
*Luster MJ, Boorman GA, Dean JH, . 1980. Examination of bone marrow, immunologic parameters and hose susceptibility following pre- and postnatal exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Int J Immunopharmacol 2:301–310.7203748
*Lyman WJ, Reehl WF, Rosenblatt DH. 1982. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill Book Company, 4–9, 15–16.
*Lynge E. 1985. A follow-up study of cancer incidence among workers in manufacture of phenoxy herbicides in Denmark. Br J Cancer 52:259–270.4027168
Ma X, Mufti NA, Babish JG. 1992. Protein tyrosine phosphorylation as an indicator of 2,3,7,8-tetrachlorodibenzo-p-dioxin exposure in vivo and in vitro. Biochem Biophys Res Commun 189(1):59–65.1280431
*Mabey WR, Smith JH, Podoll RT, . 1982. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency. EPA 440/4-81-014, 107–108.
Mably TA, Moore RW, Peterson RE. 1991. Effects of perinatal exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on pre- and postnatal plasma testosterone (T) concentrations in male rats [Abstract 996]. The Toxicologist 11:262.
*Mably TA, Moore RW, Peterson RE. 1992a. In utero and lactational exposure of male rats to 2,3,7,8-tetrachlordibenzo-p-dioxin. 1. Effects on androgenic status. Toxicol Appl Pharmacol 114(1):97–107.1585378
*Mably TA, Moore RW, Peterson RE. 1992b. In utero and lactational exposure of male rats to 2,3,7,8-tetrachlordibenzo-p-dioxin. 2. Effects on sexual behavior and the regulation of luteinizing hormone secretion in adulthood. Toxicol Appl Pjarmacol 114(1):108–117.
*Mably TA, Moore RW, Peterson RE. 1992c. In utero and lactational exposure of male rats to 2,3,7,8-tetrachlordibenzo-p-dioxin. 3. Effects on spermatogenesis and reproductive capability. Toxicol Appl Pharmacol 114(1):118–126.1585364
*Mably TA, Theobald HM, Ingall GB, . 1990. Hypergastrinemia is associated with decreased gastric acid secretion in 2,3,7,8-tetrachlorodibenzo-p-dioxin-treated rats. Toxicol Appl Pharmacol 106:518–528.2260098
Madge DS. 1977. Effects of trichlorphenoxyacetic acid and chlorodioxins on small intestinal function. Gen Pharmacol 8:319–324.604157
*Madhukar BV, Brewster DW, Matsumura F. 1984. Effects of in vivo administered 2,3,7,8-tetrachlorodibenzo-p-dioxin on receptor binding of epidermal growth factor in the hepatic plasma membrane of rat, guinea pig, mouse and hamster. Proc Natl Acad Sci USA 81:7404–7411.
*Madsen C, Larsen JC. 1989. Relative toxicity of chlorinated dibenzo-para-dioxins, and dibenzofurans measured by thymus weight and liver-enzyme induction in perinatally dosed rats 2,3,7,8-TCDD, 2,3,4,7,8-PCDF, 1,2,3,7,8-PCDD. Chemosphere 18:955–966.
Mahle NJ, Whiting LF. 1980. The formation of chlorodibenzo-p-dioxins by air oxidation and chlorination of bituminous coal. Chemosphere 9:693–699.
*Mahon MJ, Gasiewicz TA. 1995. Ah receptor phosphorylation: Localization of phosphorylation sites to the C-terminal half of the protein. Arch Biochem Biophys 318:166–174.7726558
*Malisch R. 1994. Determination of dioxins and furans in coloured candle wax. Chemosphere 29(9–11):1957–1963.
*Mamantov A. 1984. Linear correlation between photolysis rates and toxicity of polychlorinated dibenzo-p-dioxins. Environ Sci Technol 18:808–810.
*Manara L, Coccia P, Croci T. 1984. Prevention of TCDD toxicity in laboratory rodents by addition of charcoal or cholic acids to chow. Food Chem Toxicol 22:815–818.6541620
*Mantovani A, Vecci A, Luini W, . 1980. Effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin on macrophage and natural killer cell-mediated cytotoxicity in mice. Biomedicine 32:200–204.7470583
*Manz A, Berger J, Dwyer JH, . 1991. Cancer mortality among workers in chemical plant contaminated with dioxin. Lancet 338:959–964.1681339
Marcheterre L, Webster GR, Barrie MDC, . 1985. Fate of 14C-octachlorodibenzo-p-dioxin in artificial outdoor ponds. Chemosphere 14:835–838.
Mariani G, Benfenati E, Fanelli R, . 1992. Incineration of agro-industrial wastes and macro- and micropollutants emission. Chemosphere 23:1359–64.
*Marinovich M, Sirtori CR, Galli CL, . 1983. The binding of 2,3,7,8-tetrachlorodibenzo-p-dioxin to plasma lipoproteins may delay toxicity in experimental hyperlipidemia. Chem Biol Interact 45:393–399.6883580
Marklund S, Andersson R, Tysklind M, . 1990. Emissions of PCDDs and PCDFs in gasoline and diesel fueled cars. Chemosphere 20:553–561.
Marklund S, Kjeller LO, Hansson M, . 1986. Determination of PCDDs and PCDFs in incineration samples and pyrolytic products. In: Rappe C, Choudhary G, Keith LH, eds. Chlorinated dioxins and dibenzofurans in perspective. Chelsea, MI: Lewis Publishers, Inc., 79–92.
*Marklund S, Rappe C, Tyslind M, . 1987. Identification of polychlorinated dibenzofurans and dioxins in exhaust from cars run on leaded gasoline. Chemosphere 16:29–36.
*Marklund S, Tysklind M, Andersson R, Ljung K, . 1991. Environmental deposition of PCDDs and PCDFs as determined by the analysis of snow samples from the northern Sweden. Chemosphere 23:1359–1364.
Marlow DA. 1986. Hexachlorobenzene exposure in the production of chlorophenols: Industrywide studies on branch. Cincinnati, OH: National Institute for Occupational Safety and Health, 161–169.
Marple L, Berridge B, Throop L. 1986a. Measurement of the water-octanol partition coefficient of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Environ Sci Technol 20:397–399.22300212
*Marple L, Brunck R, Throop L. 1986b. Water solubility of 2,3,7,8,-tetrachlorodibenzo-p-dioxin. Environ Sci Technol 20(2):180–182.22288808
*Marquis PJ, Hacket M, Holland LG, . 1994. Analytical methods for a national study of chemical residues in fish. 1: Polychlorinated dibenzo-p-dioxins, dibenzofurans. Chemosphere 29(3):495–508.
Mason G, Denomme MA, Safe L, . 1987. Polybrominated and chlorinated dibenzo-para-dioxins structure-activity relationships. Chemosphere 16:1729–1731.
Mason G, Farrell K, Keys B, . 1986. Polychlorinated dibenzo-p-dioxins: Quantitative in vitro and in vivo structure-activity relationships. Toxicology 41:21–31.3750336
*Mason G, Safe S. 1986a. Synthesis, biologic and toxic effects of the major 2,3,7,8-tetrachlorodibenzo-p-dioxin metabolites in the rat. Toxicology 41:153–159.3764940
Mason G, Safe S. 1986b. Synthesis, biologic and toxic properties of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Chemosphere 15:2081–2083.
*Mastroiacovo P, Spagnolo A, Marni E, . 1988. Birth defects in the Seveso area after TCDD contamination. JAMA 259:1668–1672.3343773
*Matsumura F. 1994. How important is the protein phosphorylation pathway in the toxic expression of dioxin-type chemicals? Biochem Pharmacol 48:215–224.8053917
*Matsumura F, Benezet HJ. 1973. Studies on the bioaccumulation and microbial degradation of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Environ Health Persp 5:253–258.
Matsumura F, Quensen J, Tsushimoto G. 1983. Microbial degradation of TCDD in a model ecosystem. In: Tucker RE, . eds. Human and Environmental risks of chlorinated dioxins and related compounds. New York, London: Plenum Press, 191–219.
*Max SR, Silbergeld EK. 1987. Skeletal muscle glucocorticoid receptor and glutamine synthetase activity in the wasting syndrome in rats-treated with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 15:523–527.
*May G. 1973. Chloracne from the accidental production of tetrachlorodibenzodioxin. Br J Med 30:276–283.
*McConkey DJ, Orrenius S. 1989. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD) kills glucocorticoid-sensitive thymocytes in vivo. Biochem Biophys Res Commun 160:1003–1008.2543382
McConnell EE. 1985. Comparative toxicity of PCBs and related compounds in various species of animals. Environ Health Perspect 60:29–33.2992923
*McConnell EE, Lucier GW, Rumbaugh RC, . 1984. Dioxin in soil: Bioavailability after ingestion by rats and guinea pigs. Science 223:1077–1079.6695194
*McConnell EE, Moore JA. 1979. Toxicopathology characteristics of the halogenated aromatics. Ann. NY Acad. Sci. 320:138–147.110189
*McConnell EE, Moore JA, Dalgard DW. 1978a. Toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin in rhesus monkeys (Macaca mulatta) following a single oral dose. Toxicol Appl Pharmacol 43:175–187.415382
*McConnell EE, Moore JA, Haseman JK, . 1978b. The comparative toxicity of chlorinated dibenzo-p-dioxins in mice and guinea pigs. Toxicol Appl Pharmacol 44:335–356.675706
*McCormack KM, Gibson JE, Hook JB. 1976. Effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on renal function in rats in vivo. Toxicol Appl Pharmacol 37:177.
*McCrady JK, Maggard SP. 1993. Uptake and photodegradation of 2,3,7,8-tetrachlorodibenzo-p-dioxin sorbed to grass foliage. Environ Sci Tech 27:343–350.
*McCrady JK, McFarlane C, Gander LK. 1990. The transport and fate of 2,3,7,8- TCDD in soybeans and corn. Chemosphere 21: 359–376.
*McCurvin DMA, Schellenberg DH, Clement RE, . 1989. A comparison of tandem quadrupole mass spectrometry versus single quadrupole capabilities for the determination of chlorinated dioxins and dibenzofurans in environmental samples. Chemosphere 19:201–204.
*McKee P, Burt A, McCurvin D, . 1990. Levels of dioxins, furans and other organic contaminants in harbour sediments near a wood preserving plant using pentachlorophenol and creosote. Chemosphere 20(10–12):1679–1685.
*McKinney JD, Chae K, Oatley SJ, . 1985a. Molecular interactions of toxic chlorinated dibenzo-p-dioxins and dibenzofurans with thyroxine binding prealbumin. J Med Chem 28:375–381.3919186
*McKinney JD, Fawkes J, Jordan S, . 1985b. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD) as a potent and persistent thyroxine agonist: A mechanistic model for toxicity based on molecular reactivity. Environ Health Perspect 61:41–53.2998749
McKone TE, Ryan PB. 1989. Human exposure to chemicals through food chains: An uncertainty analysis. Environ Sci Technol 23:1154–1163.
McLachlan M, MacKay D, Jones PH. 1990. A conceptual model of organic chemical volatilization at waterfalls. Environ Sci Technol 24:252–257.
*McLachlan MS. 1993. Digestive tract absorption of polychlorinated dibenzo-p-dioxins, dibenzofurans, and biphenyls in a nursing infant. Toxicol Appl Pharmacol 123:68–72.8236263
*McLachlan MS, Hinkel M, Reissinger M, . 1994. A study of the influence of sewage sludge fertilization on the concentrations of PCDD/F and PCB in soil and milk. Environmental Pollution 85:337–343.15091665
*McLemore TL, Adelberg S, Liu MC, . 1990. Expression of CYP1A1 gene in patients with lung cancer: Evidence for cigarette smoke-induced gene expression in normal lung tissue and for altered gene regulation in primary pulmonary carcinomas. J Natl Cancer Inst 82:127–133.
McMahon LW. 1983. Organic priority pollutants in wastewater. Proceedings of the 1982 UCC-ND/GAT Environ Protection Seminar, April 5-7, 1982, Glenstone Lodge, Gatlinburg TN. NTIS DE83010817.
*McNulty W. 1984. Fetotoxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) for Rhesus Macaques (Macaca mulatta). Am J Primatol 6:41–47.31986843
*McNulty W. 1985. Toxicity and fetotoxicity of TCDD, TCDF, and PCB isomers in Rhesus Macaques (Macaca mulatta). Environ Health Perspect 60:77–88.3161723
*McNulty WP, Nielsen-Smith JO, Lay Jr JO, . 1982. Persistence of TCDD in monkey adipose tissue. Food Cosmet Toxicol 20:985–987.
*McPeters AL, Overcash MR. 1993. Demonstrations of photodegradation by sunlight of 2,3,7,8-tetrachlorodibenzo-p-dioxins in 6 cm soil columns. Chemosphere 27:1221–34.
McQueen EG, Veale AMO, Alexander WS, . 1977. 2,4,5-T and human birth defects. Report of the Division of Public Health, New Zealand Department of Health.
*MDNR. 1987. Clean water commission: Water quality standards. Missouri Department of Natural Resources. Washington, DC: Bureau of National Affairs, Inc., 10 CSR 20-7.031.
*Mebus CA, Piper WN. 1986. Decreased rat adrenal 21-hydroxylase activity associated with decreased adrenal microsomal cytochrome P-450 after exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Biochem Pharmacol 35:4359–4262.3491611
*Mebus CA, Reddy VR, Piper WN. 1987. Depression of rat testicular 17-hydroxylase and 17,20-lyase after administration of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Biochem Pharmacol 36:727–731.3827954
Mehrle PM, Buckler DR, Little EE, . 1988. Toxicity and bioconcentration of 2,3,7,8-tetrachlorodibenzodioxin and 2,3,7,8-tetrachlorodibenzofuran in rainbow trout. Environ Toxicol Chem 1:47–62.
Mes J. 1981. Human milk analysis for halogenated hydrocarbon residues. Int J Environ Anal Chem 9:283–300.6786993
Mes J, Weber D. 1989. Non-orthochlorine substituted coplanar polychlorinated biphenyl congeners in Canadian adipose tissue, breast milk and fatty foods. Chemosphere 19:1357–1365.
*Messerer P, Zober A, Becher H. 1998. Blood lipid concentrations of dioxins and furans in a sample of BASF employees included in the IARC registry of workers exposed to phenoxy acid herbicides and/or chlorophenols. Environ Health Perspect 106 (Suppl 2):733–735.
Meyer C, O’Keefe P, Hilker D, . 1989. A survey of twenty community water systems in New York State for PCDDs and PCDFs. Chemosphere 19:21–26.
*Meyne J, Allison DC, Bose K, . 1985. Hepatotoxic doses of dioxin do not damage mouse bone marrow chromosomes. Mutat Res 157:63–69.4010698
*Michalek JE, Pirkle JL, Caudill SP, . 1996. Pharmacokinetics of TCDD in veterans of Operation Ranch Hand: 10-year follow-up. J Toxicol Environ Health 47:209–220.8604146
*Michalek JE, Rahe AJ, Boyle CA. 1998. Paternal dioxin, preterm birth, intrauterine growth retardation, and infant death. Epidemiology 9:161–167.9504284
*Michalek JE, Rahe AJ, Kulkarni PM, . 1998. Levels of 2,3,7,8-tetrachlorodibenzo-p-dioxin in 1,302 unexposed air force Vietnam-era veterans. Journal of Exposure Analysis and Environmental Epidemiology 8(1):59–64.9470105
*Miller AG, Whitlock JP Jr. 1981. Novel variant in benzo[a]pyrene metabolism. J Biol Chem 256:2433–2437.7462248
*Miller GC, Herbert VR, Miille MJ, . 1989a. Photolysis of octachlorodibenzo-p-dioxin on soils: Production of 2,3,7,8-TCDD. Chemosphere 18:1265–1274.
Miller GC, Herbert VR, Miller WW. 1989b. Effect of sunlight on organic contaminants at the atmosphere-soil interface. In: Reactions and movement of organic chemicals in soils. SSSA special publication no. 22. 99–110.
*Miller GC, Herbert VR, Zepp RG. 1987. Chemistry and photochemistry of low-volatility organic chemicals on environmental surfaces. Environ Sci Technol 21:1164–1167.
*Mimnaugh EG, Worland PJ, Whitesell L, . 1995. Possible role for serine/threonine phsphorylation in the regulation of the heteroprotein complex between the hsp90 stress protein and pp60v-src tyrosine kinase. J Biol Chem 270:28654–28659.7499384
Miyata H, Takayama K, Ogaki J, . 1989. Level of PCDDs, coplanar PCBs and PCDFs in patients with Yusho disease and in Yusho oil. Chemosphere 18:407–416.
*MMWR. 1987. Epidemiologic notes and reports. Serum dioxin in Vietnam-era veterans--preliminary report. Atlanta, GA: Centers for Disease Control, Morbidity and Mortality Weekly Report 36:470–475.
*MMWR. 1988. Preliminary report: 2,3,7,8-tetrachlorodibenzo -p-dioxin exposure to humans - Seveso, Italy. Morbidity and Mortality Weekly Report 37(48):733–736.2973556
*Mocarelli P, Brambilla P, Gerthoux PM, . 1996. Change in sex ratio with exposure to dioxin. Lancet 348:409.8709758
*Mocarelli P, Marocchi A, Brambilla P, . 1986. Clinical laboratory manifestations of exposure to dioxin in children. JAMA 256:2687–2695.2877102
*Mocarelli P, Needham LL, Marocchi A, . 1991. Serum concentrations of 2,3,7,8-tetrachlorodibenzo-p-dioxin and test results from selected residents of Seveso, Italy. J Toxicol Environ Health 32:357–366.1826746
Mohamad AH, Zerezghi M, Caruso JA. 1986. Determination of polychlorinated dibenzo-p-dioxins using capillary gas chromatography with microwave-induced plasma detection. Anal Chem 58:469–471.3963399
*Moore JA, Gupta BN, Zinkl JG, . 1973. Postnatal effects of maternal exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Environ Health Perspect 5:81–85.4752916
Moore M, Narasimhan TR, Steinberg MA, . 1993. Potentiation of CYP1A1 gene expression in MCF-7 human breast cancer cells cotreated with 2,3,7,8-tetrachlorodibenzo-p-dioxin and 12-O-tetradecanoylph orbol-13-acetate. Arch Biochem Biophys 305(2):483–488.8396892
*Moore RW, Jefcoate CR, Peterson RE. 1991. 2,3,7,8-Tetrachlorodibenzo-p-dioxin inhibits steroidogenesis in the rat testis by inhibiting the mobilization of cholesterol to cytochrome P450scc. Toxicol Appl Pharmacol 109:85–97.1645482
Moore RW, Mably TA, Bjerke KL, . 1992. In utero and lactational 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) exposure decreased androgenic responsiveness of male sex organs and permanently inhibits spermatogenesis and demasculinizes sexual behavior in rats. Toxicologist 12(1):81
*Moore RW, Parsons JA, Bookstaff RC, . 1989. Plasma concentrations of pituitary hormones in 2,3,7,8-tetrachlorodibenzo-p-dioxin-treated male rats. J Biochem Toxicol 4:165–172.2558221
*Moore RW, Peterson RE. 1988. Androgen catabolism and excretion in 2,3,7,8-tetrachlorodibenzo-p-dioxin-treated rats. Biochem Pharmacol 37:560–562.3337750
*Moore RW, Potter CL, Theobald HM, . 1985. Androgenic deficiency in male rats treated with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 79:99–111.4049410
*Moran RA, Lee CW, Fujimoto JM, . 1986. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on IgA serum and bile levels in rats. Immunopharmacology 12:245–250.3818260
*Morgan JE, Whitlock JP Jr. 1992. Transcription-dependent and transcription-independent nucleosome disruption induced by dioxin. Proc Natl Acad Sci USA 89:11622–11626.1454854
Morita M, Yashuhara A, Seki H, . 1987. Chlorodibenzo-para-dioxins in the feral pigeon. Chemosphere 16:1749–1752.
*Morris DL, Holsapple MP. 1991. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on humoral immunity: II. B-Cell activation. Immunopharmacology 21:171–182.1917439
*Morris DL, Jordan SD, Holsapple MP. 1991. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on humoral immunity: similarities to Staphylococcus aureus Cowan strain I (SAC) in the in vitro T-dependent antibody response. Immunopharmacology 21:159–170.1917438
*Morris DL, Snyder NK, Gokani V, . 1992. Enhanced suppression of humoral immunity in DBA/2 mice following subchronic exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Toxicol Appl Pharmacol 112:128–132.1310164
Morrissey RE, Harris MW, Diliberto JJ, . 1992. Limited PCB antagonism of TCDD-induced malformations in mice. Toxicol Lett 60(1):19–25.1539179
Morselli L, Zappoli S, Liberti A, . 1989. Evaluation and comparison of organic and inorganic compounds between emission and immission samples from municipal solid waste incinerator. Chemosphere 18:2263–2273.
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical Pharmacokinetics in Newborns and Infants. Clinical Pharmacokinetics 5:485–527.7002417
*Mortelmans K, Haworth S, Speck W, . 1984. Mutagenicity testing of Agent Orange and related compounds. Toxicol Appl Pharmacol 75:137–146.6379990
*Moses M, Lilis R, Crow KD, . 1984. Health status of workers with past exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin in the manufacture of 2,4,5-trichlorophenoxyacetic acid: Comparison of findings with and without chloracne. Am J Ind Med 5:161–182.6142642
*Moses M, Prioleau PG. 1985. Cutaneous histologic findings in chemical workers with and without chloracne with past exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Am Acad Dermatol 12:497–506.3157708
*Mott L. 1995. The disproportionate impact of environmental health threats on children of color. Environmental Health Perspectives 103(suppl6):33–35.
Mottet NK. 1985. Morphogenic injury by chemical agents. In: Mottet NK, ed. Environmental pathology. New York, NY: Oxford University, 82–125.
Mottura A, Zei G, Nuzzo F, . 1981. Evaluation of results of chromosome analyses on lymphocytes of TCDD exposed subjects after the Seveso accident. Mutat Res 85:238–239.
*Muir DC G, Lawrence S, Holoka M, . 1992. Partitioning of polychlorinated dioxins and furans between water, sediments and biota in lake mesocosms. Chemosphere 25(1–2):119–24.
*Muir DCG, Townsend BE, Webster GRB. 1983. Bioavailability of 14C-1,3,6,8-tetrachlorodibenzo-p-dioxin and 14C-octachlorodibenzo-p-dioxin to aquatic insects in sediment and water. Fate and Distribution of PCDD and PCDF, 89–102.
*Muir DCG, Yarachewski AL, Webster GRB. 1986b. Bioconcentration of four chlorinated dioxins by rainbow trout and fathead minnows. In: Bahner RC, Hansen DJ, eds. Aquatic toxicology and hazard assessment: Eighth Symposium, Fort Mitchell, KY, April 15-17, 1984. Philadelphia, PA: ASTM, 442–454.
*Muir DCG, Yarechewski AL. 1988. Dietary accumulation of four chlorinated dioxin congeners by rainbow trout and fathead minnow. Environ Toxicol Chem 7:227–236.
*Muir DCG, Yarechewski AL, Knoll A, . 1986a. Bioconcentration and disposition of 1,3,6,8-tetrachlorodibenzo-p-dioxin and octachlorodibenzo-p-dioxin by rainbow trout and fathead minnows. Environ Toxicol Chem 5:261–272.
*Mulcahy MT. 1980. Chromosome aberrations and “Agent Orange.” Med J Aust 2:573–574.
*Muller JF, Hulster A, Papke A, . 1993. Transfer pathways of PCDD/PCDF to fruits. Chemosphere 27(1–3):195–201.
*Muller JF, Hulster AA, Papke OC, . 1994. Transfer of PCDD/PCDF from contaminated soils into carrots, lettuce and peas. Chemosphere 29(9–11):2175–2181.7850372
*Murai K, Tsuji H, Fujishima F. 1991. [Treatment of Yusho PCB poisioning patients with cholestyramine.] Fukuoka Ishi 82:226–329. (Japanese)
*Murk AJ, Legler J, Denison MS, . 1996. Chemical-activated luciferase gene expression (calux): A novel in vitro bioassay for ah receptor active compounds in sediments and pore water. Fundam Appl Toxicol 33(1):149–60.8812260
*Murray FJ, Smith FA, Nitschke KD, . 1979. Three-generation reproduction study of rats given 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in the diet. Toxicol Appl Pharmacol 50:241–251.505455
*Muto H, Takizawa Y. 1989. Dioxins in cigarette smoke. Arch Environ Health 44:171–174.2751353
*MWQS. 1988a. Minnesota recommended allowable limits for drinking water contaminants release no. 2, November. Minnesota Water Quality Standards.
*MWQS. 1988b. Minnesota water quality standards and criteria for toxic substances, provisional data subject to change, 11/88. Minnesota Water Quality Standards.
*Nagarkatti PS, Sweeney GD, Gauldie J, . 1984. Sensitivity to suppression of cytotoxic T-cell generation by 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) is dependent on the Ah genotype of the murine host. Toxicol Appl Pharmacol 72:169–176.6608808
Nagayama J, Kiyohara C, Masuda Y, . 1985. Genetically mediated induction of aryl hydrocarbon hydroxylase activity in human lymphoblastoid cells by polychlorinated dibenzofuran isomers and 2,3,7,8-TCDD. Arch Toxicol 56:230–235.3922334
*Nagayama J, Mohri N, Kiyohara C, . 1989. Comparative toxicologic study of 2,3,7,8-tetrachloro-dibenzo-p-dioxin in Ah responsive and nonresponsive strains of mice. Chemosphere 19:927–932.
Naikwadi KP, Karasek FW. 1986. Gas chromatographic separation of 2,3,7,8-tetrachlorodibenzo-p-dioxin from polychlorinated biphenyls and tetrachlorodibenzo-p-dioxin isomers using a polymeric liquid crystal capillary column. J Chromatogr 369:203–207.3098769
Naikwadi KP, Karasek FW. 1990a. Development of GC capillary column for isomer-specific separation of toxic isomer of PCCDs and PCDFs in environmental samples. Chemosphere 20:1379–1384.
Naikwadi KP, Karasek FW. 1990b. Use of C-13 labelled dioxins mixture for analysis of polychlorinated dibenzo-para-dioxins in environmental samples by GC. Int J Environ Anal Chem 38:329–342.
Nakano T, Tsuji M, Okuno T. 1987. Levels of chlorinated organic compounds in the atmosphere. Chemosphere 16:1781–1786.
Nakano T, Tsuji M, Okuno T. 1990. Distribution of PCDDs, PCDFs and PCBs in the atmosphere. Atmos Environ 24A:1361–1368.
*NAS/NRC. 1977. Drinking water and health: Part II. Washington, DC: National Academy of Sciences, Safe Drinking Water Committee, National Academy Press, 508–513.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
*NAS/NRC. 1989. Biological markers in reproductive toxicology. National Research Council. Board of Environmental Studies and Toxicology. Committee on Biological Markers. 15–35.
*NAS/NRC. 1989. Recommended Dietary Allowances, 10th ed. National Academy of Sciences, National Research Council, Food and Nutrition Board. National Academy Press, Washington DC.
*Nash RC, Beall ML. 1980. Distribution of silvex, 2,4-D, and TCDD applied to turf in chambers and field plots. J Agri Food Chem 28(3):614–623.
*NATICH. 1992. National Air Toxics Information and Clearinghouse. Database report on state, local, and EPA air toxics activities. Washington, DC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards.
*Nau H, Bass R. 1981. Transfer of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) to the mouse embryo and fetus. Toxicology 20:299–308.7314120
*Nau H, Bass R, Neubert D. 1986. Transfer of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) via placenta and milk, and postnatal toxicity in the mouse. Arch Toxicol 59:36–40.3741141
Nauman CH, Schaum JL. 1987. Human exposure estimation for 2,3,7,8-TCDD. Chemosphere 16:1851–1856.
*NCASI. 1993. Summary of data reflective of pulp and paper industry progress in reducing the TCDD/TCDF content of effluents, pulps and wastewater treatment sludges. National Council of the Paper Industry for Air and Stream Improvement, Inc. Special report no. 93-08.
*NCI/NTP. 1979a. Bioassay of 2,7-dichlorodibenzo-p-dioxin (DCDD) for possible carcinogenicity. Bethesda MD: U.S. Department of Health, Education, and Welfare, Public Health Service, National Cancer Institutes/National Toxicology Program. (NIH) DHEW Publication no. 79-1378.
*NCI/NTP. 1979b. Bioassay of dibenzo-p-dioxin for possible carcinogenicity. Bethesda MD: U.S. Department of Health, Education, and Welfare, Public Health Service, National Cancer Institutes/National Toxicology Program. (NIH) DHEW Publication no. 79-1377.
*NCI/NTP. 1980. Bioassay of a mixture of 1,2,3,6,7,8-hexachlorodibenzo-p-dioxin and 1,2,3,7,8,9-hexachlorodibenzo-p-dioxin (gavage) for possible carcinogenicity: CAS No. 57653-85-7, CAS No. 19408-74-3. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health/National Toxicology Program. NCI Carcinogen Tech Rep Ser no. 198. NTP no. 80-12.
Nebert DW, Robinson JR, Niwa A, . 1975. Genetic expression of aryl hydrocarbon hydroxylase activity in the mouse. J Cell Physiol 85:393–414.1091656
*Needham LL, Gerthoux PM, Patterson DG, . 1994. Half-life of 2,3,7,8-tetrachlorodibenzo-p-dioxin in serum of Seveso adults: Interim report. Organohalogen Compounds 21:81–85.
Needham LL, Patterson DG, Alley CC, . 1987. Polychlorinated dibenzo-p-dioxins and dibenzofurans levels in persons with high and normal levels of 2,3,7,8-tetrachlorodibenzo-p-dioxins. Chemosphere 16:2027–2031.
*Needham LL, Patterson DG Jr, Burse VW, . 1996. Reference range data for assessing exposure to selected environmental toxicants. Toxicology and Industrial Health 2(3/4):507–513.
*Needham LL, Patterson DG Jr, Houk VN. 1991. Levels of TCDD in selected human populations and their relevance to human risk assessment. Banbury Report 35: Biological basis for risk assessment of dioxins and related compounds. Cold Spring Harbor Press, 229–247.
Needham LL, Patterson DG Jr, Pirkle JL, . 1989. The basis of measuring 2,3,7,8-tetrachloro-dibenzo-p-dioxin in serum. Chemosphere 18:425–430.
*Nelson CJ, Holson JF, Green HG, . 1979. Retrospective study of the relationship between agricultural use of 2,4,5-T and cleft palate occurrence in Arkansas. Teratol 19:377–384.
*Nessel CS, Amoruso MA, Umbreit TH, . 1990. Hepatic aryl hydrocarbon hydroxylase and cytochrome P450 induction following the transpulmonary absorption of TCDD from intratracheally instilled particles. Fundam Appl Toxicol 15:500–509.2258014
*Nessel CS, Amoruso MA, Umbreit TH, . 1992. Pulmonary bioavailability and fine particle enrichment of 2,3,7,8-tetrachlorodibenzo-p-dioxin in respirable soil particles. Fundam Appl Toxicol 19(2):279–85.1516786
*Nessel CS, Butler JP, Post GB, . 1991. Evaluation of the relative contribution of exposure routes in a health risk assessment of dioxin emissions from a municipal waste incinerator. J Exposure Anal Environ Epidemiol 1(3):283–307.
Nestrick TJ, Lamparski LL. 1983. Assessment of chlorinated dibenzo-p-dioxin formation and potential emission to the environment from wood combustion. Chemosphere 12:617–626.
*Nestrick TJ, Lamparski LL, Frawley NN, . 1986. Perspectives of a large scale environmental survey for chlorinated dioxins: Overview and soil data. Chemosphere 15:1453–1460.
*Nestrick TJ, Lamparski LL, Townsend DI. 1980. Identification of tetrachlorodibenzo-p-dioxin isomers at the 1-ng level by photolytic degradation and pattern recognition techniques. Anal Chem 52:1865–1874.
*Neubert D, Dillman I. 1972. Embryotoxic effects in mice treated with 2,4,5-trichlorophenoxyacetic acid and 2,3,7,8-tetrachlorodibenzo-p-dioxin. Arch Pharmacol 272:243–264.
*Neubert D, Golor G, Neubert R. 1992c. TCDD-toxicity equivalencies for PCDD/PCDF congeners: prerequisites and limitations. Chemosphere 25:65–70.
*Neubert D, Wiesmueller T, Abraham K, . 1990a. Persistence of various polychlorinated dibenzo-p-dioxins and dibenzofurans (PCDDs and PCDFs) in hepatic and adipose tissue of marmoset monkeys. Arch Toxicol 64:431–442.2125825
Neubert D, Zens P, Rothenwallner A, . 1973. A survey of the embryotoxic effects of TCDD in mammalian species. Environ Health Perspect 5:67–79.4270943
*Neubert R, Golor G, Stahlmann R, . 1992a. Dose-dependent TCDD-induced increase or decrease in T-lymphocyte subsets in the blood of New World monkeys (Callithrix jacchus). Chemosphere 25(7–10):1201–1206.
*Neubert R, Golor G, Stahlmann R, . 1992b. Polyhalogenated dibenzo-p-dioxins and dibenzofurans and the immune system. 4. Effects of multiple-dose treatment with 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on peripheral lymphocyte subpopulations of a nonhuman primate (Callithrix jacchus). Arch Toxicol 66(4):250–259.1514923
*Neubert R, Jacob-Müller U, Helge H, . 1991. Polyhalogenated dibenzo-p-dioxins and dibenzofurans and the immune system. Arch Toxicol 65:213–219.1905127
*Neubert R, Jacob-Müller U, Stahlmann R, . 1990b. Polyhalogenated dibenzo-p-dioxins and dibenzofurans and the immune system. I. Effects on peripheral lymphocyte subpopulations of a non-human primate (Callithrix jacchus) after treatment with 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Arch Toxicol 64:345–359.2403285
*Neubert R, Maskow L, Delgado I, . 1995. Chlorinated dibenzo-p-dioxins and dibenzofurans and the human immune system. 2. In vitro proliferation of lymphocytes from workers with quantified moderately-increased body burdens. Life Sci 56:421–436.7830503
*Neubert R, Maskow L, Webb J, . 1993. Chlorinated dibenzo-p-dioxins and dibenzofurans and the human immune system. 1. Blood cell receptors in volunteers with moderately increased body burdens. Life Sci 53:1995–2006.8255162
*Neuhold LA, Gonzalez FJ, Jaiswal AK, . 1986. Dioxin inducible enhancer region upstream from the mouse Pi-450 gene and interaction with a heterologous SV40 promoter. DNA 5:403–411.3023000
*Neuhold LA, Shirayoshi Y, Ozato K, . 1989. Regulation of mouse CYP1A1 gene expression by dioxin: requirements of two cis-acting elements during induction. Mol Cell Biol 9:2378–2386.2548080
Neumann CM, Brauner JA, Kerkvliet NI. 1991. T cell activation in vivo via the CD3 receptor: Effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) exposure [Abstract 48]. Toxicologist 11:36.
*Neumann CM, Oughton JA, Kerkvliet NI. 1993. Anti-CD3-induced T-cell activation. II. Effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Int J Immunopharmacol 15(4):543–50.8365828
Neupert M, Grupe A, Weis H. 1988. Stability of polybrominated dibenzo-p-dioxins and dibenzofurans under laboratory handling conditions. Chemosphere 17:1089–1097.
Newsome WH, Iverson F, Ryan JJ, . 1984. Chlorinated compounds in tissues of chickens raised on pentachlorophenol-contaminated litter. Food Addit Contam 1:3–9.6537345
Nguyen TNP, Bui SH, Dan QV, . 1989. Dioxin levels in adipose tissues of hospitalized women living in the south of Vietnam in 1984-85 with a brief review of their clinical histories. Chemosphere 19:933–936.
Niemann RA. 1986. Surrogate-assisted determination of 2,3,7,8-tetrachlorodibenzo-para-dioxin in fish by electron-capture capillary gas-chromatography. J Assoc Off Anal Chem 69:976–980.3804953
Niimi AJ, Oliver BG. 1986. Biological half-lives of chlorinated dibenzo-p-dioxins and dibenzofurans in rainbow trout (Salmo gairdneri). Environ Toxicol Chem 5:49–53.
*Niimi AJ, Oliver BG. 1989a. Distribution of polychlorinated biphenyl congeners and other halocarbons in whole fish and muscle among Lake Ontario salmonids. Environ Sci Technol 23:83–88.
*Niimi AJ, Oliver BG. 1989b. Assessment of relative toxicity of chlorinated dibenzo-p-dioxins, and biphenyls in Lake Ontario salmonids to mammalian systems using toxic equivalent factors (TEF). Chemosphere 18(7–8):1413–1423.
NIOSH. 1984. 2,3,7,8-Tetrachlorodibenzo-p-dioxin. Current intelligence bulletin 40. Cincinnati, OH: Department of Health and Human Services, National Institute for Occupational Safety and Health.
NIOSH. 1992. NIOSH Recommendations for Occupational Safety. U. S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, Division of Standards Development and Technology Transfer. Cincinnati, OH.
*NIOSH. 1997. NIOSH pocket guide tochemical hazards. U.S. Depatment of Health and Human Services. Public Health Services. Centers for Disease Control and Prevention. National Institute for Occupational Safety and Health.
Nirmalakhandan NN, Speece RE. 1989. Prediction of aqueous solubility of organic chemicals based on molecular structure: 2. Application to PNAs, PCBs, PCDDs, etc. Environ Sci Technol 23:708–713.
Nisbet ICT, Paxton MB. 1982. Statistical aspects of three-generation studies of the reproductive toxicity of TCDD and 2,4,5-T. Am Stat 36:290–298.
Noble R, Walker S, Sherman P, . 1991. Dioxins in the analytical laboratory. IARC Sci Publ 108:181–196
*Nobmann ED Byers T Lanier AP . 1992. The diet of Alaska native adults: 1987-1988. Am J Clin Nutr 55:1024–1032.1570796
Nolan RJ, Smith FA, Hefner JG. 1979. Elimination and tissue distribution of 2,3,7,8-tetrachloro-dibenzo-p-dioxin (TCDD) in female guinea pigs following a single oral dose. Toxicol Appl Pharmacol 48:A162.
Norback DH, Allen JR. 1973. Biological responses of the nonhuman primate, chicken, and rat to chlorinated dibenzo-p-dioxin ingestion. Environ Health Perspect 5:233–240.4201767
*Norback DH, Engblom JF, Allen JR. 1975. Tissue distribution and extraction of octachlorodibenzo-para-dioxin in the rat. Toxicol Appl Pharmacol 32:330–338.1154398
Noren K. 1988. Changes in the levels of organochlorine pesticides, polychlorinated biphenyls, dibenzo-p-dioxins and dibenzofurans in human milk from Stockholm, Sweden 1972-1985. Chemosphere 17:39–50.
*Noren K, Sj÷vall J. 1987. Analysis of organochlorine pesticides, polychlorinated biphenyls, dibenzo-p-dioxins and dibenzofurans in human milk by extraction with the lipophilic gel Lipidex« Noren K. J Chromator 422:103–115.
Norris LA. 1981. The movement, persistance, and fate of the phenoxy herbicides and TCDD in forests. Residue Reviews 80:65–135.
*Norstrom RJ, Simon M, Muir DCG. 1990. Polychlorinated dibenzo-p-dioxins and dibenzofurans in marine mammals in the Canadian north. Environ Pollut 66:1–19.15092247
*Norwood CB, Hackett M, Pruell RJ, . 1989. Polychlorinated dibenzo-p-dioxins and dibenzofurans in selected estuarine sediments. Chemosphere 18:553–560.
*Nosek JA, Craven SR, Sullivan JR, . 1992. Metabolism and disposition of 2,3,7,8-tetrachlorodibenzo-p-dioxin in ring-necked pheasant hens, chicks and eggs. J Toxicol Environ Health 35(3):153–164.1602521
Nottrodt IA, Ballschmiter K. 1986. Causes for and reduction strategies against emissions of PCDD/PCDF from waste incineration plants-interpretations of recent measurements. Chemosphere 15:1225–1237.
*NRC. 1993. Pesticides in the Diets of Infants and Children. National Research Council. Washington DC: National Academy Press.
NRCC. 1981. Polychlorinated dibenzo-p-dioxins: Criteria for their effects on man and his environment. Ottawa, Canada: National Research Council of Canada, Associate Committee on Scientific Criteria for Environmental Quality. NRCC no. 18574.
*NREPC. 1986. National Resources and Environmental Protection Cabinet. Department for Environmental Protection. Frankfort, KY: Proposed Regulation. 401 KAR 63:022.
*NREPC. 1988. National Resources and Environmental Protection Cabinet. Kentucky Waste Management Regulations. Frankfort, KY: Department for Environmental Protection, Division of Waste Management. 401 KAR 31:030, 040, and 160.
*NTP. 1982a. Carcinogenesis bioassay of 2,3,7,8-tetrachlorodibenzo-p-dioxin (CAS no. 1746-01-6) in Swiss-Webster mice (dermal study). Bethesda, MD: Carcinogenesis Testing Program, National Cancer Institute, National Institute of Health. Research Triangle Park, NC: National Toxicology Program. (NIH) DHHS publication no 82-1757.
*NTP. 1982b. Carcinogenesis bioassay of 2,3,7,8-tetrachlorodibenzo-p-dioxin (CAS no. 1746-01-6) in Osborne-Mendel rats and B6C3F1 mice (gavage study). Bethesda, MD: Carcinogenesis Testing Program, National Cancer Institute, National Institute of Health. Research Triangle Park, NC: National Toxicology Program. (NIH) DHHS publication no 82-1765.
*NTP. 1989. Fifth annual report on carcinogens. Summary. U.S. Department of Health and Human Services, Public Health Services, Research Triangle Park, NC, by Technical Resources, Inc., Rockville, MD.
*NTP. 1995. Long term technical reports and short term toxicity study reports. National Toxicology Program. National Institute of Occupations Safety and Health, Research Triangle Park, NC.
*NTP. 1998. Eighth Annual Report on Carcinogens. U.S. Department of Health and Human Services, Public Health Services, Research Triangle Park, NC. http://www.ehis.niehs.nih.gov/roc/eighth/chemicals/tcdd.pdf.
*NTP. 1998. Eighth report on carcinogens. 1998 Summary. U.S. Department of Health and Human Services. Public Health Services. National Toxicology Program.
*Nygren M, Hansson M, Sj÷str÷m M, . 1988. Development and validation of a method for determination of PCDDs and PCDFs in human blood plasma: A multivariate comparison of blood and adipose tissue levels between Vietnam veterans and matched controls. Chemosphere 17:1663–1692.
*Nygren M, Rappe C, Lindstrom G, . 1986. Identification of 2,3,7,8-substituted polychlorinated dioxins and dibenzofurans in environmental and human samples. In: Rappe C, Choudhary G, Keith LH, eds. Chlorinated dioxins and dibenzofurans in perspective. Chelsea, MI: Lewis Publishers, Inc., 17–34.
*NYPDWS. 1989. New York Public Drinking Water Standards. Code revision, effective 1/9/89.
*NYWQSGV. 1987. New York Water Ambient Quality Standards and Guidance Values, 4/1/87.
O’Keefe P, Hilker D, Meyer C, . 1984. Tetrachlorodibenzo-p-dioxins and tetrachlorodibenzofurans in Atlantic Coast striped bass and in selected Hudson River fish, waterfowl and sediments. Chemosphere 13:849–860.
*O’Keefe P, Meyer C, Smith R, . 1986. Reverse-phase adsorbent cartridge for trapping dioxins in drinking water. Chemosphere 15:1127–1134.
O’Keefe PW, Smith RM, Hilker DR, . 1989. Interlaboratory validation of PCDD and PCDF concentrations found in municipal incinerator emissions. Chemosphere 18:185–192.
Oberg T, Bergstrom JGT. 1987. Emission and chlorination pattern of PCDD/PCDF from indicator parameters. Chemosphere 16:1221–1230.
*Oehme M, Mano S, Bjerke B. 1989. Formation of polychlorinated dibenzofurans and dibenzo-p-dioxins by production processes for magnesium and refined nickel. Chemosphere 18:1379–1389.
*Oehme M, Mano S, Mikalsen A, . 1986. Quantitative method for the determination of femtogram amounts of polychlorinated dibenzo-p-dioxins and dibenzofurans in outdoor air. Chemosphere 15:607–617.
*Oehme M, Mano S, Mikalsen A, . 1987. Formation and presence of polyhalogenated and polycyclic compounds in the emissions of small and large scale municipal waste incinerators. Chemosphere 16:143–153.
Ogaki J, Takayama K, Miyata H, . 1987. Levels of PCDDs and PCDFs in human tissues and various foodstuffs in Japan. Chemosphere 16:2047–2056.
*Okey AB, Riddick DS, Harper PA. 1994. The Ah receptor: Mediator of the toxicity of 2.3.7.8-tetrachlorodibenzo-p-dioxin (TCDD) and related compounds. Toxicol Lett 70(1):1–22.8310450
*Okey AB, Vella LM, Harper PA. 1989. Detection and characterization of a low affinity form of cytosolic Ah receptor in livers of mice nonresponsive to induction of cytochrome P1-450 by 3-methylcholanthrene. Mol Pharmacol 35: 823–830.2543914
*Okino ST, Pendurthi UR, Tukey RH. 1992. Phorbol esters inhibit the dioxin receptor-mediated transcriptional activation of the mouse CYP1A1 and CYP1A2 genes by 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Biol Chem 267:6991–6998.1313028
*Oku A, Tomari K, Kamada T, . 1995. Destruction of PCCDs and PCDFs. A convenient method using alkali-metal hydroxide in 1,3,-dimethyl-2-imidazolidinone (DMI). Chemosphere 31(8):3873–3878.
Olie K, Schecter A, Constable J, . 1989. Chlorinated dioxin and dibenzofuran levels in food and wildlife samples in North and South Vietnam. Chemosphere 19:493–496.
Olie K, Slot PC, Wever H. 1989. Decomposition of octachlorodibenzofuran and formation of the hepta congeners during GLC analysis. Chemosphere 19:103–108.
Olie K, Vermeulen PL, Hutzinger O. 1977. Chlorodibenzo-p-dioxins and chlorodibenzofurans are trace compounds in fly ash and flue gas of some municipal incinerators in the Netherlands. Chemosphere 8:455–459.
*Oliver RM. 1975. Toxic effects of 2,3,7,8-tetrachlorodibenzo-1,4-dioxin in laboratory workers. Br J Ind Med 32:49–53.123754
*Olson JR. 1986. Metabolism and disposition of 2,3,7,8-tetrachlorodibenzo-p-dioxin in guinea pigs. Toxicol Appl Pharmacol 85:263–273.3764914
Olson JR, Bellin JS, Barnes DG. 1989. Reexamination of data used for establishing toxicity equivalence factors (TEFs) for chlorinated dibenzo-para-dioxins and dibenzofurans (CDDs and CDFs). Chemosphere 18:371–381.
Olson JR, Gasiewicz TA, Geiger LE, . 1983. The metabolism of 2,3,7,8-tetrachlorodibenzo-p-dioxin in mammalian systems. In: Coulston R, Pocchiari F, eds. Accidental exposure to dioxins: Human health aspects. New York, NY: Academic Press, 81–100.
*Olson JR, Gasiewicz TA, Neal RA, . 1980b. Tissue distribution excretion, and metabolism of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in the Golden Syrian Hamster. Toxicol Appl Pharmacol 56:78–85.7444968
*Olson JR, Holscher MA, Neal RA. 1980a. Toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin in the Golden Syrian hamster. Toxicol Appl Pharmacol 55:67–78.7423509
*Olson JR, McGarrigle BP. 1992. Comparative developmental toxicity of 2,3,7,8-tetrachloro-dibenzo-p-dioxin (TCDD). Chemophere 25(1–2):71–74.
*Olson JR, Wroblewski VJ. 1985. Metabolism of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in isolated hepatocytes from guinea pigs and rats. Chemosphere 14:979–982.
*Ono M, Kashima Y, Wakimoto T, . 1987. Daily intake of PCDDs and PCDFs by Japanese through food. Chemosphere 16:1823–1828.
Ono M, Wakimoto T, Tatsukawa R, . 1986. Polychlorinated dibenzo-p-dioxins and dibenzofurans in human adipose tissues of Japan. Chemosphere 15:1629–1634.
Onuska FI. 1988. Trials, tribulations and trends in analysis of chlorinated dibenzo-para-dioxins [Abstract]. Abstracts of Papers of the American Chemical Society 195:203.
*Onuska FI, Mudroch A, Terry KA. 1983. Identification and determination of trace organic substances in sediment cores from the western basin of Lake Ontario. J Great Lakes Res 9:169–182.
*Oppelt ET. 1991. Air emissions from the incineration of hazardous waste. In: Mehlman MA, ed. Advances in modern environmental toxicology. Vol XIX. Health hazards and risks from exposure to complex mixtures and air toxic chemicals. Princeton, NJ: Princeton Scientific Publishing Co., Inc., 1–26.
Opperhuizen A. 1986. Bioconcentration of hydrophobic chemicals in fish. ASTM Spec Tech Publ 9:304–315.
Opperhuizen A, Sijm DTHM. 1990. Bioaccumulation and biotransformation of polychlorinated dibenzo-p-dioxins and dibenzofurans in fish. Environ Toxicol Chem 9:175–186.
*Orazio CE, Kapila S, Puri RK, . 1992. Persistence of chlorinated dioxins and furans in the soil environment. Chemosphere 25(7–10):1469–1474.
*Orban JE, Stanley JS, Schwemberger JG, . 1994. Dioxins and dibenzofurans in adipose tissue of the general U.S. population and selected subpopulations. Am J Public Health 84:439–445.8129062
Orth RG, Ritchie C, Hileman F. 1989. Measurement of the photoinduced loss of vapor phase TCDD. Chemosphere 18:1275–1282.
*OSHA. 1987. Access to employee exposure and medical records. U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.20.
*OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Office of Technology Assessment, Washington, DC. OTA-BA-438.
*Ott MG, Holder BB, Olson RO. 1980. A mortality analysis of employees engaged in the manufacture of 2,4,5-trichlorophenoxyacetic acid. J Occup Med 22:47–50.7354412
*Ott MG, Messerer P, Zober A. 1993. Assessment of past occupational exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin using blood lipid analysis. Int Arch Environ Health 65:1–8.
*Ott MG, Olson RA, Cook RR. 1987. Cohort mortality study of chemical workers with potential exposure to the higher chlorinated dioxins. J Occup Med 29:422–429.2439670
*Ott MG, Zober A. 1996. Cause specific mortality and cancer incidence among employees exposed to 2,3,7,8-TCDD after a 1953 reactor accident. Occup Environ Med 53:606–612.8882118
*Ott MG, Zober A, Germann C. 1994. Laboratory results for selected target organs in 138 individuals occupationally exposed to TCDD. Chemosphere 29:9–11.
*Oughton JA, Pereira CB, DeKrey GK, . 1995. Phenotypic analysis of spleen, thymus, and peripheral blood cells in aged C57BL/6 mice following long-term exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Fund Appl Toxicol 25:60–69.
*Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: Saunders, 222–238.
Ozvacic V. 1986. A review of stack sampling methodology for PCDDs/PCDFs. Chemosphere 15:1173–1178.
*Päpke O, Ball M, Lis A. 1992. Various PCDD/PCDF patterns in human blood resulting from different occupational exposures. Chemosphere 25:1101–8.
*Päpke O, Ball M, Lis A. 1993. Potential occupational exposure of municipal waste incinerator workers with PCDD/PCDF. Chemosphere 27:203–9.
Päpke O, Ball M, Lis ZA, . 1989a. PCDD and PCDF in indoor air of kindergartens in northern W. Germany. Chemosphere 18:617–626.
*Päpke O, Ball M, Lis ZA, . 1989b. PCDD/PCDF in whole blood samples of unexposed persons. Chemosphere 19:941–948.
Päpke O, Ball M, Lis ZA, . 1990. Determination of PCDD/PCDF in whole blood from persons involved in fire incidents. Chemosphere 20:959–966.
Palansky J, Kapila S, Manahan SE, . 1986. Studies on vapor phase transport and role of dispersing medium on mobility of 2,3,7,8-TCDD in soil. Chemosphere 15:1389–1396.
*Park J-Y K, Shigenaga MK, Ames BN. 1996. Induction of cytochrome P4501A1 by 2,3,7,8-tetrachlorodibenzo-p-dioxin or indolo(3,2-b) carbazole is associated with oxidative DNA damage. Proc Natl Acad Sci USA 93: 2322–2327.8637871
Parlar H. 1984. Geochemical induced degradation of environmental chemicals. Presenius Z Anal Chem 319:114–118.
*Parsons JR. 1992. Influence of suspended sediment on the biodegradation of chlorinated dibenzo-p-dioxins. Chemosphere 25(12):1973–1980
Parsons JR, Storms MCM. 1989. Biodegradation of chlorinated dibenzo-p-dioxins in batch and continuous cultures of strain JB1. Chemosphere 19:1297–1308.
*Patterson DG Jr, Fingerhut MA, Roberts DW, . 1989a. Levels of polychlorinated dibenzo-p-dioxins and dibenzofurans in workers exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Am J Ind Med 16:135–146.2773945
*Patterson DG Jr, Fürst P, Alexander LR, . 1989b. Analysis of human serum for PCDDs/PCDFs: A comparison of three extraction procedures. Chemosphere 19:89–96.
*Patterson DG Jr, Fürst P, Henderson LO, . 1989d. Partitioning of in vivo bound PCDDs/PCDFs among various compartments in whole blood. Chemosphere 19:135–142.
*Patterson DG Jr, Hampton L, Lapeza Cr Jr, . 1987a. High-resolution gas chromatographic/high-resolution mass spectrometric analysis of human serum on a whole-weight and lipid basis for 2,3,7,8-tetrachlorodibenzo-p-dioxin. Anal Chem 59:2000–2005.3631519
*Patterson DG Jr, Hoffman RE, Needham LL, . 1986a. 2,3,7,8-Tetrachlorodibenzo-p-dioxin levels in adipose tissue of exposed and control persons in Missouri. JAMA 256:2683–2686.3490589
*Patterson DG Jr, Holler JS, Belser WT, . 1987b. Determination of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in human adipose tissue on whole-weight and lipid basis. Chemosphere 16:935–936.
Patterson DG Jr, Holler JS, Lapeza CR Jr, . 1986b. High-resolution gas chromatographic/high-resolution mass spectrometric analysis of human adipose tissue for 2,3,7,8-tetrachlorodibenzo-p-dioxin. Anal Chem 58:705–713.3706742
Patterson DG Jr, Holler JS, Smith SJ, . 1986c. Human adipose data for 2,3,7,8-tetrachlorodibenzo-p-dioxin in certain US samples. Chemosphere 15:2055–2060.
Patterson DG Jr, Needham LL, Pirkle JL, . 1988. Correlation between serum and adipose tissue levels of 2,3,7,8-tetrachlorodibenzo-p-dioxin in 50 persons from Missouri. Arch Environ Contam Toxicol 17:139–143.3355228
Patterson DG Jr, Reddy W, Barnhart ER, . 1989c. Synthesis and analytical characterization of all tetra to octachlorodibenzo-p-dioxins. Chemosphere 19:233–240.
Patterson DG Jr, Turner WE, Isaacs SG, . 1990. A method performance evaluation and lessons learned after analyzing more than 5,000 human adipose tissue, serum, and breast milk samples for polychlorinated dibenzo-p-dioxins (PCDDs) and dibenzofurans (PCDFs). Chemosphere 20:829–863.
*Patterson Jr. DG, Todd GD, Turner WE, . 1994. Levels of non-ortho-substituted (coplanar), mono- and di-ortho-substituted polychlorinated biphenyls, dibenzo-p-dioxins, and dibenzofurans in human serum and adipose tissue. Environ Health Perspect 102(supp 1):195–204.
*Paulson KE, Darnell J Jr, Rushmore T, . 1990. Analysis of the upstream elements of the xenobiotic compound-inducible and positionally regulated glutathione S-transferase Ya gene. Mol Cell Biol 10:1841–1852.2325638
*Paustenbach D, Finley B, Lau V, . 1991. An evaluation of the inhalation hazard posed by diozin-contaminated soils. J Air Waste Manage Assn. 41:1334–1340.
Paustenbach DJ, Shu HP, Murray FJ. 1986. A critical examination of assumptions used in risk assessments of dioxin contaminated soil. Regul Toxicol Pharmacol 6:284–307.3775086
*Paustenbach DJ, Wenning RJ, Lau V, . 1992. Recent developments on the hazards posed by 2,3,7,8-tetrachlorodibenzo-p-dioxin in soil: Implications for setting risk-based cleanup levels at residential and industrial sites. J Toxicol Environ Health 36(2):103–150.1608067
*Pazdernik TL, Rozman KK. 1985. Effect of thyroidectomy and thyroxine on 2,3,7,8-tetrachlorodibenzo-p-dioxin-induced immunotoxicity. Life Sci 36:695–703.3881642
*Pazderova-Vejlupkova J, Nemcova M, Pickova J, . 1981. The development and prognosis of chronic intoxication by tetrachlorodibenzo-p-dioxin in men. Arch Environ Health 36:5–11.7469493
*Pearson RG, McLaughlin DL, McIlveen WD. 1990. Concentrations of PCDD and PCDF in Ontario soils from the vicinity of refuse and sewage sludge incinerators and remote rural and urban locations. Chemosphere 20(10–12):1543–1548.
Pedersen LG, Darden TA, Oatley SJ, . 1986. A theoretical study of the binding of polychlorinated biphenyls (PCBs), dibenzodioxins, and dibenzofuran to human plasma prealbumin. Journal of Medicinal Chemistry 29:2451–2457.3097319
*Pegg DG, Hewett WR, McCormack K, . 1976. Effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin on renal function in the rat. J Toxicol Environ Health 2:55–65.994246
*Pegram RA, Diliberto JJ, Moore TC, . 1995. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD) distribution and cytochrome P4501A induction in young adult and senescent male mice. Toxicol Letters 76:119–126.
Pelizzetti E, Borgareelo M, Minero C, . 1988. Photocatalytic degradation of polychlorinated dioxins and polychlorinated biphenyls in aqueous suspensions of semiconductors irradiated with simulated solar light. Chemosphere 17:499–510.
*Peper M, Klett M, Frentzel-Beyme R, . 1993. Neuropsychological effects of chronic exposure to environmental dioxins and furans. Environ Res 60:124–135.8432263
Perdew GH. 1991. Chemical cross-linking of the cytosolic and nuclear forms of the Ah receptor: determination of protein composition [Abstract 12]. Toxicologist 11:27.
Perdew GH. 1992. Chemical cross-linking of the cytosolic and nuclear form of the Ah receptor in hepatoma cell line 1c1c7. Biochem Biophys Res Comm 182:55–62.1310021
*Pereira WE, Rostad CE, Sisak ME. 1985. Geochemical investigation of polychlorinated dibenzo-p-dioxins in the subsurface environment at an abandoned wood-treatment facility. Environ Toxicol Chem 4:629–639.
*Pesatori AC, Consonni S, Tironi A, . 1993. Cancer in a young population in a dioxin-contaminated area. Int J Epidemiol 22:1010–1013.8144281
*Pesatori AC, Zocchetti C, Guercilena S, . 1998. Dioxin exposure and non-malignant health effects: A mortality study. Occup Environ Med 55:126–131.9614398
Peterson RE, Seefeld MD, Christian BJ, . 1984. The wasting syndrome in 2,3,7,8-tetrachlorodibenzo-p-dioxin toxicity: Basic features and their interpretation. In: Poland A, Kimbrough RD, eds. Banbury Rep 18. Cold Spring Harbor Laboratory, 291–308.
*Peterson RE, Theobald HM, Kimmel GL. 1993. Developmental and reproductive toxicity of dioxins and related compounds: Cross-species comparisons. Crit Rev Toxicol 23:283–335.8260069
Petreas MX, Wiesmuller T, Palmer FH, . 1992. Aquatic life as biomonitors of dioxin/furan and coplanar polychlorinated biphenyls contamination in the Sacramento-San Joaquin River Delta. Chemosphere 25(4):621–631.
Petty J, Rodgers P. 1985. Source, distribution and fate-workshop summary. In: Kamrin MA, Rodgers PW, eds. Dioxins in the environment. Washington, DC: Hemisphere Publishing Corporation, 299–306.
Petty JD, Stalling DL, Smith LM, . 1983. Occurrence and potential impact of PCDFs and PCDDs in aquatic ecosystems. Trace Subst Environ Health 17:96–102.
Pfeiffer Cd. 1976. Determination of chlorinated dibenzo-p-dioxins in pentachlorophenol by liquid chromatography. J Chromatogr Sci 14:386–391.
*Phiet PH, Anh TK, Vu DQ, . 1989. Preliminary observations on the clinical histories, polychlorinated dibenzodioxin and dibenzofuran tissue levels and 2,3,7,8-TCDD toxic equivalents of potentially dioxin-exposed patients living in the south of Vietnam. Chemosphere 19:937–940.
Philippi M, Krasnobage V, Zeyer J, . 1981. Fate of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in microbial cultures and soil under laboratory conditions. FEMS Symp 12:2210–2233.
*Philippi M, Schmid J, Wipf HK, . 1982. A microbial metabolite of TCDD. Experientia 38:659–661.7106232
*Phillips LJ, Birchard GF. 1991. Regional variations in human toxics exposure in the USA: An analysis based on the national human adipose tissue survey. Arch Environ Contam Toxicol 21:159–168.1958071
*PHS. 1992. CCEHRP interim statement on dioxins. Committee to Coordinate Environmental Health and Related Programs, interagency committee.
*Phuong NTN, Hung BS, Vu DQ, . 1989b. Dioxin levels in adipose tissues of hospitalized women living in south of Vietnam in 1984-85 with a brief review of their clinical histories. Chemosphere 19:933–936.
*Phuong NTN, Thuy TT, Phuong PK. 1989a. An estimate of reproductive abnormalities in women inhabiting herbicide sprayed and non-herbicide sprayed areas in the south of Vietnam, 1952-1981. Chemosphere 18:843–846.
Piper WN, Rose RQ, Gehring PJ. 1973. Excretion and tissue distribution of 2,3,7,8-tetrachlorodibenzo-p-dioxin in the rat. Environ Health Perspect 5:241–244.4778781
Piper WN, Ruangwises S, Bestervelt LL, . 1991. Leydig cell testosterone production and P45017 (17-hydroxylase and C17-20lyase) activities after in vitro exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) [Abstract 997]. Toxicologist 11:262.
*Pirkle J, Wolfe W, Patterson D, . 1989. Estimates of the half-life of 2,3,7,8-tetrachlorodibenzo-p-dioxin in Vietnam veterans of Operation Ranch Hand. J Toxicol Environ Health 27:165–171.2733058
*Piskorska-Pliszczynska J, Astroff B, Zacharewski T, . 1991. Mechanism of action of 2,3,7,8-tetrachlorodibenzo-p-dioxin antagonists: Characterization of [125I]-6-methyl-8-iodo-1,3-dichlorodibenzofuran-Ah receptor complexes [Abstract 1047]. Toxicologist 11: 272.
Pitea D, Bonati L, Lasagni M, . 1989a. The combustion of municipal solid wastes and PCDF emissions: Part 1. PCDD and PCDF in MSW. Chemosphere 18:1457–1464.
Pitea D, Cosentino U, Lasagni M, . 1989b. The combustion of municipal wastes and PCDD and PCDF emissions: Part 3. PCDD and PCDF in fly ash. Chemosphere 18:1475–1483.
Pitea D, Lasagni M, Bonati L, . 1989c. The combustion of municipal solid wastes and PCDD and PCDF emissions: Part 2. PCDD and PCDF in stack gases. Chemosphere 18:1465–1474.
*Pitot HC, Goldsworthy T, Campbell HA. 1980. Quantitative evaluation of the promotion by 2,3,7,8-tetrachlorodibenzo-p-dioxin of hepatocarcinogenesis from diethylnitrosamine. Cancer Res 40:3616–3620.6108157
*Plimmer JR, Klingebiel UI, Crosby DG, . 1973. Photochemistry of dibenzo-p-dioxins. In: Blair EH, ed. Chlorodioxins-origin and fate. Washington, DC: Advances in Chemistry Series, 44–54.
Pluess N, Poiger H, Hohback C, . 1988. Subchronic toxicity of some chlorinated dibenzofurans (PCDFs) and a mixture of PCDFs and chlorinated dibenzodioxins (PCDDs) in rats. Chemosphere 17:973–984.
*Pluim HJ, Boersma ER, Kramer I, . 1994c. Influence of short-term dietary measures on dioxin concentrations in human milk. Environ Health Perspect 102:968–971.9738212
*Pluim HJ, deVijlder JJM, Olie K, . 1993c. Effects of pre and postnatal exposure to chlorinated dioxins and furans on human neonatal thyroid hormone concentrations. Environ Health Perspect 101:504–508.8137779
*Pluim HJ, Koope JG, Olie K, . 1994a. Clincal laboratory manifestations of exposure to background levels of dioxins in the perinatal period. Act Paediatr 83:583–587.
*Pluim HJ, Koppe GJ, Oilie K, . 1992. Effect of dioxins on thyroid function in newborn babies. Lancet 3339:1303.
*Pluim HJ, van der Goot M, Olie K, . 1996. Missing effects of background dioxin exposure on development of breast-fed infants during the first half year of life. Chemosphere 33:1307–1315.8799995
*Pluim HJ, van der Slikke JW, Koppe JG, . 1993a. Levels of PCDDs and PCDFs in human milk: Dependence on several parameters and dietary habits. Chemosphere 26(10):1889–1894.
*Pluim HJ, van der slikke JW, Olie K, . 1994b. Dioxins and vitamin K status of the newborn. J Environ Sci Health A29:793–802.
*Pluim HJ, Wever J, Koppe JG, . 1993b. Intake and fecal excretion of chlorinated dioxins and dibenzofurans in breast-fed infants at different ages. Chemosphere 26:1947–1952.
*Pocchiari F, Silano V, Zampieri A. 1979. Human health effects from accidental release of tetrachlorodibenzo-p-dioxin (TCDD) at Seveso, Italy. Ann NY Acad Sci 320:311–320.287395
*Podoll RT, Jaber HM, Mill T. 1986. Tetrachlorodibenzodioxin: Rates of volatilization and photolysis in the environment. Environ Sci Technol 20:490–492.19994933
Poellinger L, Cuthill S, Wihelmsson A. 1991. The dioxin receptor: A signal-dependent gene regulatory protein [Abstract 13]. Toxicologist 11:27.
Poellinger L, Lund J, Soderkvist P, . 1986. The receptor for 2,3,7,8-TCDD: Structure, possible functions and relationship to endocrine receptors: An overview. Chemosphere 15:9–12.
*Pohjanvirta R, Tuomisto L, Tuomisto J. 1989. The central nervous system may be involved in TCDD toxicity. Toxicology 58:167–174.2799824
Pohjanvirta R, Unkila M, Tuomisto J. 1993a. Comparative acute lethality of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD), 1,2,3,7,8-pentachlorodibenzo-p-dioxin and 1,2,3,4,7,8-hexachlorodibenzo-p-dioxin in the most TCDD-susceptible and the most TCDD-resistant rat strain. Pharmacol Toxicol 73(1):52–6.8234194
*Pohjanvirta R, Unkila M, Tuomisto JT, . 1993b. Effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on plasma and tissue beta-endorphin-like immunoreactivity in the most TCDD-susceptible and the most TCDD-resistant rat strain. Life Sci 53(19):1479–1487.8412511
*Pohjanvirta R, Vartiainen T, Uusi-Rauva A, . 1990. Tissue distribution, metabolism, and excretion of [14C]-TCDD in a TCDD-susceptible and a TCDD-resistant rat strain. Pharmacol Toxicol 66:92–100.
*Pohl H, DeRosa C, Holler J. 1995. Public health assessment for dioxins exposure from soil. Chemosphere 1995 31(1):(2437–2454).7670858
*Pohl HR, Hibbs BF. 1996. Breast-feeding exposure of infants to environmental contaminants - a public health risk assessment viewpoint: chlorinated dibenzodioxins and chlorinated dibenzofurans. Toxicol Indust Health 12(5):105–114.
*Poiger H, Buser HR. 1984. The metabolism of TCDD in the dog and rat. Banbury Rep 18:39–47.
*Poiger H, Schlatter C. 1980. Influence of solvents and adsorbents on dermal and intestinal absorption of TCDD. Food Cosmet Toxicol 18:477–481.6451493
Poiger H, Schlatter C. 1983. Animal toxicology of chlorinated dibenzo-p-dioxins. Chemosphere 12:453–462.
*Poiger H, Schlatter C. 1985. Influence of phenobarbital and TCDD on the hepatic metabolism of TCDD in the dog. Experientia 41:376–378.3972084
*Poiger H, Schlatter C. 1986. Pharmacokinetics of 2,3,7,8-TCDD in man. Chemosphere 15:1489–1494.
*Poiger H, Weber H, Schlatter CH. 1982. Special aspects of metabolism and kinetics of TCDD in dogs and rats: Assessment of toxicity of TCDD-metabolites(s) in guinea pigs. In: Hutzinger O, Frei RW, Merian E, ., eds. Chlorinated dioxins and related compounds: Impact on the environment. New York, NY: Pergamon Press, 317–325.
*Poland A, Glover E. 1973a. Chlorinated dibenzo-p-dioxins: Potent inducers of delta-aminolevulinic acid synthetase and aryl hydrocarbon hydroxylase: 2. Study of the structure-activity relationship. Mol Pharmacol 9:736–747.4762634
*Poland A, Glover E. 1973b. Mechanism of toxicity of the chlorinated dibenzo-p-dioxins. Environ Health Perspect 5:245–251.4752907
*Poland A, Glover E. 1979. An estimate of the maximum in vivo covalent binding of 2,3,7,8-tetrachlorodibenzo-p-dioxin to rat liver protein, ribosomal RNA and DNA. Cancer Res 39:3341–3344.476664
*Poland A, Glover E. 1980. 2,3,7,8-Tetrachlorodibenzo-p-dioxin segregation of toxicity with the Ah locus. Mol Pharmacol 17:86–94.7383021
*Poland A, Glover E. 1987. Variation in the molecular mass of the Ah receptor among vertebrate species and strains of rats. Biochem Biophys Res Comm 146:1439–1449.3040002
*Poland A, Glover E. 1990. Characterization and strain distribution pattern of the murine Ah receptor specified by the Ahd and Ahb-3 alleles. Mol Pharmacol 38:306–312.2169579
*Poland A, Glover E, Bradfield CA. 1991. Characterization of polyclonal antibodies to the Ah receptor prepared by immunization with a synthetic peptide hapten. Mol Pharmacol 39:20–26.1846218
*Poland A, Glover E, Kende AS. 1976. Stereospecific, high affinity binding of 2,3,7,8-tetrachlorodibenzo-p-dioxin by hepatic cytosol: Evidence that the binding species is a receptor for induction of aryl hydrocarbon hydroxylase. J Biol Chem 251:4936–4946.956169
*Poland A, Greenlee WF, Kende AS. 1979. Studies on the mechanisms of action of the chlorinated dibenzo-p-dioxins and related compounds. Ann NY Acad Sci 320:214–230.110192
*Poland A, Knutson JC. 1982. 2,3,7,8-Tetrachlorodibenzo-p-dioxin and related halogenated aromatic hydrocarbons: Examination of the mechanism of toxicity. Ann Rev Pharmacol Toxicol 22:517–554.6282188
*Poland A, Knutson JC, Glover E. 1984. Histologic changes produced by 2,3,7,8-tetrachlorodibenzo-p-dioxin in the skin of mice carrying mutations that affect the integument. J Invest Dermatol 83:454–459.6501924
*Poland A, Palen D, Glover E. 1982. Tumour promotion by TCDD in skin of HRS/J hairless mice. Nature 300:271–273.7144882
*Poland A, Palen D, Glover E. 1994. Analysis of the four alleles of the murine aryl hydrocarbon receptor. Mol Pharmacol 46: 915–921.7969080
*Poland AP, Smith D, Metter G, . 1971. A health survey of workers in a 2,4-D and 2,4,5-T plant with special attention to chloracne, porphyria cutanea tarda, and psychologic parameters. Arch Environ Health 22:316–327.4250712
*Pollenz RS, Sattler CA, Poland A. 1994. The aryl hydrocarbon receptor and aryl hydrocarbon receptor nuclear translocator protein show distinct subcellular localizations in Hepa 1c1c7 cells by immunofluorescence microscopy. Mol Pharmacol 45: 428–438.8145729
*Pongratz I, Mason GGF, Poellinger L. 1992. Dual roles of the 90 kDa heat shock protein hsp90 in modulating functional activities of the dioxin receptor. J Biol Chem 267:13728–13734.1320028
*Pongratz I, Stromstedt P-E, Mason GGF, . 1991. Inhibition of the specific DNA binding activity of the dioxin receptor by phosphatase treatment. J Biol Chem 266:16813–16817.1653248
*Popp P, Keil P, Moeder M, . 1997. Application of accelerated solvent extraction followed by gas chromatography, high-performance liquid chromatography and gas chromatography-mass spectrometry for the determination of polycyclic aromatic hydrocarbons, chlorinated pesticides and polychlorinated dibenzo-p-dioxins and dibenzofurans in solid wastes. Journal of Chromatography A 774(1–2):203–211.
*Porte C, Albaiges J. 1993. Bioaccumulation patterns of hydrocarbons and polychlorinated biphenyls in bivalves, crustaceans, and fishes. Archives of Environmental Contamination and Toxicology 26:273–281.
Portier C, Tritscher A, Kohn M, . 1993. Ligand/receptor binding for 2,3,7,8-TCDD: Implications for risk assessment. Fundam Appl Toxicol 20(1):48–56.8381755
*Potter CL, Menahan LA, Peterson RE. 1986a. Relationship of alterations in energy metabolism to hypophagia in rats treated with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Fundam Appl Toxicol 6:89–97.3086171
*Potter CL, Moore RW, Inhorn SL, . 1986b. Thyroid status and thermogenesis in rats treated with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 84:45–55.3715868
*Potter CL, Sipes IG, Russell DH. 1983. Hypothyroxinemia and hypothermia in rats in response to 2,3,7,8-tetrachlorodibenzo-p-dioxin administration. Toxicol Appl Pharmacol 69:89–95.6134353
*Pratt RM, Dencker L, Diewert VM. 1984. TCDD-induced cleft palate in the mouse: Evidence for alterations in palatal shelf fusion. Teratol Carcinogen Mutagen 4:427–436.
*Prokipcak RD, Okey AB. 1990. Equivalent molecular mass of cytosolic and nuclear forms of Ah receptor from Hepa-1 cells determined by photoaffinity labeling with 2,3,7,8-[3H]tetrachlorodibenzo-p-dioxin. Biochem Biophys Res Comm 172:698–704.2173576
*Pruell RJ, Rubinstein NI, Taplin BK, . 1993. Accumulation of polychlorinated organic contaminants from sediment by three benthic marine species. Arch Environ Contam Toxicol 24(3):290–297.
Puhvel SM, Connor MJ, Sakamoto M. 1990. Vitamin A deficiency and dioxin-induced cutaneous toxicity in murine skin [Abstract]. In: Tricontinental meeting: European Society for Dermatological Research (ESDR), Japanese Society for Investigative Dermatology (JSID) and Society for Investigative Dermatology (SID), Washington, DC, May 2-5, 1990. J Invest Dermatol 94:568.
*Puhvel SM, Sakamoto M. 1988. Effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin on murine skin. J Invest Dermatol 90:354–358.2894397
*Puhvel SM, Sakamoto M, Ertl DC, . 1982. Hairless mice as models for chloracne: A study of cutaneous changes induced by topical application of established chloracnegens. Toxicol Appl Pharmacol 64:492–503.6215744
Puntoni R, Merlo F, Fini A, . 1986. Soft tissue sarcoma in Seveso. Lancet 2:525.2875277
Puri RK, Clevenger TE, Kapila S, . 1989. Studies of parameters affecting translocation of tetrachlorodibenzo-p-dioxin in soil. Chemosphere 18:1291–1296.
Puri RK, Kapila S, Lo YH, . 1990. Effect of co-contaminants on the distribution of polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans in saturated soils. Chemosphere 20:1589–1596.
*Quattrochi LC, Vu T, Tukey RH. 1994. The human CYP1A2 gene and induction by 3-methylcholanthrene. J Biol Chem 269: 6949–6954.8120057
*Ramsey JC, Hefner JG, Karbowski RJ, . 1982. The in vivo biotransformation of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in the rat. Toxicol Appl Pharmacol 65:180–184.7147251
*Randerath K, Putman KL, Randerath E, . 1988. Organ-specific effects of long-term feeding 2,3,7,8-tetrachlorodibenzo-p-dioxin and 1,2,3,7,8-pentachlorodibenzo-p-dioxin on I-compounds in hepatic and renal DNA of female Sprague-Dawley rats. Carcinogenesis 9:2285–2289.3191574
*Randerath K, Putman KL, Randerath E, . 1989. Liver DNA alterations by 2,3,7,8-tetrachlorodibenzo-p-dioxin and 1,2,3,7,8-pentachlorodibenzo-p-dioxin in the female rat. Chemosphere 18:681–685.
*Randerath K, Putman KL, Randerath E, . 1990. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin on 1-compounds in hepatic DNA of Sprague-Dawley rats: Sex specific effects and structure-activity relationships. Toxicol Appl Pharmacol 103:271–280.2158676
*Rannug U, Sjogren M, Rannug A, . 1991. Use of artificial intelligence in structure-affinity correlations of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) receptor ligands. Carcinogenesis 12:2007–2015.1657432
*Rao MS, Subbarao V, Prasad JD, . 1988. Carcinogenesis of 2,3,7,8-tetrachlorodibenzo-p-dioxin in the Syrian golden hamster. Carcinogenesis 9:1677–1679.3409472
Rappe C. 1984. Analysis of polychlorinated dioxins and furans: All 75 PCDDs and 135 PCDFs can be identified by isomer-specific techniques. Environ Sci Technol 18:78a–90a.
*Rappe C. 1992. Dietary exposure and human levels of PCDDs and PCDFs. Chemosphere 25:231–34.
*Rappe C. 1993. Sources of exposure, environmental concentrations and exposure assessment of PCDDs and PCDFs. Chemosphere 27(ISS 1–3):211–25.
Rappe C, Bergovist PA, Hansson M, . 1984. Chemistry and analysis of polychlorinated dioxins and dibenzofurans in biological samples. Banbury Rep 18:17–25.
*Rappe C, Bergqvist P-A, Kjeller L-O, . 1991. Levels and patterns of PCDD and PCDF contamination in fish, crab, and lobsters from Newark Bay and the New York Bight. Chemosphere 22(3–4):239–266.
Rappe C, Kjeller L. 1987. PCDDs and PCDFs in environmental samples air, particulates, sediments and soil. Chemosphere 16:1775–1780.
Rappe C, Kjeller LO, Andersson R. 1989a. Analyses of PCDDs and PCDFs in sludge and water samples. Chemosphere 19:13–20.
*Rappe C, Kjeller LO, Bruckmann P, . 1988. Identification and quantification of PCDDs and PCDFs in urban air. Chemosphere 17:3–20.
Rappe C, Kjeller LO, Marklund S, . 1986a. Electrical PCB accidents: An update. Chemosphere 15:1291–1295.
Rappe C, Lundstroem G, Glas B, . 1990. Levels of PCDDs and PCDFs in milk cartons in commercial milk. Chemosphere 20:1649–1656.
Rappe C, Marklund S, Kjeller LO, . 1986b. PCDDs and PCDFs in emissions from various incinerators. Chemosphere 15:1213–1218.
Rappe C, Marklund S, Kjeller LO, . 1989b. Long-range transport of PCDDs and PCDFs on airborne particles. Chemosphere 18:1283–1290.
Rappe C, Nygren M. 1984. Chemical analysis of human samples identification and quantification of polychlorinated dioxins and dibenzofurans. Environ Sci Res 30:305–314.
Rappe C, Nygren M, Buser H, . 1983. Identification of polychlorinated dioxins (PCDDs) and dibenzofurans (PCDFs) in human samples, occupational exposure and Yusho patients. Environ Sci Res 26:241–253.
Rappe C, Nygren M, Buser HR, . 1982. Occupational exposure to polychlorinated dioxins and dibenzofurans. Pergamon Ser Environ Sci 5:495–513.
Rappe C, Nygren M, Lindstrom G, . 1986c. Dioxins and dibenzofurans in biological samples of European origin. Chemosphere 15:1635–1640.
Rappe C, Nygren M, Lindstrom G, . 1987. Polychlorinated dibenzofurans and dibenzo-p-dioxins and other chlorinated contaminants in cows milk from various locations in Switzerland. Environ Sci Technol 21:964–970.19994994
Rappe C, Nygren M, Marklund S, . 1985. Assessment of human exposure to polychlorinated dibenzofurans and dioxins. Environ Health Perspect 60:303–304.4029099
Rappe C, Swanson SE, Glas B. 1989c. Formation of PCDDs and PCDFs by the chlorination of water. Chemosphere 19:1875–1880.
Rappe C, Tarkowski S, Yrjaenh E. 1989d. The WHO/EURO quality control study on PCDDs and PCDFs in human milk. Chemosphere 18:883–889.
Ravo VR, Unger A. 1995. A novel application of a competitive binding model in dioxin risk assessment. Reg Toxicol Pharmacol 21:108–116.
Rawls RL. 1983. Dioxin’s human toxicity is most difficult problem: Dioxin is extremely toxic to certain animals, but scientists are only beginning to understand the nature of its toxicity and what it does to humans. Chemical and Engineering News 61:37–48.
*Reed LW, Hunt GT, Maisel BE, . 1990. Baseline assessment of PCDDs/PCDFs in the vicinity of the Elk River, Minnesota generating station. Chemosphere 21:159–171.
*Reggiani G. 1980. Acute human exposure to TCDD in Seveso, Italy. J Toxicol Environ Health 6:27–43.7381973
Reiner EJ, Schellenberg DH, Taguchi VY. 1991. Environmental applications for the analysis of chlorinated dibenzo-p-dioxins and dibenzofurans using mass-spectrometry. Environ Sci Technol 25:110–117
Reiner EJ, Schellenberg DH, Taguchi VY, . 1990. Application of tandem quadrupole mass spectrometry for the ultra-trace determination of polychlorinated dibenzo-p-dioxins and dibenzofurans. Chemosphere 20:1385–1392.
Reischl A, Reissinger M, Thoma H, . 1989. Uptake and accumulation of PCDD/F in terrestrial plants: Basic considerations. Chemosphere 19:467–474.
*Reyes H, Peisz-Porszasz S, Hankinson O. 1992. Identification of the Ah receptor nuclear translocator (Arnt) as a component of the DNA binding form of the Ah receptor. Science 256:1193–1195.1317062
Rghei HO, Eiceman GA. 1984. Adsorption and chlorination of dibenzo-p-dioxin and 1-chlorodibenzo-p-dioxin on fly ash from municipal incinerators. Chemosphere 13:421–426.
Rghei HO, Eiceman GA. 1985. Effect of matrix on heterogeneous phase chlorine substitution reactions for dibenzo-p-dioxin and hydrochloric-acid in air. Chemosphere 14:167–172.
*Rier SE, Martin DC, Bowman RE, . 1993. Endometriosis in Rhesus monkeys (Macaca mulatta) following chronic exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Fund Appl Toxicol 21:433–441.
Riihimaki V, Sisko A, Hernberg S. 1982. Mortality of 2,4-dichlorophenoxyacetic acid and 2,4,5-trichlorophenoxyacetic acid herbicide applicators in Finland. Scand J Work Environ Health 8:37–42.7134921
*Rippen G, Wesp H. 1993. Kale uptake of of PCDD/PCDF, PCB and PAH under field conditions: Importance of gaseous dry deposition. Presented at Dioxin 93. 13th International Symposium on Chlorinated Dioxins and Related Compounds, Vienna, Austria, September 1993.
*Riss A, Hagenmaier H, Weberruss U, . 1990. Comparison of PCDD/PCDF levels in soil, grass, cow’s milk, human blood and spruce needles in an areas of PCDD/PCDF contamination through emissions from a metal reclamation plant. Chemosphere 21(12):1451–1456.
*Roberts EA, Johnson KC, Harper PA, . 1990. Characterization of the Ah receptor mediating aryl hydrocarbon hydroxylase induction in the human liver cell line HepG2. Arch Biochem Biophys 276:442–450.2154949
Roberts EA, Shear NH, Okey AB, . 1985. The Ah receptor and dioxin toxicity: From rodent to human tissues. Chemosphere 14:661–674.
*Roffman A, Roffman HK. 1991. Air emissions from municipal waste combustion and their environmental effects. Sci Total Environ 104(1–2):87–96.1871592
*Rogers AM, Anderson ME, Back KC. 1982. Mutagenicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin and perfluoro-n-decanioc acid in L5178y mouse lymphoma cells. Mutat Res 105:445–449.7155164
Rogers CJ, Kornel A, Peterson RL. 1987. Mobile KPEG destruction unit for PCBs, dioxins and furans in contaminated waste. Presented at the 13th Annual Research Symposium: Land disposal, remedial action: Incineration and treatment of hazardous wastes, Cincinnati, Ohio. May 6-8, 1987, 361–365.
*Rohde S, Moser GA, PΣpke O, . 1997. Fecal clearance of PCDD/Fs in occupationally exposed persons. Organohalogen Compounds 33:408–413.
*Roman BL, Peterson RE. 1998. In utero and lactational exposure of the male rat to 2,3,7,8-tetrachlorodibenzo-p-dioxin impairs prostate development. 1. Effects on gene expression. Tox Appl Pharmacol 150:240–253.
*Roman BL, Pollenz RS, Peterson RE. 1998a. Responsiveness of the adult male rat reproductive tract to 2,3,7,8-tetrachlorodibenzo-p-dioxin exposure. Ah receptor and ARNT expression, CYP1A1 induction, and Ah receptor down-regulation. Tox Appl Pharmacol 150:228–239.
*Roman BL, Sommer RJ, Shinomiya K, . 1995. In utero and lactational exposure of the male rat to 2,3,7,8-tetrachlorodibenzo-p-dioxin: Impaired prostate growth and development without inhibited androgen production. Toxicol Appl Pharmacol 134:241–250.7570601
*Roman BL, Timms BG, Prins GS, . 1998b. In utero and lactational exposure of the male rat to 2,3,7,8-tetrachlorodibenzo-p-dioxin impairs prostate development. 2. Effects on growth and cytodifferentiation. Tox Appl Pharmacol 150:254–270.
*Romkes M, Piskorska-Pliszczynska J, Keys B, . 1987. Quantitative structure-activity relationships: analysis of interactions of 2,3,7,8-tetrachlorodibenzo-p-dioxin and 2-substituted analogues with rats, mouse, guinea pig, and hamster cytosolic receptor. Cancer Res 47:5108–5111.3040239
*Romkes M, Safe S. 1988. Comparative activities of 2,3,7,8-tetrachlorodibenzo-p-dioxin and progesterone as antiestrogens in the female rat uterus. Toxicol Appl Pharmacol 92:368–380.2832970
*Rordorf BF. 1986. Thermal properties of dioxins, furans and related compounds. Chemosphere 15:1325–1332.
Rordorf BF. 1987. Prediction of vapor pressures, boiling points and enthalpies of fusion for twenty-nine halogenated dibenzo-p-dioxins. Thermochim Acta 112:117–122.
*Rordorf BF. 1989. Prediction of vapor pressures, boiling points and enthalpies of fusion for twenty-nine halogenated dibenzo-p-dioxins and fifty-five dibenzofurans by vapor pressure correlation method. Chemosphere 18:783–788.
*Rose JQ, Ramsey JC, Wentzler TH, . 1976. The fate of 2,3,7,8-tetrachlorodibenzo-p-dioxin following single and repeated oral doses to the rat. Toxicol Appl Pharmacol 36:209–226.1273842
Rosengren R, Safe S, Bunce NJ. 1991. Structure-dependent interactions of ligands with the rat cytosolic Ah receptor: Kinetic analysis [Abstract 10]. Toxicologist 11:27.
Rosengren R, Safe S, Bunce NJ. 1992. Kinetics of the association of several tritiated polychlorinated dibenzo-p-dioxin and dibenzofuran congeners with hepatic cytosolic Ah receptor from the Wistar rat. Chem Res Toxicol 5(3):376–82.1324021
*Rosenthal GJ, Lebetkin E, Thigpen JE, . 1989. Characteristics of 2,3,7,8-tetrachlorodibenzo-p-dioxin induced endotoxin hypersensitivity: Association with hepatotoxicity. Toxicology 56:239–251.2472021
Rotard W, Christmann W, Lattner A, . 1987. Occurrence of PCDD and PCDF in motor oils, refined oils and contaminated soils. Chemosphere 16:1847–1849.
*Roth W, Voorman R, Aust SD. 1988. Activity of thyroid hormone-inducible enzymes following treatment with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 92:65–74.3341028
*Rozman K. 1984. Separation of wasting syndrome and lethality caused by 2,3,7,8-tetrachloro-dibenzo-p-dioxin. Toxicol Lett 22:279–285.6485001
Rozman K, Greim H. 1986. Toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin in cold-adapted rats. Arch Toxicol 59:211–215.3827590
*Rozman K, Pfeifer B, Kerecsen L, . 1991. Is a serotonergic mechanism involved in 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD)-induced appetite suppression in the Sprague-Dawley rat? Arch Toxicol 65:124–128.2059152
Rozman K, Roth WL, Greim H, . 1993. Relative potency of chlorinated dibenzo-p-dioxins (CDDs) in acute, subchronic and chronic (carcinogenicity) toxicity studies: Implications for risk assessment of chemical mixtures. Toxicology 77(1–2):39–50.8442017
*Rozman K, Rozman T, Scheufler E, . 1985. Thyroid hormones modulate the toxicity of 2,3,7,8-TCDD. J Toxicol Environ Health 16:481–491.4087313
RTECS. 1996. Registry of Toxic Effects of Chemical Substances. National Library of Medicine, Bethesda, MD. August 21. 1996.
Ryan JJ. 1986. Variation of dioxins and furans in human tissues. Chemosphere 15:1585–1593.
Ryan JJ. 1987. Personal telephone communication between DK Basu and JJ Ryan Food Research Division, Health Protection Branch, Ottawa, Canada. Syracuse Research Corporation, N.Y., September 2, 1987.
*Ryan JJ, Beaudoin N, Mills P, . 1997. Dioxin-like compounds in total diet food, Canada 1992-93. Organohalogen Compounds 32:121–124.
*Ryan JJ, Conacher HBS, Panopio LG, . 1991. Gas chromatographic separations of all 136 tetra- to octa- polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans on nine different stationary phases. Journal of Chromatography 541:131–183.
*Ryan JJ, Gasiewicz TA, Brown Jr JR. 1990. Human body burden of polychlorinated dibenzofurans associated with toxicity based on the Yusho and Yucheng incidents. Fund Appl Toxicol 15:722–731.
Ryan JJ, Lau BPY, Pilon JC, . 1984a. Incidence and levels of 2,3,7,8-tetrachlorodibenzo-p-dioxin in Lake Ontario and commercial fish. Environ Sci Technol 18:719–721.
*Ryan JJ, Levesque D, Panopio LG, . 1993a. Elimination of polychlorinated dibenzofurans (PCDFs) and polychlorinated biphenyls (PCBs) from human blood in the Yusho and Yu-Cheng rice oil poisonings. Arch Environ Contam Toxicol 24:504–512.8507107
*Ryan JJ, Lizotte R, Lau BPY. 1985a. Chlorinated dibenzo-p-dioxins and chlorinated dibenzofurans in Canadian human adipose tissue. Chemosphere 14:697–706.
*Ryan JJ, Lizotte R, Lewis D. 1987a. Human tissue levels of PCDDs and PCDFs from a fatal pentachlorophenol poisoning. Chemosphere 16:1989–1996.
Ryan JJ, Lizotte R, Newsome WH. 1984b. Study of chlorinated diphenyl ethers and chlorinated 2-phenoxyphenols as interferences in the determination of chlorinated dibenzo-p-dioxins and chlorinated dibenzofurans in biological samples. J Chromatogr 303:351–360.6440897
*Ryan JJ, Lizotte R, Panopio LG, . 1993b. Polychlorinated dibenzo-p-dioxins (PCDDs) and polychlorinated dibenzofurans (PCDFs) in human milk samples collected across Canada in 1986-87. Food Addit Contam 10(4):419–428.8405581
Ryan JJ, Lizotte R, Sakuma T, . 1985b. Chlorinated dibenzo-para-dioxins, chlorinated dibenzofurans and pentachlorophenol in Canadian chicken and pork samples. J Agric Food Chem 33:1021–1026.
Ryan JJ, Pilon JC. 1980. High-performance liquid chromatography in the analysis of chlorinated dibenzodioxins and dibenzofurans in chicken liver and wood shaving samples. J Chromatogr 197:171–180.
Ryan JJ, Pilon JC. 1982. Chlorinated-dibenzodioxins and dibenzofurans in chicken litter and livers arising from pentachlorophenol contamination of wood shavings. In: Hutzinger O., ed. Chlorinated dioxins and related compounds: Impact on the environment. New York, NY: Pergamon Press, 183–189.
Ryan JJ, Schecter A, Lizotte R, . 1985c. Tissue distributions of dioxins and furans in humans from the general population. Chemosphere 14:929–932.
Ryan JJ, Schecter A, Masuda Y, . 1987b. Comparison of PCDDs and PCDFs in the tissues of Yusho patients with those from the general population in Japan and China. Chemosphere 16:2017–2026.
*Ryan JJ, Schecter A, Sun WF, . 1986. Distribution of chlorinated dibenzo-p-dioxins and chlorinated dibenzofurans in human tissues from the general population. In: Rappe C, Choudhary G, Keith LH, eds. Chlorinated dioxins and dibenzofurans in perspective. Chelsea, MI: Lewis Publishers, Inc., 3–16.
*Ryan JJ, Shewchuk C, Lau P-Y, . 1992. Polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans in Canadian bleached paperboard milk containers (1988-1989) and their transfer to fluid milk. J Agric Fd Chem 40:919–923.
Ryan JJ, Williams DT. 1983. Analysis of human fat tissue from the Great Lakes area for 2,3,7,8-tetrachlorodibenzo-p-dioxin and furan residues. Environ Chem 23:157–158.
Sacchi GA, Vigano P, Fortunati G, . 1986. Accumulation of 2,3,7,8-tetrachlorodibenzo-p-dioxin from soil and nutrient solution by bean and maize plants. Experientia 42(5):586–588.
*Safe S. 1986. Comparative toxicology and mechanism of action of polychlorinated dibenzo-p-dioxins and dibenzofurans. Annu Rev Pharmacol Toxicol 26:371–399.3013079
*Safe S. 1987. Determination of 2,3,7,8-TCDD toxic equivalent factors (TEFs): Support for the use of the in vitro induction assay. Chemosphere 16:791–802.
*Safe S. 1990. Polychlorinated biphenyls (PCBs), dibenzo-p-dioxins (PCDDs), dibenzofurans (PCDFs), and related compounds: Enviornmental and mechanistic considerations which support the development of toxic equivalency factors. Toxicology 21:51–88.
*Safe S. 1992. Development, validation and limitations of toxic equivalency factors. Chemosphere 25:61–64.
*Safe S. 1998a. Limitations of the toxic equivalency factor approach for risk assessment of TCDD and related compounds. Teratogenesis Carcinog Mutagen 17:285–304.
*Safe S, Astroff B, Harris M, . 1991. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD) and related compounds as antiestrogens: Characterization and mechanism of action. Pharmacol Toxicol 69:400–409.1766914
Safe S, Brown KW, Donnelly KC, . 1992. Polychlorinated dibenzo-p-dioxins and dibenzofurans associated with wood-preserving chemical sites: Biomontoring with pine needles. Environ Sci Technol 26:394–396.
Safe S, Mason G, Keys B, . 1986. Polychlorinated dibenzo-p-dioxins and dibenzofurans: Correlation between in vitro and in vivo structure-activity relationships (SARs). Chemosphere 15:1725–1731.
*Safe SH. 1995. Modulation of gene expression and endocrine response pathways by 2,3,7,8-tetrachlorodibenzo-p-dioxin and related compounds. Pharmacol Ther 67:247–281.7494865
*Safe SH. 1998b. Development validation and problems with the toxic equivalency factor approach for risk assessment of dioxins and related compounds. J Anim Sci 76:134–141.9464894
*Sanderson JT, Elliott JE, Norstrom RJ, . 1994. Monitoring biological effects of polychlorinated dibenzo-p-dioxins, dibenzofurans, and bipehnyls in Great Blue Heron chicks in British Columbia. J Toxicol Environ Health 41(4):434–450.
*Santostefano MJ, Johnson KL, Whisnant NA, . 1996. Subcellular localization of TCDD differs between the liver, lungs, and kidneys after acute and subchronic exposure: Species/dose comparisons and possible mechanism. Fundam Appl Toxicol 34:265–275.8954756
*Santostefano MJ, Wang X, Richardson VM, . 1998. A pharmacodynamic analysis of TCDD-induced cytochrome P450 gene expression in multiple tissues: dose- and time-dependent effects. Tox Appl Pharmacol 151:294–310.
*Saracci R, Kogevinas M, Bertazzi PA, . 1991. Cancer mortality in workers exposed to chlorphenoxy herbicides and chlorophenols. Lancet 338:1027–1032.1681353
Sarna LP, Hodge PE, Webster GRB. 1984. Octanol-water partition coefficients of chlorinated dioxins and dibenzofurans by reversed-phase HPLC using several C18 columns. Chemosphere 13:975–983.
*Sawahata T, Olson JR, Neal RA. 1982. Identification of metabolites of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) formed on incubation with isolated rat hepatocytes. Biochem Biphys Res Commun 105:341–346.
*Sax NI, Lewis RJ, eds. 1987. Hawley’s Condensed Chemical Dictionary. New York, NY: Van Nostrand Reinhold, 11:886.
Schafer W, Ballschmiter K. 1986. Monobromo-polychloro-derivatives of benzene, biphenyl, dibenzofuran, and dibenzodioxin formed in chemical-waste burning. Chemosphere 15:755–763.
*Schantz S, Bowman RE. 1989. Learning in monkeys exposed perinatally to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Neurotoxicol Teratol 11:13–19.2725437
Schantz SL, Barsotti DA, Allen JR. 1979. Toxicological effects produced in nonhuman primates chronically exposed to fifty parts-per-trillion 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Toxicol Appl Pharmacol 48:A180.
*Schantz SL, Ferguson SA, Bowman RE. 1992. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin on behavior of monkey in peer groups. Neurotoxicol Teratol 14:433–446.1488038
*Schantz SL, Laughlin NK, Van Valkenberg HC, . 1986. Maternal care by rhesus monkeys of infant monkey exposed to either lead or 2,3,7,8-tetrachlorodibenzo-p-dioxin. Neurotoxicol 2:637–650.
*Schantz SL, Mably TA, Peterson RE. 1991. Effects of perinatal exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (2,3,7,8-TCDD) on spatial learning and memory and locomotor activity in rats. Teratol 43:497.
*Schaum J, Cleverly D, Lorber M, . 1994. Updated analysis of U.S. sources of dioxin-like compounds and background exposure levels. Organohalogen Compounds 20:178–184.
Schecter A. 1983. Contamination of an office building in Binghamton, New York, by PCBs, dioxins, furans, and biphenylenes after an electrical panel and electrical transformer incident. Chemosphere 12:669–680.
*Schecter A. 1985. Medical surveillance of exposed persons after exposure to PCBs, chlorinated dibenzodioxins and dibenzofurans after PCB transformer or capacitor incidents. Environ Health Perspect 60:333–338.3928362
*Schecter A. 1994. Elevated dioxin blood levels in British chemical workers. J Occup Med 36(12):1283–1287.
*Schecter A, Constable JD, Arghestani S, . 1987a. Elevated levels of 2,3,7,8-tetrachlorodibenzo-p-dioxin in adipose tissue of certain U.S. veterans of the Vietnam war. Chemosphere 16:1997–2001.
*Schecter A, Constable JD, Bangert JV, . 1989a. Elevated body burdens of 2,3,7,8-tetrachlorodibenzo-dioxin in adipose tissue of United States Vietnam veterans. Chemosphere 18:431–438.
Schecter A, Constable JD, Bangert JV, . 1989b. Isomer specific measurement of polychlorinated dibenzodioxin and dibenzofuran isomers in human blood from American Vietnam veterans two decades after exposure to Agent Orange. Chemosphere 18:531–538.
*Schecter A, Cramer P, Boggess K, . 1996c. Dioxin intake from U.S. Food: Results from a new nationwide food survey. In: Organohalogen Compounds volume 28.
*Schecter A, Dai LC, Thuy LTB, . 1995. Agent Orange and the Vietnamese: The persistence of elevated dioxin levels in human tissues. Am J Public Health 85:516–522.7702115
Schecter A, Dekin A, Weerasinghe NCA, . 1988. Sources of dioxins in the environment: A study of PCDDs and PCDFs in ancient, frozen Eskimo tissue. Chemosphere 17:627–631.
*Schecter A, Fürst P, Fürst C, . 1989c. Levels of polychlorinated dibenzodioxins and dibenzofurans in cow’s milk and in soybean derived infant formulas sold in the United Sates and other countries. Chemosphere 19:913–918.
*Schecter A, Fürst P, Fürst C, . 1991a. Dioxins, dibenzofurans and selected chlorinated organic compounds in human milk and blood from Cambodia, Germany, Thailand, the USA, the USSR, and Vietnam. Chemosphere 23:1903–1912.
*Schecter A, Fürst P, Fürst C, . 1994a. Chlorinated dioxins and dibenzofurans in human tissue from general populations: A selective review. Environ Health Perspectives Supplements 102(1):159–171.
*Schecter A, Fürst P, Krüger C, . 1989d. Levels of polychlorinated dibenzofurans, dibenzodioxins, PCBs, DDT, and DDE, hexachlorobenzene, dieldrin, hexachlorocyclohexanes, and oxychlordane in human breast milk from the United States, Thailand, Vietnam, and Germany. Chemosphere 18:445–454.
*Schecter A, Fürst P, Ryan JJ, . 1989e. Polychlorinated dioxins and dibenzofurans levels from human milk from several locations in the United States, Germany, and Vietnam. Chemosphere 19:979–984.
*Schecter A, Gasiewicz TA. 1987a. Health hazard assessment of chlorinated dioxins and dibenzofurans contained in human milk. Chemosphere 16:2147–2154.
Schecter A, Gasiewicz TA. 1987b. Human breast milk levels of dioxins and dibenzofurans: Significance with respect to current risk assessments. ACS Symp Ser 338:162–173.
Schecter A, Kooke R, Olie K, . 1989f. Chlorinated dioxin and dibenzofuran levels in food samples collected between 1985-87 in north and south of Vietnam. Chemosphere 18:627–634.
*Schecter A, Li L. 1997. Dioxins, dibenzofurans, dioxin-like PCBs, and DDE in U.S. fast food, 1995. Chemosphere 34(5–7):1449–1457.9134678
Schecter A, Malkin R, PΣpke O, . 1991b. Dioxin levels in blood of municipal incinerator workers. Med Sci Res 19:331–332.
*Schecter A, McGee H, Stanley JS, . 1996b. Dioxins and dioxin like chemicals in blood and semen of American Vietnam veterans from the state of Michigan. Amer J Ind Med 30:647–654.8914711
*Schecter A, PΣpke O, Ball M. 1990a. Evidence for transplacental transfer of dioxins from mother to fetus: Chlorinated dioxinal dibenzofuran levels in the livers of stillborn infants. Chemosphere 21:1017–1022.
*Schecter A, Papke O, Dellarco M, . 1996d. A comparison of dioxins and dibenzofurans in cooked and uncooked food. Organohalogen compounds, volume 28.
*Schecter A, Papke O, Lis A, . 1996a. Decrease in milk and blood dioxin levels over two years in a mother nursing twins: Estimates of decreased maternal and increased infant dioxin body burden from nursing. Chemosphere 32:543–549.8907231
*Schecter A, Ryan J, Papke O. 1994b. Elevated dioxin blood levels in Russian chemical workers and their children following maternal exposure. Chemosphere 29 9–11):2361–2370.7850385
Schecter A, Ryan JJ. 1988. Polychlorinated dibenzo-p-dioxin and dibenzofuran levels in human adipose tissues from workers 32 years after occupational exposure to 2,3,7,8-TCDD. Chemosphere 17:915–920.
Schecter A, Ryan JJ. 1989. Blood and adipose tissue levels of PCDDs/PCDFs over three years in a patient after exposure to polychlorinated dioxins and dibenzofurans. Chemosphere 18:635–642.
*Schecter A, Ryan JJ. 1991. Brominated and chlorinated dioxin blood levels in a chemist 34 years after exposure to 2,3,7,8-tetrachlorodibenzodioxin and 2,3,7,8-tetrabromodibenzodioxin. Chemosphere 23:1921–1924.
*Schecter A, Ryan JJ, Constable JD. 1986a. Chlorinated dibenzo-p-dioxin and dibenzofuran levels in human adipose tissue and milk samples from the north and south of Vietnam. Chemosphere 15:1613–1620.
*Schecter A, Ryan JJ, Constable JD. 1987b. Polychlorinated dibenzo-p-dioxin and polychlorinated dibenzofuran levels in human breast milk from Vietnam compared with cow’s milk and human breast milk from the North American continent. Chemosphere 16:2003–2016.
Schecter A, Ryan JJ, Constable JD. 1989g. Chlorinated dioxins and dibenzofurans in human milk from Japan, India, and the United States of America. Chemosphere 18:975–980.
*Schecter A, Ryan JJ, Constable JD, . 1990b. Partioning of 2,3,7,8-chloroinated dibenzo-p-dioxins and dibenzofurans between adipose tissue and plasma lipid of 20 Massachusetts Vietnam veterans. Chemosphere 20:951–958.
*Schecter A, Ryan JJ, Gitlitz G. 1986b. Chlorinated dioxin and dibenzofurans levels in human adipose tissues from exposed and control populations. In: Rappe C, Choudhary G, Keith LH, eds. Chlorinated dioxins and dibenzofurans in perspective. Chelsea, Michigan: Lewis Publishers, Inc., 51–56.
*Schecter A, Ryan JJ, Lizotte R, . 1985a. Chlorinated dibenzodioxins and dibenzofurans in human adipose tissue from exposed and control New York State patients. Chemosphere 14:933–937.
*Schecter A, Ryan JJ, Masuda Y, . 1994c. Chlorinated and brominated dioxins and dibenzofurans in human tissue following exposure. Environ Health Perspect 102(S1):134–147.
*Schecter A, Ryan JJ, PΣpke O, . 1993. Elevated dioxin levels in the blood of male and female Russian workers with and without chloracne 25 years after phenoxyherbicide exposure: the UFA “Khimprom” incident. Chemosphere 27:253–258.
*Schecter A, Startin J, Wright C, . 1994. Dioxins in U.S. food and estimated daily intake. Chemosphere 29(9–11):2261–2265.7850373
*Schecter A, Startin J, Wright C, . 1994d. Congener-specific levels of dioxins and dibenzofurans in U.S. food and estimated daily dioxin toxic equivalent intake. Environ Health Perspectives 102(11):962–966
*Schecter A, Startin J, Wright C, . 1996e. Concentrations of polychlorinated dibenzo-p-dixions and dibenzofurans in human placental and fetal tissues from the U.S. and in placentas from Yu-Cheng exposed mothers. Chemosphere. 32:551–557.8907232
*Schecter A, Tiernan T. 1985. Occupational exposure to polychlorinated dioxins, polychlorinated furans, polychlorinated biphenyls, and biphenylenes after an electrical panel and transformer accident in an office building in Binghamton, NY. Environ Health Perspect 60:305–313.3928358
*Schecter A, Tiernan T, Schaffner F. 1985b. Patient fat biopsies for chemical analysis and liver biopsies for ultrastructural characterization after exposure to polychlorinated dioxins, furans and PCBs. Environ Health Perspect 60:241–254.3928350
Scheidl K, Kuna RP, Wurst F. 1985. Chlorinated dioxins and furans in emissions from municipal incineration. Chemosphere 14:913–917.
*Schlaud M, Seidler A, Salje A, . 1995. Organochlorine residues in human breast milk: analysis through a sentinel practice network. Journal of Epidemiology & Community Health 49(suppl. 1):17–21.7561664
Schmid P, Suter-Hofmann ME, Schlatter C. 1989. A simplified clean-up procedure for the rapid determination of PCDDs and PCDFs based on retention on activated carbon AX-21. Chemosphere 18:1741–1748.
*Schrenk D, Buchmann A, Dietz K, . 1994. Promotion of preneoplastic foci in rat liver with 2,3,7,8-tetrachlorodibenzo-p-dioxin, 1,2,3,4,6,7,8-heptachlorodibenzo-p-dioxin and a defined mixture of 49 polychlorinated dibenzo-p-dioxins. Carcinogenesis 15(3):509–515 8118936
*Schroll R, Bierling B, Cao G, . 1994. Uptake pathways of organic chemicals from soil by agricultural plants. Chemosphere 28(2):297–303.
*Schroll R, Scheunert I. 1993. Uptake pathways of octachlorodibenzo-p-dioxin from soil by carrots. Chemosphere 26(9):1631–1640.
*Schroy JM, Hileman FD, Cheng SC. 1985. Physical/chemical properties of 2,3,7,8-TCDD (2,3,7,8-tetrachlorodibenzo-p-dioxin). Chemosphere 14:877–880.
*Schulz-Schlage T, Golor G, Stahlmann R. 1992. Biological effect of high doses of TCDD in the marmoset monkey, Callithrix jacchus, Plateau of ethoxyresorufin O-deethylase activity in liver microsomes. Chemosphere 25(7–10):991–995.
*Schuman RF, Hunter KW. 1988. Ultra sensitive bioassay for dioxin. Electric Power Research Institute Report, 7-11 – 7-14.
*Schwetz BA, Norris JM, Sparschu GL, . 1973. Toxicology of chlorinated dibenzo-p-dioxins. Environ Health Perspect 5:87–99.4270944
SDGWQS. 1989. South Dakota Ground-Water Quality Standards, 2/89. South Dakota Chapter 74:03:15.
*Secor CL, Mills EL, Harshbarger, . 1993. Bioaccumulation of toxicants, element and nutrient composition, and soft tissue histology of Zebra mussels (dreissena polymorpha) from New York state waters. Chemosphere 26(8):1559–1575.
*Sedman RM, Esparza JR. 1991. Evaluation of the public health risks associated with semivolatile metal and dioxin emissions from hazardous waste incinerators. Environmental Health Perspectives 94:181–187.1954929
*Seefeld MS, Corbett SW, Keesey RE, . 1984a. Characterization of the wasting syndrome in rats treated with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 73:311–322.6710531
*Seefeld MS, Keesey RE, Peterson RE. 1984b. Body weight regulation in rats treated with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 76:526–536.6506077
*Seefeld MS, Peterson RE. 1984. Digestible energy and efficiency of feed utilization in rats treated with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 74:214–222.6740672
*Seiler JP. 1973. A survey on the mutagenicity of various pesticides. Experientia 29:622–623.4730312
*Seo B-W, Li M-H, Hansen LG . 1995. Effects of gestational and lactational exposure to coplanar polychlorinated biphenyl (PCB) congeners or 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on thyroid hormone concentrations in weanling rats. Toxicol Lett 78:253–262.7624895
*Servos M, Muir D, Whittle D, . 1989b. Bioavailability of octachlorodibenzo-p-dioxin in aquatic systems. Chemosphere 19(1–6):969–972.
*Servos MR, Muir D CG, Webster G RB. 1992. Environmental fate of polychlorinated dibenzo-p-dioxins in lake enclosures. Can J Fish Aquat Sci 49(4):722–734.
Servos MR, Muir DCG, Webster GRB. 1989a. The effect of dissolved organic matter on the bioavailability of polychlorinated dibenzo-p-dioxins. Aquat Toxicol 14:169–184.
Seta J. 1991. Written communication (March 26) to Susan Press, ICF Incorporated, regarding 1990 NOES data for 2,3,7,8-TCDD. Cincinnati, OH: Department of Health and Human Services.
*Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Creep RO, Astwood EB, eds., Geiger SR, executive ed. Handbook of physiology: Endocrinology V. (Chapter 6). American Physiological Society, Washington DC.
*Sewall CH, Flager N, Van den Heuvel JP, . 1995. Alterations in thyroid function in female Sprague-Dawley rats following chronic treatment with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 132:237–244.7540335
*Sewall CH, Lucier GW, Tritscher AM, . 1993. TCDD-mediated changes in hepatic epidermal growth factor receptor may be a critical event in the hepatocarcinogenic action of TCDD. Carcinogenisis 14(9):1885–1893.
*Shane BS, Metosh-Dickey CA, Ebel JG Jr., . 1993. Toxicological evaluation of milk from lactating dairy cows following consumption of newsprint. J Agric Food Chem 41(2):240–245.
Shara MA, Stohs SJ. 1987. Biochemical and toxicological effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) congeners in female rats. Arch Environ Contam Toxicol 16:599–606.3632042
*Shear N, Schmidt C, Huntley S, . 1996. Evaluation of the factors relating combined sewer overflows with sediment contamination of the Lower Passaic River. Mar Poll Bull 32(3):288–304.
Sheffield A. 1985. Sources and releases of PCDDs and PCDFs to the Canadian environment. Chemosphere 14:811.
*Shen ES, Guengerich FP, Olson JR. 1989. Biphasic response for hepatic microsomal enzyme induction by 2,3,7,8-tetrachlorodibenzo-p-dioxin in C57BL/6J and DBA/2J mice. Biochem Pharmacol 38:4075–4084.2512931
*Shen ES, Gutman SI, Olson JR. 1991. Comparison of 2,3,7,8-tetrachlorodibenzo-p-dioxin-mediated heptotoxicity in C57BL/6J and DBA/2J mice. J Toxicol Environ Health 32:367–381.2016751
*Shen ES, Whitlock JP Jr. 1992. The potential role of DNA methylation in the response to 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Biol Chem 264:17754–17758.
Shepard BM, Young AL. 1981. Dioxins as contaminants of herbicides: The U.S. perspective. In: Tucker RE, Young AL, Gray AP, eds. Human and environmental risks of chlorinated dioxins and related compounds. New York, NY: Plenum Press, 3–11.
*Sherman RK, Clement RE, Tashiro C. 1990. The distribution of polychlorinated dibenzo-p-dioxins and dibenzofurans in Jackfish Bay, Lake Superior, in relation to a Kraft pulp mill effluent. Chemosphere 20(10–12):1641–1648.
*Sherman WR, Keenan RE, Gunster DG, . 1992. Reevaluation of dioxin bioconcentration and bioaccumulation factors for regulatory purposes. J Toxicol Environ Health 37:211–229.1404482
Sherry JP, Apsimon JW, Collier TL, . 1990. Use of DMSO as solubilization agent in the detection of 2,3,7,8-TCDD by radioimmunoassay. Chemosphere 20:1409–1416.
Sherry JP, Tse H. 1990. A procedure for the determination of polychlorinated dibenzo-p-dioxins in fish. Chemosphere 20:865–872.
*Shiu WY, Doucette W, Gobas FAPC, . 1988. Physical-chemical properties of chlorinated dibenzo-p-dioxins. Environ Sci Technol 22:651–658.
Shiverick KT, Muther TF. 1983. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD) effects on hepatic microsomal steroid metabolism and serum estradiol of pregnant rats. Biochem Pharmacol 32:991–995.6301511
Shu H, Teitelbaum P, Webb AS, . 1988. Bioavailability of soil-bound TCDD: Dermal bioavailability in the rat. Fundam Appl Toxicol 10:335–343.3356321
Shu HP, Paustenbach DJ, Murray FJ. 1987. A critical evaluation of the use of mutagenesis, carcinogenesis, and tumor promotion data in a cancer risk assessment of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Regul Toxicol Pharmacol 7:57–88.3575798
Sijm DTHM, Weaver H, Devries PJ, . 1989. Octanol/water partition coefficients of polychlorinated dibenzo-p-dioxins and dibenzofurans: Experimental values determined with a stirring method. Chemosphere 19:263–266.
*Silbergeld EK, Gasiewicsz TA. 1989. Dioxins and the Ah receptor. Am J Ind Med 16:455–474.2558567
*Silkworth J, McMartin D, DeCaprio A, . 1982. Acute toxicity in guinea pigs and rabbits of soot from a polychlorinated biphenyl-containing transformer fire. Tox Appl Pharmacol 65:425–439.
*Silkworth JB, Cutler DS, Antrim L, . 1989b. Teratology of 2,3,7,8-tetrachlorodibenzo-p-dioxin in a complex environmental mixture from the Love Canal. Fundam Appl Toxicol 13:1–15.2767349
*Silkworth JB, Cutler DS, Sack G. 1989a. Immunotoxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin in a complex environmental mixture from the Love Canal. Fundam Appl Toxicol 12:303–312.2714530
*Silverstone AE, Frazier, DE, Fiore NC, . 1994. Dexamethasone, -estradiol, and 2,3,7,8-tetrachlorodibenzo-p-dioxin elicit thymic atrophy through different cellular targets. Toxicol Appl Pharmacol 126: 248–259.7516097
*Simon N, Guzzetta J, Thielen D. 1989. GC/MS and GC/MS/MS: Complimentary techniques for the quantitation of tetrachlorodibenzo-p-dioxin in soils and sediments from industrial sites. Chemosphere 18:163–168.
*Sine C, ed. 1990. Farm chemicals handbook. Willoughby, OH: Meister Publishing Co., C87, C261.
*Singer R, Moses M, Valciukas J, . 1982. Nerve conduction velocity studies of workers employed in the manufacture of phenoxy herbicides. Environ Res 29:297–311.7160349
*Singh J, Miles W, Barrette JP. 1985. Determination of polychlorinated dibenzo-p-dioxins in technical pentachlorophenol. J Assoc Off Anal Chem 68:583–586.
Slaga TJ, Nesnow S. 1985. Sencar mouse skin tumorigenesis. In: Millmen HA, Weisburger EK, eds. Handbook of carcinogen testing. Park Ridge, N.J.: Noyes Publ, 230–250.
*Slob W, Van Jaarsveld JA. 1993. A chain model for dioxins: From emission to cow’s milk. Chemosphere 27(ISS 1–3):509–16.
*Sloop TC, Lucier GW. 1987. Dose-dependent elevation of Ah receptor binding by TCDD rat liver. Toxicol Appl Pharmacol 88:329–337.3033846
Smith AH. 1987. Infant exposure assessment for breast milk dioxins and furans derived from waste incineration emissions. Risk Anal 7:347–353.3685542
*Smith AH, Fisher DO, Dip NP, . 1982. Congenital defects and miscarriages among New Zealand 2,4,5-T sprayers. Arch Environ Health 37:197–200.7114899
*Smith AH, Francis JE, Kay SJ, . 1981. Hepatic toxicity and uroporphyringen decarboxylase activity following a single dose of 2,3,7,8-tetrachlorodibenzo-p-dioxin to mice. Biochem Pharmacol 30:2825–2830.7317077
*Smith AH, Pearce NE, Fisher DO, . 1984a. Soft tissue sarcoma and exposure to phenoxyherbicides and chlorophenols in New Zealand. J Natl Cancer Inst 73:1111–1117.6593487
*Smith FA, Schwetz BA, Nitschke KD. 1976. Teratogenicity of 2,3,7,8-tetrachloro-dibenzo-p-dioxin in CF-1 mice. Toxicol Appl Pharmacol 38:517–523.1014011
Smith LM, Schwartz TR, Feltz K, . 1990a. Determination and occurrence of AHH-active polychlorinated-biphenyls, 2,3,7,8-tetrachloro-para-dioxin and 2,3,7,8-tetrachlorodibenzofuran in Lake Michigan sediment and biota - the question of their relative toxicological significance. Chemosphere 21:1063–1085.
Smith LM, Stalling DL, Johnson JL. 1984b. Determination of part-per-trillion levels of polychlorinated dibenzofurans and dioxins in environmental samples. Anal Chem 56:1830–1842.6437278
*Smith RM, O’Keefe P, Aldous K, . 1992. Measurement of PCDFs and PCDDs in air samples and lake sediments at several locations in upstate New York. Chemosphere 25(1–2):95–8.
*Smith RM, O’Keefe PW, Aldous KM, . 1983. 2,3,7,8-Tetrachlorodibenzo-p-dioxin in sediment samples from Love Canal storm sewers and creeks. Environ Sci Technol 17:6–10.22304544
*Smith RM, O’Keefe PW, Aldous KM, . 1990b. Chlorinated dibenzofurans and dioxins in atmospheric samples from cities in New York. Environ Sci Technol 24:1502–1506.
*Smith RM, O’Keefe PW, Briggs R, . 1990c. Continuous ambient air monitoring for CDFs and CDDs: Niagara Falls New York. Organohalogen Compd 4:233–236.
*Smith RM, O’Keefe PW, Hilker DR, . 1986a. Determination of picogram per cubic meter concentrations of tetra- and pentachlorinated dibenzofurans and dibenzo-p-dioxins in indoor air by high-resolution gas chromatography/high-resolution mass spectrometry. Anal Chem 58:2414–2420.3789396
Smith RM, O’Keefe PW, Hilker DR, . 1986b. Sampling, analytical method and results for chlorinated dibenzo-p-dioxins and chlorinated dibenzofurans from incinerator stack effluent and contaminated building indoor air samples. In: Rappe C, Choudhary G, Keith LH, eds. Chlorinated dioxins and dibenzofurans in perspective. Chelsea, MI: Lewis Publishers, Inc., 93–108.
Smith RM, O’Keefe PW, Hilker DR, . 1989. Ambient air and incinerator testing for chlorinated dibenzofurans and dioxins by low resolution mass spectrometry. Chemosphere 18:585–592.
*Sommer RJ, Ippolito DL, Peterson RE. 1996. In utero and lactational exposure of the Male Holtzman rat to 2,3,7,8-tetrachlorodibenzo-p-dioxin: decreased epididymal and ejaculated sperm numbers without alterations in sperm transit rate. Toxicol Appl Pharmacol 140:146–153.8806880
Sovocool GW, Mitchum RK, Tondeur Y, . 1988. Bromo- and bromochloro-polynuclear aromatic hydrocarbons, dioxins and dibenzofurans in municipal incinerator fly ash. Biomed Environ Mass Spectrum 15:669–676.
Sparschu GL Jr, Dunn FL Jr, Lisowe RW, . 1971a. Effects of high levels of 2,4,5-trichlorophenoxyacetic acid on fetal development in the rat. Food Cosmet Toxicol 9:527–530.5157310
Sparschu GL Jr, Dunn FL Jr, Row VK Jr. 1971b. Study of the teratogenicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin in the rat. Food Cosmet Toxicol 9:405–412.5314812
*SRI. 1991. 1991 Directory of Chemical Producers: United States of America. Menlo Park, CA: Stanford Research Institute International, 823, 1033.
Srinivasan KR, Fogler HS. 1986. Binding of OCDD, 2,3,7,8-TCDD and HCB to clay-based sorbents. In: Rappe C, Choudhary G, Keith LH, eds. Chlorinated dioxins and dibenzofurans in perspective. Chelsea, MI: Lewis Publishers, Inc., 531–539.
*Stahl BU, Kettrup A, Rozman K. 1992. Comparative toxicity of four chlorinated dibenzo-p-dioxins (CDDs) and their mixture. Part I: Acute toxicity and toxic equivalency factors (TEFs). Arch Toxicol 66(7):471–7.1444813
*Stahl BU, Rozman K. 1990. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD)-induced appetite suppression in the Sprague-Dawley rat is not a direct effect on feed intake regulation in the brain. Toxicol Appl Pharmacol 106:158–162.2251679
*Stahlmann R, Schulz-Schalge T, Korte M, . 1992. Clinical chemistry and hematology in rats after short-term and after long-term exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Chemosphere 25(7–10):1207–1214.
Stalling DL, Norstrom RJ, Smith LM, . 1985. Patterns of PCDD, PCDF, and PCB contamination in Great Lakes, fish and birds and their characterization by principal components analysis. Chemosphere 14:627–643.
*Stalling DL, Peterman PH, Smith LM, . 1986. Use of pattern recognition in the evaluation of PCDD and PCDF residue data from GC/MS analysis. Chemosphere 15:1435–1443.
Stalling DL, Smith LM, Petty JD, . 1983. Residues of polychlorinated dibenzo-p-dioxins and dibenzofurans in Laurentar Great Lakes fish. In: Tucker E, Young AL, Gray AP, eds. Human and environmental risks of chlorinated dioxins and related compounds. New York, London: Plenum Publishing Corp, 221–240.
*Stanker LH, Watkins B, Rogers N, . 1987. Monoclonal antibodies for dioxin: Antibody characterization and assay development. Toxicology 45:229–243.3629609
*Stanley JS. 1986. Broad scan analysis of the FY82 National human adipose tissue survey specimens: Volume 1. Executive summary. Washington, D.C.: U.S. Environmental Protection Agency. EPA 560/5-86-035.
*Stanley JS, Boggess KE, Onstot J, . 1986. PCDDs and PCDFs in human adipose tissue from the EPA FY82 NHATS repository. Chemosphere 15:1605–1612.
*Staples CA, Werner A, Hoogheem T. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
Startin JR. 1994. Dioxins in food. In: Schecter A., ed, Dioxins and health. New York, Plenum Press, 115–137.
Startin JR, Rose M, Offen C. 1989. Analysis of PCDDs and PCDFs in human milk from the U.K. Chemosphere 19:985–988.
*Stehl RH, Papenfuss RR, Bredeweg RA, . 1973. Stability of pentachlorophenol and chlorinated dioxins to sunlight, heat, and combustion. Advan Chem Ser 120:119–125.
*Stehr PA, Stein G, Falk H, . 1986. A pilot epidemiologic study of possible health effects associated with 2,3,7,8-tetrachlorodibenzo-p-dioxin contaminations in Missouri. Arch Environ Health 41:16–22.3963882
*Stehr-Green PA, Naylor PH, Hoffman RE. 1989. Diminished thymosinalpha-1 levels in persons exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Toxicol Environ Health 28:285–295.2585536
Steinwandter H. 1994. A simple and fast micromethod for the determination of 1,2,3,4,6,7,8-Heptachlorodibenzo-p-dioxin and octachlorodibenzo-p-dioxin in sewage sludges by GC-ECD. Fresenius Journal of Analytical Chemistry 348(5–6):385–389.
Steppan LB, Kirkvliet NI. 1991. Influence of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on the production of inflammatory cytokine mRNA by C57Bl/6 macrophages [Abstract 45]. Toxicologist 11:35.
Stevens KM. 1981. Agent Orange toxicity: A quantitative perspective. Hum Toxicol 1:31–39.7348691
Stieglitz L, Zwick G, Roth W. 1986. Investigation of different treatment techniques for PCDD/PCDF in fly ash. Chemosphere 15:1135–1140.
Stockbauer JW, Hoffman RE, Schramm WF, . 1988. Reproductive outcomes of mothers with potential exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Am J Epidemiol 128:410–419.3394706
*Stohs SJ, Shara MA, Alsharif NZ, . 1990. 2,3,7,8-Tetrachlorodibenzo-p-dioxin-induced oxidative stress in female rats. Toxicol Appl Pharmacol 106:126–135.2251677
*Sugawara Y, Gee SJ, Sanborn JR, . 1998. Development of a highly sensitive enzyme-linked immunosorbent assay based on polyclonal antibodies for the detection of polychlorinated dibenzo-p-dioxins. Anal Chem 70(6):1092–9.9530001
*Sullivan MJ, Stanford JT. 1990. Risk associated with potential exposure to dioxin through consumption of tea brewed using tea bags containing bleached pulp. Chemosphere 20:1755–1762.
*Sunahara GI, Nelson KG, Wong TK, . 1987. Decreased human birth weights after in utero exposure to PCBs and PCDFs are associated with decreased placental EGF-stimulated receptor autophosphorylation capacity. Mol Pharmacol 32: 572–578.3119985
Suskind RR. 1985. Chloracne, “the hallmark of dioxin intoxication.” Scand J Work Environ Health 11:165–171.2930898
*Suskind RR, Hertzberg VS. 1984. Human health effects of 2,4,5-T and its toxic contaminants. J Am Med Assoc 251:2372–2380.
*Svensson B-G, Hallberg T, Nilsson A, . 1994. Parameters of immunological competence in subjects with high consumption of fish contaminated with persistent organochlorine compounds. Int Arch Occup Environ Health 65:351–358.8034358
Svensson B-G, Nilsson A, Hansson M, . 1991. Exposure to dioxins and dibenzofurans through the consumption of fish. N Engl J Med 324(1):8–12.1898530
*Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85:17–28.
*Swanson HI, Bradfield CA. 1993. The Ah receptor: Genetics, structure and function. Pharmacogenetics 3: 213–230.8287061
*Swanson HI, Chan WK, Bradfield CA. 1995. DNA binding specificities and pairing rules of the Ah receptor, ARNT, and SIM proteins. J Biol Chem 270: 26292–26302.7592839
*Swanson SE, Rappe C, Malmstr÷m J, . 1988. Emissions of PCDDs and PCDFs from the pulp industry. Chemosphere 17:681–691.
*Sweeney A. 1994. Reproductive epidemiology of dioxins. In: Schecter A, ed. Dioxins and health. New York: Plenum Press, 549–585.
Sweeney M, Fingerhut M, Arezzo J, . 1991. Neurologic changes in workers exposed to 2,3,7,8-TCDD. National Institute for Occupational Safety and Health, Cincinnati, OH, 56.
*Sweeney MH, Fingerhut MA Arezzo J, . 1993. Peripheral neurophathy after occupational exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Am J Ind Med 23:845–858.8392292
*Sweeney MH, Fingerhut MA, Connally LB, . 1989. Progress of the NIOSH cross-sectional medical study of workers occupationally exposed to chemicals contaminated with 2,3,7,8-TCDD. Chemosphere 19:973–977.
Sweeney MH, Fingerhut MA, Patterson DG, . 1990. Comparison of serum levels of 2,3,7,8-TCDD in TCP production workers and in an unexposed comparison group. Chemosphere 20:993–1000.
*Sweeney MP, Hornung RW, Wall DK, . 1992. Prevalence of diabetes and increased fasting serum glucose in workers with long-term exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. 12th International Symposium on Dioxins and Related Compounds, August 23–28 Tampere, Finland.
Swerev M, Ballschmiter K. 1989. Pattern analysis of PCDDs and PCDFs in environmental samples as an approach to an occurrence/source correlation. Chemosphere 18:609–616.
Takayama K, Miyata H, Mimura M, . 1988. Rapid analytical method for PCDDs, PCDFs, and polychlorobenzenes in samples from municipal waste incinerators. Eisei Kagaku 34:231–236.
*Takimoto K, Lindahl R, Dunn TJ, . 1994. Structure of the 5’ flanking region of class 3 aldehyde dehydrogenase in the rat. Arch Biochem Biophys 312: 539–546.8037469
*Takizawa Y, Muto H. 1987. PCDDs and PCDFs carried to the human body from the diet. Chemosphere 16:1971–1975.
Tanabe S, Kannan N, Subramanian A, . 1987. Highly toxic coplanar PCBs: Occurrence, source, persistency and toxic implications to wildlife and humans. Environ Pollut 47:147–163.15092716
Tanaka K, Hara S, Makino S. 1992. Development of new program for dioxin analysis using mass spectrometry. Kankyo Kagaku 2(2):428–9.
Tarkowski S, Yrjanheikki E. 1986. Polychlorinated dibenzo-p-dioxins and dibenzofurans in human milk Reasons for concern. Chemosphere 15:1641–1648.
Tarkowski S, Yrjanheikki E. 1989. Polychlorinated dibenzodioxins and dibenzofurans in human milk: An interim health risk evaluation. Chemosphere 18:1107–1113.
*Tarkowski S, Yrjanheikki E. 1989. Polychlorinated dibenzodioxins and dibenzofurans in human milk: an interim health risk evaluation. Chemosphere 18(1–6):1107–1113.
Tashiro C, Clement RE, Davies S, . 1990. Water round robin parts-per-quadrillion determination of PCDDs and PCDFs. Chemosphere 20:1313–1318.
*Tashiro C, Clement RE, Lusis M, . 1989a. Monitoring dioxins and furans in precipitation samples. Chemosphere 18:777–782.
*Tashiro C, Clement RE, Reid N, . 1989b. Determination of dioxins and furans in precipitation collected in urban and rural Ontario locations. Chemosphere 19:535–540.
Tashiro C, Clement RE, Szakolcai A, . 1989c. Comparison of high volume sampling techniques for dioxins and furans in ambient air. Chemosphere 19:1–6.
Taylor JS. 1979. Environmental chloracne: Update and overview. Ann NY Acad Sci 320:295–307.222187
*Taylor MJ, Lucier GW, Mahler JF, . 1992. Inhibition of acute TCDD toxicity by treatment with anti-tumor necrosis factor antibody or dexamethasone. Toxicol Appl Pharmacol 117(1):126–132.1440607
*Tenchini ML, Crimaudo C, Pacchetti G, . 1983. A comparative cytogenetic study on cases of induced abortions in TCDD-exposed and nonexposed women. Environ Mutagen 5:73–85.6832086
*Tepper A, Burr S, Piacitelli L, . 1997. Serum levels of polychlorinated dibenzo-p-dioxins and dibenzofurans in pulp and paper mill workers. Chemosphere 34(5–7):1587–1603.9134690
Theisen J, Funcke W, Balfanz E, . 1989. Determination of PCDFs and PCDDs in fire accidents and laboratory combustion tests involving PVC-containing materials. Chemosphere 19:423–428.
*Theobald HM, Ingall GB, Mably TA, . 1991. Response of the antral mucuso of the rat stomach to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 108:167–179.1672476
Thibodeaux LJ, Lipsly D. 1985. A fate and transport model for 2,3,7,8-tetrachlorodibenzo-p-dioxin in fly ash on soil and urban surfaces. Hazard Waste Hazard Mater 2:225–235.
Thiess AM, Frentzel-Beyme R. 1977. Mortality study of persons exposed to dioxin following an accident which occurred in the BASF on 13, November 1953. Working Papers, Joint NIEHS/IARC Working Group Report. Lyon, France, June.
*Thiess AM, Frentzel-Beyme R, Link R. 1982. Mortality study of persons exposed to dioxin in a trichlorophenol-process accident that occurred in the BASF/AG on November 17, 1953. Am J Ind Med 3:179–189.6215858
*Thigpen JE, Faith RE, McConnell EE, . 1975. Increased susceptibility of bacterial infection as a sequela of exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Infect Immun 12:1319–1324.173655
*Thoma H. 1988. PCDD/F-concentrations in chimney soot from house heating systems. Chemosphere 17:1369–1379.
*Thoma H, Mucke W, Kauert G. 1990. Comparison of the polychlorinated dibenzo-p-dioxin and dibenzofuran in human tissue and human liver. Chemosphere 20:433–442.
Thoma H, Muecke W, Kretschmer E. 1989. Concentrations of PCDD and PCDF in human fat and liver samples. Chemosphere 18:491–498.
Thomann RV. 1989. Bioaccumulation model of organic chemical distribution in aquatic food chains. Environ Sci Technol 23:699–707.
Thomas HF. 1980. Internal memo to P. Cohn, Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances.
*Thomas PT, Hinsdill RD. 1979. The effect of perinatal exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin on the immune response of young mice. Drug Chem Toxicol 2:77–98.548257
*Thomas VM, Spiro TG. 1995. An estimation of dioxinemissiions in the United States. Toxicology and Environmental Chemistry 50:1–37.
*Thomas VM, Spiro TG. 1996. The U.S. dioxin inventory: are there missing sources? Environmental Science & Technology 30 (2):82A–85A.
Thompson HC Jr, Kendall DC, Korfmacher WA, . 1986a. Assessment of the contamination of a multibuilding facility by polychlorinated biphenyls, polychlorinated dibenzo-p-dioxins, and polychlorinated dibenzofuran. Environ Sci Technol 20:597–607.19994957
Thompson HC Jr, Kendall DC, Korfmacher WA, . 1986b. Polychlorinated dibenzo-p-dioxins, polychlorinated dibenzofurans, and polychlorinated biphenyls at a contaminated multibuilding facility. In: Rappe C, Choudhary G, Keith LH, eds. Chlorinated dioxins and dibenzofurans in perspective. Chelsea, MI: Lewis Publishers, Inc., 121–136.
*Thompson TS, Clement RE, Thornton N, . 1990. Formation and emission of PCDDs/PCDFs in the petroleum refining industry. Chemosphere 20(10–12):1525–32.
*Thunberg T. 1984. Effects of TCDD on vitamin A and its relation to TCDD toxicity. Banbury Rep 38:333–344.
*Thunberg T, Ahlborg UG, Hakansson H, . 1980. Effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin on the hepatic storage of retinol in rats with different dietary supplies of vitamin A (retinol). Arch Toxicol 45:273–285.6778458
*Thunberg T, Ahlborg UG, Johnsson H. 1979. Vitamin A (retinol) status in the rat after a single oral dose of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Arch Toxicol 42:265–274.518291
*Thunberg T, Ahlborg UG, Wahlstr÷m B. 1984. Comparison between the effects of 2,3,7,8-tetrachloro-dibenzo-p-dioxin and six other compounds on the vitamin A storage, the UDP-glucuronosyltransferase and the aryl hydrocarbon hydroxylase activity in the rat liver. Arch Toxicol 55:16–19.6428382
*Thunberg T, Hakansson H. 1983. Vitamin A (retinol) status in the Gunn rat: The effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Arch Toxicol 53:225–233.6412665
Tiernan TO, Taylor ML, Garrett JH, . 1983. PCDDs, PCDFs and related compounds in the effluents from combustion processes. Chemosphere 12:595–606.
*Tiernan TO, Taylor ML, Garrett JH, . 1985. Sources and fate of polychlorinated dibenzodioxins, dibenzofurans and related compounds in human environments. Environ Health Perspect 59:145–158.3921357
Tiernan TO, Taylor ML, Vanness GF, . 1984. Analyses of human tissues for chlorinated dibenzo-p-dioxins and chlorinated dibenzofurans: The state of the art. In: Lowrance WW, ed. Public health risks of the dioxins. New York, NY: Rockerfeller University, 31–56.
Tiernan TO, Wagel DJ, Vanness GF, . 1989a. Dechlorination of PCDD and PCDF sorbed on activated carbon using the KPEG reagent. Chemosphere 19:573–578.
*Tiernan TO, Wagel DJ, Vanness GF, . 1989b. PCDD/PCDF in the ambient air of metropolitan area in the U.S. Chemosphere 19:541–546.
TMN. 1987. Survey finds little dioxin at control sites: Industry finds trace amounts in paper products and highest levels at pesticide plants. Toxic Materials News. September 30, 301.
Tognoni G, Bonaccorsi A. 1982. Epidemiological problems with TCDD: A critical view. Drug Metab Rev 13:447–469.7105971
*Tomaszewski KE, Montgomery CA, Melnick RL. 1988. Modulation of 2,3,7,8-tetrachlorodibenzo-p-dioxin toxicity in F344 rats by di(2-ethylhexyl)phthalate. Chem Biol Interact 65:205–222.3378278
*Tong H, Gross M, Schecter A, . 1990. Sources of dioxins in the environment : Second stage study of PCDDs/PCDFs in ancient human tissue and environmental samples. Chemosphere 20:987–992.
*Tong HY, Arghestani S, Gross ML, . 1989a. Polychlorodibenzodioxins and polychlorodibenzofurans in the dust of the ambient atmosphere in a municipal waste incinerator. Chemosphere 18:577–584.
Tong HY, Karasek FW. 1986. Comparison of quantitation of polychlorinated dibenzodioxins and polychlorinated dibenzofurans in complex environmental samples by high resolution gas chromatography with flame ionization, electron capture and mass spectrometric detection. Chemosphere 15:1141–1146.
*Tong HY, Monson SJ, Gross ML, . 1989b. Elevated levels of 2,3,7,8-TCDD in the tissue of an agricultural sprayer of herbicides: A single case study. Chemosphere 18:469–476.
Tong HY, Shore DL, Karasek FW. 1984b. Isolation of polychlorinated dibenzodioxins and polychlorinated dibenzofurans for a complex organic mixture by two-step liquid chromatographic fractionation for quantitative analysis. Anal Chem 56:2442–2447.6517332
Tong HY, Shore DL, Karasek FW, . 1984a. Identification of organic wastes obtained from incineration of municipal waste by high-performance liquid chromatographic fractionation and gas chromatography-mass spectrometry. J Chromatogr 285:413–441.
*Tonn T, Esser C, Schneider EM, . 1996. Persistence of decreased T-helper cell function in industrial workers 20 years after exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Environ Health Perspect 104:422–426.8732953
*Toth K, Olah E, Somfai-Relle S, . 1984. Effect of herbicide 2,4,5-trichlorophenoxyethanol (TCPE) containing dioxin on mutation and induction of sister chromatid exchanges. Carcinogenesis 5:1725–1728.6499124
*Toth K, Somfai-Relle S, Sugar J, . 1979. Carcinogenicity testing of herbicide 2,4,5-trichlorophen-oxyethanol containing dioxin and of pure dioxin in Swiss mice. Nature 278:548–549.431718
*Towara J, Hiller B, Hutzinger O, . 1992. PCDD/F in distillation residues from dry cleaners. Chemosphere 25:1509–1516.
Townsend DI. 1980. The use of dioxin isomer group ratios to identify sources and define background levels of dioxins in the environment. J Environ Sci Health 15:571–609.
*Townsend JC, Bodner KM, Van Peenen PFD, . 1982. Survey of reproductive events of wives of employees exposed to chlorinated dioxins. Am J Epidemiol 115:695–713.7081201
Travis CC, Arms AD. 1988. Bioconcentration of organics in beef, milk, and vegetation. Environ Sci Technol 22:271–274.22288859
*Travis CC, Hattemer-Frey HA. 1987. Human exposure to 2,3,7,8-TCDD. Chemosphere 16:2331–2342.
*Travis CC, Hattemer-Frey HA. 1989. Human exposure to dioxin from municipal solid waste incineration. Waste Management 9:151–156.
*Travis CC, Hattemer-Frey HA. 1991. Human exposure to dioxin. The Science of the Total Environment 104(1–2):97–127.1871593
*Tritscher AM, Goldstein JA, Portier CJ, . 1992. Dose-response relationships for chronic exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin in a rat tumor promotion model: Quantification and immunolocalization of CYP1A1 and CYP1A2 in the liver. Cancer Res 52:3436–3442.1596902
Tsushimoto G, Matsumura F, Sago R. 1982. Fate of 2,3,7,8-TCDD in an outdoor pond and in model aquatic ecosystems. Environ Toxicol Chem 1:61–68.
*Tucker AN, Vore SJ, Luster MI. 1986. Suppression on B cell differentiation by 2,3,7,8-tetrachloro-dibenzo-p-dioxin. Mol Pharmacol 29:372–377.3486342
Tuinstra LGMT, Van Rhijn JA, Roos AH, . 1990. Determination of planar chlorobiphenyls in animal fat. Journal of High Resolution Chromatography 13:797–802.
*Tulp MTM, Hutzinger O. 1978. Rat metabolism of polychlorinated dibenzo-p-dioxins. Chemosphere 7:761–768.
*Tuomisto J, Pohjanvirta R. 1991. Do we hypothese on the mechanism of action of dioxins help in risk assessment? Sci Tot Environ 106:21–31.
*Tuomisto J, Pohjanvirta R, MacDonald E, . 1990. Changes in rat brain monoamines, monoamine metabolites and histamine after a single administration of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Pharmacol Toxicol 67:260–265.2255684
Turkstra E, Pols HB. 1989. PCDDs and PCDFs in Dutch inland waters. Chemosphere 18:539–551.
*Turner JN, Collins DN. 1983. Liver morphology in guinea pigs administered either pyrolysis products of a polychlorinated biphenyl transformer fluid or 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Appl Pharmacol 67:417–429.6405510
*Turteltaub KW, Felton JS, Gledhill BL, . 1990. Accelerator mass spectrometry in biomedical dosimetry: Relationship between low-level exposure and covalent binding of heterocyclic amine carcinogens to DNA. Proc Natl Acad Sci USA 87:5288–5292.2371271
*Tysklind M, Faengmark I, Marklund S, . 1993. Atmospheric transport and transformation of polychlorinated dibenzo-p-dioxins and dibenzofurans. Environ Sci Technol 27(10):2190–7.
*U.S. Congress. 1986. Superfund amendments and reauthorization act of 1986. Title III. Emergency planning and community right-to-know act. Ninety-ninth Congress of the United States of America. Second Sesstion. January 21, 1986.
U.S. Congress 1991. Dioxin treatment technologies background paper. Office of Technology Assessment. OTA-BP-0-93. Washington, DC: U.S. Government Printing Office. November 1991.
*Uematsu F, Kikuchi H, Motomiya M, . 1991. Association between restriction frgament length polymorphism of the human cytochrome P450IIE1 gene and susceptibility to lung cancer. Jpn J Cancer Res 82:254–256.1673675
*Umbreit TH, Hesse EJ, Gallo MA. 1986a. Bioavailability of dioxin in soil from a 2,4,5-T manufacturing site. Science 232:497–499.3961492
*Umbreit TH, Hesse EJ, Gallo MA. 1986b. Comparative toxicity of TCDD contaminated soil from Times Beach, Missouri, and Newark, New Jersey. Chemosphere 15:2121–2124.
*Umbreit TH, Hesse EJ, Gallo MA. 1987. Reproductive toxicity in female mice of dioxin-contaminated soils from a 2,4,5-trichlorophenoxyacetic acid manufacturing site. Arch Environ Contam Toxicol 16:461–466.3606204
*Umbreit TH, Hesse EJ, Gallo MA. 1988. Reproductive studies of C57B/6 male mice treated with TCDD-contaminated soils from a 2,4,5-trichlorophenoxyacetic acid manufacturing site. Arch Environ Contam Toxicol 17:145–150.3355229
*Umbreit TH, Patel D, Gallo MA. 1985. Acute toxicity of TCDD contaminated soil from an industrial site. Chemosphere 14:945–947.
*Unkila M, Pohjanvirta R, MacDonald E, . 1993a. Differential effect of TCDD on brain serotonin metabolism in a TCDD-susceptible and a TCDD-resistant rat strain. Chemosphere 27(1–3):401–6.
*Unkila M, Pohjanvirta R, MacDonald E, . 1994. Dose response and time course of alterations in tryptophan metabolism by 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in the most TCDD-susceptible and the most TCDD-resistant rat strain: Relationship with TCDD lethality. Toxicol Appl Pharmacol 128:280–292.7940543
*Unkila M, Tuomisto JT, Pohjanvirta R, . 1993b. Effect of a single lethal dose of TCDD on the levels of monoamines, their metabolites and tryptophan in discrete brain nuclei and peripheral tissues of Long-Evans rats. Pharmacol Toxicol 72(4–5):279–285.8372047
*USAF. 1991. Air Force health study: An epidemiological investigation of health effects in Air Force personnel following exposure to herbicides. Brooks Air Force Base, TX: U.S. Air Force, Chapters 1-5, 18, 19.
USDOC. 1984. Technical issues concerned with PCDD and PCDF formation and destruction in MSW fired incinerators. Gaithersburg, MD: National Bureau of Standards, U.S. Department of Commerce.
Uza M, Hunsinger R, Thompson T, . 1990. Validation studies of an automated preconcentration water sampler APS for chlorinated dibenzo-p-dioxins and dibenzofurans. Chemosphere 20:1349–1354.
Vaino H, Hesso A, Haeppinen P. 1989. Chlorinated dioxins and dibenzofurans in the environment. Scand J Work Environ Health 15:377–382.2482540
*Valli K, Wariishi H, Gold MH. 1992. Degradation of 2,7-dichlorodibenzo-p-dioxin by the lignin-degrading Basidiomycete Phanerochaete chrysosporium. Journal of Bacteriology 174(7):2131–2137.1551837
*Van Birgelen APJM, Van der Kolk J, Fase KM, . 1995. Subchronic dose-response study of 2,3,7,8-tetrachlorodibenzo-p-dioxin in female Sprague-Dawley rats. Toxicol Appl Pharmacol 132:1–13.7747272
*Van den Berg M, Birnbaum L, Bosveld ATC, . 1998. Toxic equivalency factors (TEFs) for PCBs, PCDDs, and PCDFs for humans and wildlife. Environ Health Perspect 106(12):775–792.9831538
Van den Berg M, Blank F, Heeremans C, . 1987a. Presence of polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans in fish-eating birds and fish from the Netherlands. Arch Environ Contam Toxicol 165:149–158.
*Van den Berg M, De Jongh J, Poiger H, . 1994. The toxicokinetics and metabolism of polychlorinated dibenzo-p-dioxins (PCDDs) and dibenzofurans (PCDFs) and their relevance to toxicity. Crit Rev. Toxicol 24:1–74.8172651
Van den Berg M, de Vroom E, van Greevenbroek M, . 1985. Bioavailability of PCDDs and PCDFs absorbed on fly ash in rat, guinea pig and Syrian golden hamster. Chemosphere 14:865–869.
*Van den Berg M, Heeremans C, Veenhoven E, . 1987b. Transfer of polychlorinated dibenzo-p-dioxins and dibenzofurans to fetal and neonatal rats. Fundam Appl Toxicol 9:635–644.3692020
Van den Berg M, Meerman L, Olie K, . 1986a. Retention of PCDDs and PCDFs in the liver of the rat and hamster after oral administration of a municipal incinerator fly ash extract. Toxicol Environ Chem 12:267–284.
*Van den Berg M, Olie K, Hutzinger O. 1983. Uptake and selection in rats of orally administered chlorinated dioxins and dibenzofurans from fly-ash and fly-ash extract. Chemosphere 12:537–544.
*Van den Berg M, Sinke M, Wever H. 1987c. Vehicle dependent bioavailability of polychlorinated dibenzo-p-dioxins (PCDDs) and dibenzofurans (PCDFs) in the rat. Chemosphere 16:1193–1203.
*Van den Berg M, Van der Wielen FWM, Olie K, . 1986b. Presence of PCDDs and PCDFs in human breast milk from the Netherlands. Chemosphere 15:693–706.
Van den Berg M, Van Greevenbroek M, Olie K, . 1986c. Bioavailability of polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans on fly ash after semi-chronic oral ingestion by the rat. Chemosphere 15:509–518.
*Van den Berg M, Van Wijnen J, Wever H, . 1989. Selective retention of toxic polychlorinated dibenzo-p-dioxins and dibenzofurans in the liver of the rat after intravenous administration of a mixture. Toxicology 55:173–182.2540547
*Van den Heuvel JP, Clark GC, Kohn MC, . 1994. Dioxin-responsive genes: Examination of dose-response relationships using quantitative reverse transcriptase-polymerase chain reaction. Cancer Res 54(1):62–68.8261464
*Van den Heuvel JP, Clark GC, Thompson CL, . 1993. CYP1A1 mRNA levels as a human exposure biomarker: use of quantitative polymerase chain reaction to measure CYP1A1 expression in human peripheral blood lymphocytes. Carcinogenesis 14:2003–2006.8222045
Van den Heuvel JP, Lucier G. 1993. Environmental toxicology of polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans. Environ Health Perspect 100:189–200.8394802
Van Der Kolk J, Van Birgelen A P JM, Poiger H, . 1992. Interactions of 2,2,4,4,5,5-hexachloro-biphenyl and 2,3,7,8-tetrachloeodibenzo-p-dioxin in a subchronic feeding study in the rat. Chemosphere 25:2023–2027.
Van der Welden MEJ, Craane LHJ, Evers EHG, . 1989. Bioavailability of PCDDs and PCDFs from bottom sediments and some associated biological effects in the carp (Cyprinus carpio). Chemosphere 19:1009–1016.
Van Logten MJ, Gupta BN, McConnell EE, . 1980. Role of the endocrine system in the action of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on the thymus. Toxicology 15:135–144.7376192
*Van Loveren H, Schuurman H-J, Kampinga J, . 1991. Reversibility of thymic atrophy induced by 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) and bis(tri-n-butyltin)oxide (TBTO). Int J Immunopharmacol 13(4):369–378.2050440
*Van Miller JP, Lalich JJ, Allen JR. 1977. Increased incidence of neoplasms in rats exposed to low levels of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Chemosphere 6:537–544.
*Van Miller JR, Marlar RJ, Allen JR. 1976. Tissue distribution and excretion of tritiated tetrachlorodibenzo-p-dioxin in non-human primates and rats. Food Cosmet Toxicol 14:31–34.815145
VANR. 1988. Vermont Agency of Natural Resources. Department of Environmental Conservation, Groundwater Protection Regulations, effective 9/29/88. Washington, DC: Bureau of National Affairs, Inc., State of Vermont Chapter 12.
*Vartiainen T, Jaakkola JJK, Saarikoski S, . 1998. Birth weight and sex of children and the correlation to the body burden of PCDDs/PCDFs and PCBs of the mother. Environ Health Perspect 106:61–66.9432971
*Vecchi A, Mantovani A, Sironi M, . 1980a. The effect of acute administration of 2,3,7,8-tetrachlorodibenzo-p-dioxin on humoral antibody production and cell-mediated activities in mice. Arch Toxicol Suppl 4:163–165.6933896
*Vecchi A, Mantovani A, Sironi M, . 1980b. Effect of acute exposure to 2,3,7,8-tetrachloro-dibenzo-p-dioxin on humoral antibody production in mice. Chem-Biol Interact 30:337–342.7379212
*Vecchi A, Sironi M, Canegrati M, . 1983b. Immunosuppressive effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin in the strains of mice with different susceptibility to induction of aryl hydrocarbon hydroxylase. Toxicol Appl Pharmacol 68:434–441.6857677
*Vecchi A, Sironi M, Canegrati MA, . 1983a. Comparison of the immunosuppressive effects in mice of 2,3,7,8-tetrachlorodibenzo-p-dioxin and 2,3,7,8-tetrachlorodibenzofuran. In: Choudhary G, Keith LH, Rappe C, eds. Chlorinated dioxins and dibenzofurans in the total environment. Boston, MA: Butterworth, 397–402.
Velzy CO. 1986. ASME standard sampling and analysis methods for dioxins/furans. Chemosphere 15:1179–1185.
*Vena J, Boffetta P, Becher H, . 1998. Exposure to dioxin and nonneoplastic mortality in the expanded IARC international cohort study of phenoxy herbicide and chlorophenol production workers and sprayers. Environ Health Perspect 106(Suppl 2):645–653.9599712
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: hypermethylation control of gene expression during the neonatal period. European Journal of Biochemistry 238:476–483.8681961
*Vikelsoe J, Madsen H, Hansen K. 1994. Emission of dioxins from Danish woodstoves. Chemosphere 29(9–11):2019–2027.
*Viluksela M, Stahl BU, Birnbaum LS, . 1998a. Subchronic/chronic toxicity of a mixture of four chlorinated dibenzo-p-dioxins in rats. I. Design, general observations, hematology, and liver concentrations. Toxicol Appl Pharmacol 151:57–69.9705887
*Viluksela M, Stahl BU, Birnbaum LS, . 1998b. Subchronic/chronic toxicity of a mixture of four chlorinated dibenzo-p-dioxins in rats. II. Biochemical effects. Toxicol Appl Pharmacol 151:70–78.9705888
*Viluksela M, Stahl BU, Rozman KK. 1994. Subchronic (13-week) toxicity of heptachlorodibenzo-p-dioxin in male Sprague-Dawley rats. Chemosphere 29:2381–2393.7850387
Vogg H, Metzger M, Stieglitz L. 1987. Recent findings on the formation and decomposition of PCDD/PCDF in municipal solid waste incineration. Waste Manage Res 5:285–294.
*Vos JG, Kreeftenberg JG, Engel HWB, . 1978. Studies on 2,3,7,8-tetrachlorodibenzo-p-dioxin-induced immune suppression and decreased resistance to infection: endotoxin hypersensitivity, serum zinc concentrations and effect of thymosin treatment. Toxicology 9:75–86.653744
*Vos JG, Moore JA. 1974. Suppression of cellular immunity in rats and mice by maternal treatment with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Int Arch Allergy 47:777–794.4154311
*Vos JG, Moore JA, Zinkl JG. 1973. Effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin on the immune system of laboratory animals. Environ Health Perspect 5:149–162.4148092
WAC. 1988. Control of hazardous pollutants. Wisconsin Administrative Code, Chapter NR 445. Department of Natural Resources.
*Wacker R, Poiger H, Schlatter C. 1986. Pharmacokinetics and metabolism of 1,2,3,7,8-pentachloro-dibenzo-p-dioxin in the rat. Chemosphere 15:1473–1476.
*Wagner SL, Durand LR, Inman RD, . 1991. Residues of pentachlorophenol and other chlorinated contaminants in human tissues: Analysis by electron capture gas chromatography and electron capture negative ion mass spectrometry. Arch Environ Contam Toxicol 21(4):596–606.1759853
*Wahba ZZ, Lawson TW, Murray WJ, . 1989. Factors influencing the induction of DNA single strand breaks in rats by 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Toxicology 58:57–69.2554534
Wakimoto T, Tatsukawa R. 1985. Polychlorinated dibenzo-p-dioxins and dibenzofurans in fly ash and cinders collected from several municipal incinerators in Japan. Environ Health Perspect 59:159–162.3987650
*Walden R, Schiller CM. 1985. Comparative toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in four (sub)strains of adult male rats. Toxicol Appl Pharmacol 77:490–495.3975916
*Walker NJ, Miller BD, Kohn MC, . 1998. Differences in kinetics of induction and reversibility of TCDD-induced changes in cell proliferation and CYP1A1 expression in female Sprague-Dawley rat liver. Carcinogenesis 19:1427–1435.9744539
*Waller CL, McKinney JD. 1995. Three-dimensional quantitative structure-activity relationships of dioxins and dioxin-like compounds: Model validation and Ah receptor characterization. Chem Res Toxicol 8:847–858.7492734
Walters RW, Guiseppi-Elie A. 1988. Sorption of 2,3,7,8-tetrachlorodibenzo-p-dioxin to soils from water/methanol mixtures. Environ Sci Technol 22:819–825.22195667
*Wan MT, Van Oostdam J. 1995. Utility and railroad rights-of-way contaminants: Dioxins and furans. J Environ Quality 24(2):61–69.
*Wang DKW, Chiu DH, Leung PK, . 1983. Sampling and analytical methodologies for PCDDs and PCDFs in incinerators and wood burning facilities. Environ Sci Res 26:113–126.
*Wang GL, Jiang B-H, Rue EA, . 1995. Hypoxia-inducible factor 1 is a basic-helix-loop-helix-PAS heterodimer regulated by cellular O2 tension. Proc Natl Acad Sci USA 92: 5510–5514.7539918
*Wang GL, Semanza GL. 1995. Purification and characterization of hypoxia-inducible factor 1. J Biol Chem 270: 1230–1237.7836384
*Wang X, Narasimhan TR, Morrison V, . 1991. In situ and in vitro photoaffinity labeling of the nuclear aryl hydrocarbon receptor from transformed rodent and human cell lines. Arch Biochem Biophys 287:186–194.1654803
*Wang X, Santostefano MJ, Evans MV, . 1997. Determination of parameters responsible for pharmacokinetic behavior of TCDD in female Sprague-Dawley rats. Toxicol Appl Pharmacol 147:151–168.9356318
*Ward CT, Matsumura F. 1978. Fate of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in a model aquatic environment. Arch Environ Contam Toxicol 7:349–357.727830
Wassom JS, Huff JE, Loprieno N. 1978. A review of the genetic toxicology of chlorinated dibenzo-p-dioxins. Mutat Res 47:141–160.
WDNR. 1987. Surface water quality criteria for toxic substances. Order of the State of Wisconsin Natural Resources Board repealing, renumbering, renumbering and amending, and amending, repealing and recreating, and creating rules. Section 27, Chapter NR 105. Wisconsin Department of Natural Resources.
*Webb K, Ayres S, Slavin R, . 1984. Results of a pilot study of health effects due to 2,3,7,8-tetrachlorodibenzodioxin contamination-Missouri. MMWR 33:54–61.6420667
*Webb KB, Evans RG, Knutsen AP, . 1989. Medical evaluation of subjects with known body levels of 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Toxicol Environ Health 28:183–193.2677396
*Weber H, Birnbaum LS. 1985. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD) and 2,3,7,8-tetrachlorodibenzofuran (TCDF) in pregnant C57BL/6N mice: Distribution to the embryo and excretion. Arch Toxicol 57:159–162.4062549
*Weber H, Harris MW, Haseman JK, . 1985. Teratogenic potency of TCDD, TCDF, and TCDD-TCDF combinations in C57BL/6N mice. Toxicol Lett 26:159–167.4035709
*Weber H, Poiger H, Schlatter C. 1982. Acute oral toxicity of TCDD-metabolites in male guinea pigs. Toxicol Lett 14:117–122.7157412
*Weber LW, Lebofsky M, Stahl BU, . 1992a. Comparative toxicity of four chlorinated dibenzo-p-dioxins (CDDs) and their mixture. Part II: Structure-activity relationships with inhibition of hepatic phospholpyruvate carboxykinase, pyruvate carboxylase, and gamma-glutamyl transpeptidase activities. Arch Toxicol 66(7):478–483.1359853
*Weber LW, Lebofsky M, Stahl BU, . 1992b. Comparative toxicity of four chlorinated dibenzo-p-dioxins (CDDs) and their mixture. Part III: Structure-activity relationship with increased plasma tryptophan levels, but no relationship to hepatic ethoxyresorufin o-deethylase activity. Arch Toxicol 66(7):484–488.1332652
*Weber LWD, Lebofsky M, Greim H, . 1991a. Key enzymes of gluconeogenesis are dose-dependently reduced in 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD)-treated rats. Arch Toxicol 65:119–123.2059151
*Weber LWD, Lebofsky M, Stahl BU, . 1991b. Reduced activities of key enzymes of gluconeogenesis as possible cause of acute toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in rats. Toxicology 66:133–144.1849669
*Weber LWD, Lebofsky M, Stahl BU, . 1995. Correlation between toxicity and effects on intermediate metabolism in 2,3,7,8-tetrachlorodibenzo-p-dioxin-treated male C57BL/6J and DBA/2J mice. Toxicol Appl Pharmacol 131:155–162.7878671
*Weber LWD, Palmer CD, Rozman K. 1994. Reduced activity of trytophan 2,3,-dioxygenase in the liver of rats treated with chlorinated dibenzo-p-dioxins (CDDs): Dose-responses and structure-activity relationship. Toxicol 86:63–69.
*Weber LWD, Stahl BU, Rozman K. 1992c. Are serotonergic mechanisms involved in the acute toxicity of chlorinated dibenzo-p-dioxins (CDDs)? Chemosphere 25:161–164.
*Weber LWD, Zesch A, Rozman K. 1991d. Penetration, distribution and kinetics of 2,3,7,8-tetrachlorodibenzo-p-dioxin in human skin in vitro. Arch Toxicol 65:421–428.1929859
Weber LWD, Zesch A, Rozman K. 1992d. Decontamination of human skin exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in vitro. Arch Environ Health 47:302–308.1497385
*Weber TJ, Ou X, Hart C, . 1991c. Modulation of protein phosphorylation in rat aortic smooth muscle cells by 2,3,7,8-tetrachlorodibnezo-p-dioxin (TCDD) in vivo [Abstract 1335]. Toxicologist 11: 340.
*Webster GRB, Friesen KL, Sarna LP, . 1985. Environmental fate modelling of chlorodioxins: Determination of physical constants. Chemosphere 14:609–622.
Webster GRB, Sarna LP, Friesen K, . 1984. HPLC techniques for the evaluation of the interactions of organic contaminants with individual environmental compartments. Am Chem Soc Div Environ Chem 24:42–45.
*Weerasinghe NCA, Schecter AJ, Pan JC, . 1986. Levels of 2,3,7,8-tetrachlorodibenzo-p-dioxin (2,3,7,8-TCDD) in adipose tissue of Vietnam veterans seeking medical assistance. Chemosphere 15:1787–1794.
Weeren RD, Asshauer J. 1985. Problem and results of trace analysis of 2,3,7,8-tetrachlorodibenzo-p-dioxin in 2,4,5-trichlorophenoxyacetic acid and its esters. J Assoc Off Anal Chem 68:917–921.4055639
*Weib C, Kolluri SK, Kiefer F, . 1996. Complementation of Ah receptor deficiency in hepatoma cells: negative feedback regulation and cell cycle control by the Ah receptor. Exp Cell Res 226:154–163.8660951
*Weisglas-Kuperus N, Sas TCJ, Koopman-Esseboom C, . 1995. Immunologic effects of background prenatal and postnatal exposure to dioxins and polychlorinated biphenyls in Dutch infants. Pediatr Res 38:404–410.7494667
*Weisiger R, Gollan J, Ockner R. 1981. Receptor for albumin on the liver cell surface may mediate uptake of fatty acids and other albumin-bound substances. Science 211:1048–1050.6258226
*Weissberg JB, Zinkl JG. 1973. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin upon hemostasis and hematologic function in the rat. Environ Perspect 5:119–124.
Welch KJ, Hoffman NE. 1993. Analysis of polychlorinated biphenyls, dibenxodioxins and dibenzofurans by online coupled micro-column HPLC capillary GC-MS. Journal of Liquid Chromatography 16:307–313.
*Welschpausch K, McLachlan MS, Umlauf G. 1995. Determination of the principal pathways of polychlorinated dibenzo-p-dioxins and dibenzofurans to Lolium multiflorum, Welsh ray grass. Environ Sci Technol 24(4):1090–1098.
*Wendling JM, Orth RG, Poiger H. 1990. Determination of [3H]-2,3,7,8-tetrachlorodibenzo-p-dioxin in human feces to ascertain its relative metabolism in man. Anal Chem 62:796–800.2349995
*Wenning RJ, Erickson G. 1994. Interpretation and analysis of complex environmental data using chemometric methods. Trends in Analytical Chemistry 13(10):446–456.
Wenning RJ, Harris MA, Finley B, . 1993a. Application of pattern recognition techniques to evaluate polychlorinated dibenzo-p-dioxin and dibenzofuran distributions in surficial sediments from the lower Passaic River and Newark Bay. Ecotoxicol Environ Saf 25(1):103–125.7682913
Wenning RJ, Harris MA, Paustenbach DJ, . 1992. Potential sources of 1,2,8,9-tetrachloro-dibenzo-p-dioxin in the aquatic environment. Ecotoxicol Environ Saf 23(2):133–146.1374322
*Wenning RJ, Paustenbach D, Johnson G, . 1993b. Chemometric analysis of potential sources of polychlorinated dibenzo-p-dioxins and dibenzofurans in surficial sediments from Newark Bay, New Jersey. Chemosphere 27(1–3):55–64.
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J. of Pediatrics 32a:10–18.
*White DH, Hoffman DJ. 1995. Effects of polychlorinated dibenzo p-dioxins and dibenzofurans on nesting wood ducks (aix sponsa) at Bayou Meto, Arkansas. Environmental Health Perspectives 103(suppl.4):37–39.
*White KL Jr, Lysy HH, McCay JA, . 1986. Modulation of serum complement levels following exposure to polychlorinated dibenzo-p-dioxins. Toxicol Appl Pharmacol 84:209–219.3715871
*Whitelaw M, Pongratz I, Gustafsson J-A, . 1993. Ligand-dependent recruitment of the Arnt coregulator determines DNA recognition by the dioxin receptor. Mol Cell Biol 13:2504–2514.8384309
Whitlock JB Jr. 1990. Genetic and molecular aspects of 2,3,7,8-tetrachlorodibenzo-p-dioxin action. Ann Rev Pharmacol Toxicol 30:251–277.2188570
*Whitlock JP Jr. 1987. The regulation of gene expression by 2,3,7,8-tetrachlorodibenzo-p-dioxin. Pharmacol Rev 39:147–161.3303065
*Whitlock JP Jr. 1993. Mechanistic aspects of dioxin action. Chem Res Toxicol 6:754–763.8117913
*Whittle DM, Mageau C, Duncan RK, . 1993. Canadian national dioxin sampling program: Dioxins and furans in biota near 46 puop and paper mills using the chlorine bleaching process. Chemosphere 27(1–3):279–86.
WHO. 1988. Environmental Health 29. No. 29. PCBs, PCDDs, and PCDFs in breast milk. Assessments of Health Risks. World Health Organization, Copenhagen Denmark.
*WHO. 1991. Consultation on tolerable daily intake from food of PCDDs and PCDFs. Summary report. Bilthoven, Netherlands: World Health Organization, Copenhagen Denmark.
*WHO. 1998. WHO toxic equivalent factors (TEFs) for dioxin-like compounds for humans and wildlife. Environ Health Perspect 106(12):775–792..9831538
*WHO. 1998a. WHO revises the tolerable daily intake (TDI) for dioxins. World Health Organization. 18th Symposium on Halogenated Environmental Organic Pollutants. Stockholm, Sweden. August 17-21, 1998. Organohalogens Compounds. Volume 38, 295–298.
*WHO. 1998b. World Health Organization. WHO Information. 1998 Press Releases. Press Release WHO/45. June 3, 1998. http://www.who.int/inf-pr-1998/en/pr98-45.html.
*Wiberg K, Lundstr÷m K, Glas B, . 1989. PCDDs and PCDFs in consumers’ paper products. Chemosphere 19:735–740.
*Widdowson EM, Dickerson JWT. 1964. Chapter 17: Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise, Volume II - the elements part A. New York, NY: Academic Press.
*Wiklund K, Dich J, Holm LE. 1987. Risk of malignant lymphoma in Swedish pesticide appliers. Br J Cancer 56:505–508.3689667
*Wiklund K, Holm LE. 1986. Soft tissue sarcoma risk in Swedish agriculture and forestry workers. J Natl Cancer Inst 76:229–234.3456061
*Wikstrom E, Lofvenius G, Rappe C, Marklund S. 1996. Influence of level and form of chlorine on the formation of chlorinated dioxins, dibenzofurans, and benzenes during combustion of an artificial fuel in a laboratory reactor. Environmental Science & Technology 30(5):1637–1644.
*Wild SR, Harrad SJ, Jones KC. 1993. The influence of sewage sludge applications to agricultural land on human exposure to polychlorinated dibenzo-p-dioxins (PCDDs) and -furans (PCDFs). Environ Pollution 357–369.
*Wild SR, Jones KC. 1992. Organic chemicals entering agricultural soils in sewage sludges: Screening for their potential to transfer to crop plants and livestock. Sci Total Environ 119:85–119.1631535
*Wilker C, Johnson L, Safe S. 1996. Effects of developmental exposure to indole-3-carbinol or 2,3,7,8-tetrachlorodibenzo-p-dioxin on reproductive potential of male rat offspring. Toxicol Appl Pharmacol 141:68–75.8917677
*Williams DT, Cunningham HM, Blanchfield BJ. 1972. Distribution and excretion studies of octachlorodibenzo-p-dioxin in the rat. Bull Environ Contam Toxicol 7:57–62.4669485
Williams DT, LeBel GL, Benoit FM. 1992. Polychlorodibenzodioxins and polychlorodibenzofurans in dioxazine dyes and pigments. Chemosphere 24(2):169–180.
Williams PL. 1983. Commercial PCP: Toxic impurities. Occup Health Saf 52:14–16.
Wilson JD. 1986. Airborne dioxins and dibenzofurans: Sources and fates. Comments. Environ Sci Technol 20:1185–1186.
*Winters D,Cleverly D, meier K, . 1996. A statistical survey of dioxin-like compounds in United States beef: a progress report. Chemosphere 32(3):469–478.8907224
Wipf HK, Schmid J. 1983. Seveso--an environmental assessment. In: Tucker RE, ed. Human and environmental risk of chlorinated dioxins and related compounds. New York, London: Plenum Publishing Corp, 255–274.
*Wolfe RJ, Walker RJ. 1987. Subsistence economies in Alaska: Productivity, geography, and development impacts. Arctic Anthropology 24(2):56–81.
*Wolfe WH, Lathrop GD, Albanese RA, . 1985. An epidemiologic investigation of health effects in Air Force personnel following exposure to herbicides and associated dioxins. Chemosphere 14:707–716.
*Wolfe WH, Michalek JE, Miner JC, . 1994. Determinants of TCDD half-life in veterans of Operation Ranch Hand. J Toxicol Environ Health 41:481–488.8145287
*Wolfe WH, Michalek JE, Miner JC, . 1995. Paternal serum dioxin and reproductive outcomes among veterans of Operation Ranch Hand. Epidemiol 6:17–22.
*Wood SC, Jeong HG, Morris DL, . 1993. Direct effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on human tonsillar lymphocytes. Toxicology 81(2):131–43.8378939
Wood SC, Karras JG, Holsapple MP. 1992. Integration of the human lymphocyte into immunotoxicological investigations. Fundam Appl Toxicol 18(3):450–9.1597269
Woods JS, Polissar L, Severson RK, . 1989. Soft tissue sarcoma and non-Hodgkin’s lymphoma in relation to phenoxyherbicide and chlorinated phenol exposure in western Washington. J Natl Cancer Inst 78:889–910.
*Worobec SM, DiBeneditto JP. 1984. Perspectives on occupational dermatoses. In: Drill VA, Lazar P, eds. Cutaneous toxicity. New York, NY: Raven Press, 253–268.
*Wroblewski VJ, Olson JR. 1985. Hepatic metabolism of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in the rat and guinea pig. Toxicol Appl Pharmacol 81:231–240.4060152
*Wu L, Whitlock J P JR. 1992. Mechanism of dioxin action: Ah receptor-mediated increase in promotor accessibility in vivo. Proc Natl Acad Sci USA 89(11):4811–4815.1317573
*Wu L, Whitlock JP Jr. 1993. Mechanism of dioxin action: Receptor-enhancer interaction in intact cells. Nucleic Acids Res 21:119–125.8382788
Wurrey CJ, Bourne S, Kloepfer RD. 1986. Application of gas chromatography/ matrix isolation/Fourier transformer infrared spectrometry to dioxin determinations. Anal Chem 58:482–483.
*Wuthe J, Link B, Walther J, . 1993. Dioxin and furan (PCDD/PCDF) levels in human blood from persons living in a contaminated area. Chemosphere 27(103):287–293.
Yamagishi T, Miyazaki T, Akiyama K, . 1981. Polychlorinated dibenzo-p-dioxins and dibenzofurans in commercial diphenyl ether herbicides and in fresh water fish collected from the application area. Chemosphere 10:1137–1144.
*Yamamoto T, Fukushima M. 1993. Modeling study on contribution of combustion source complex to PCDD/PCDF levels in urban air. Chemosphere 27(1–3):295–300.
*Yamashita N, Tanabe S, Ludwig JP, . 1992. Embryonic abnormalities and organochlorine contamination in double-crested cormorants (phalacrocorax auritus) and Caspian Terns (hydroprogne caspia) from the upper Great Lakes in 1988. Environ Pollution 19:163–173.
*Yanders AF, Orazio CE, Puri RK, . 1989. On translocation of 2,3,7,8-tetrachlorodibenzo-p-dioxin: Time dependent analysis at the Times Beach experimental site. Chemosphere 19:429–432.
*Yang KH, Croft WA, Peterson RE. 1977. Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin on plasma disappearance and biliary excretion of foreign compounds in rats. Toxicol Appl Pharmacol 40:485–496.882983
*Yang XP, Masten SA, Clark GC, . 1997. Markers of exposure and susceptibility to dioxin in german chemical plant workers (meeting abstract). Proceedings of the American Association for Cancer Research 38:352–353.
*Yang YG, Lebrec H, Burleson GR. 1994. Effect of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on pulmonary influenza virus titer and natural killer (NK) activity in rats. Fund Appl Toxicol 23:125–131.
Yasuda M, Nariat M. 1989. Modification of teratogenicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin in mice with various factors [Abstract]. Teratology (Japanese Teratology Society Abstracts) 40:678.
Yasuhara A, Morita M. 1989. Formation of chlorodibenzofurans by thermal decomposition of vinylidene-chloride polymer. Chemosphere 18:1737–1740.
*Yockim RS, Isensee Ar, Jones GE. 1978. Distribution and toxicity of TCDD and 2,4,5,-T in an aquatic model ecosystem. Chemosphere 3:215–220.
Young AL. 1984a. Analysis of dioxins and furans in human adipose tissue. Public Health Risk Dioxins Proc Symp 63–75.
Young AL. 1984b. Determination and measurement of human exposure to the dibenzo-p-dioxins. Bull Environ Contam Toxicol 33:702–709.6240290
Young AL, Cockerham LG, Thalken CE. 1987. A long-term study of ecosystem contamination with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Chemosphere 16:1791–1815.
Young AL, Kang HK. 1985. Status and results of federal epidemiologic studies of populations exposed to TCDD. Chemosphere 14:779–790.
Young AL, Kang HK, Shepard BM. 1983. Chlorinated dioxins as herbicide contaminants. Environ Sci Technol 17:530A–540A.22276788
Young AL, Thalken CE, Harrison DD. 1981. Persistence, bioaccumulation, and toxicology of TCDD in an ecosystem treated with massive quantities of 2,4,5-T herbicide. Proc West Soc Weed Sci 34:70–77.
*Yousefi Z, Walters RW. 1987. Use of soil columns to measure sorption of dioxins to soils. Toxic Hazard Wastes 19:181–193.
Zabik ME, Zabik MJ. 1980. Dioxin levels in raw and cooked liver, loin steaks, round and patties from beef fed technical grade pentachlorophenol. Bull Environ Contam Toxicol 24:344–349.
*Zacharewski T, Harris M, Biegel L, . 1992. 6-Methyl-1,3,8-trichlorodibenzofuran (MCDF) as an antiestrogen in human and rodent cancer cell lines: Evidence for the role of the Ah receptor. Toxicol Appl Pharmacol 113:311–318.1313996
*Zacharewski T, Harris M, Safe S. 1991. Evidence for the mechanism of action of the 2,3,7,8-tetrachlorodibenzo-p-dioxin-mediated decrease of nuclear estrogen receptor levels in wild-type and mutant Hepa 1c1c7 cells. Biochem Pharmacol 41:1931–1939.1645554
*Zacharewski T, Safe L, Safe S, . 1989. Comparative analysis of polychlorinated dibenzo-p-dioxin and dibenzofuran congeners in Great Lakes fish extracts by gas chromatography and in vitro enzyme induction activities. Environ Sci Technol 23:730–735.
*Zack JA, Suskind RR. 1980. The mortality experience of workers exposed to tetrachlorodibenzodioxin in a trichlorophenol process accident. J Occup Med 22:11–14.6444441
Zeiger E. 1983. Memorandum from Dr. Zeiger to Dr. E.E. McConnell on the results of test performed for the Environmental Mutagenesis Development Program. NTP, NIEHS.
*Zhong Y, Overcash MR, McPeters AL. 1993. Near sunlight zone model for photodegradation of TCDD in soils containing organic solvents. Chemosphere 26(7):1263–1272.
*Ziegler EE, Edwards BB, Jensen RL . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
*Zimmering S, Mason JM, Valencia R, . 1985. Chemical mutagenesis testing in Drosophila: II. Results of 20 coded compounds tested for the National Toxicology Program. Environ Mutagen 7:87–100.3917911
*Zinkl JG, Vos JG, Moore JA, . 1973. Hematologic and chemical clinical chemistry of 2,3,7,8-tetrachlorodibenzo-p-dioxin in laboratory animals. Environ Health Perspect 5:111–118.4752897
Zitko V. 1989a. A graphical presentation of the composition and properties of chlorinated dibenzodioxins and dibenzofurans. Sci Total Environ 83:191–194.
Zitko V. 1989b. Composition of chlorinated dibenzodioxins and dibenzofurans in various samples. Sci Total Environ 80:127–137.2762798
Zitko V, Hutzinger O, Choi PMK. 1972. Contamination of the Bay of Fundy - Gulf of Maine area with polychlorinated biphenyls, polychlorinated terphenyls, chlorinated dibenzodioxins, and dibenzofurans. Environ Health Perspect 1:47–50.17539085
*Zober A, Messerer P, Huber P. 1990. Thirty-four-year mortality follow-up of BASF employees exposed to 2,3,7,8-TCDD after the 1953 accident. Int Arch Occup Environ Health 62:139–157.2139014
*Zober A, Ott M, Fleig I, . 1993. Cytogenic studies in lymphocyte of workers exposed to 2,3,7,8-TCDD. Int Arch Occup Environ Health 65:157–161.8282413
*Zober A, Ott MG, Messerer P. 1994. Morbidity follow up study of BASF employees exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) after a 1953 chemical reactor incident. Occup Environ Med 51:479–486.8044248
*Zober A, Papke O. 1993. Concentrations of PCDDs and PCDFs in human tissue 36 years after accidental dioxin exposure. Chemosphere 27:413–418.
Zook DR, Rappe C. 1994. Environmental sources, distribution, and fate of polychlorinated dibenzodioxins, dibenzofurans, and related organochlorines. In: Schecter A, ed. Dioxins and health. New York: Plenum Press, 80–113.