# PAST PEER-REVIEWS

Several drafts of the Toxicological Profile for Chlorinated Dibenzo-p-Dioxins were submitted for a peer-review in the past.

## Draft 1997

Ross Norstrom, | National Wildlife Research Center, Environment Canada, Hull, Quebec, Canada
James Olson, | Department of Pharmacology and Toxicology, State University of New York at Buffalo, Buffalo, NY
Dennis Paustenbach, | McLaren/Hart ChemRisk, Alameda, CA
John Ryan, | Bureau of Chemical Safety, Health and Welfare Canada, Ottawa, Ontario, Canada
Arnold Schecter, | College of Medicine, State University of New York, Health Science Center, Binghamton, NY

## Draft 1994 (scientific panel meeting)

Anthony DeCaprio, | Wadsworth Center for Laboratories and Research, New York State Department of Health, Albany, NY
Thomas Gasiewicz, | University of Rochester Medical Center, Rochester, NY
Ross Norstrom, | National Wildlife Research Center, Environment Canada, Hull, Quebec, Canada
James Olson, | Department of Pharmacology and Toxicology, State University of New York at Buffalo, Buffalo, NY
Dennis Paustenbach, | McLaren/Hart ChemRisk, Alameda, CA
John Ryan, | Bureau of Chemical Safety, Health and Welfare Canada, Ottawa, Ontario, Canada
Arnold Schecter, | College of Medicine, State University of New York, Health Science Center, Binghamton, NY

## Draft 1992

Thomas Gasiewicz, | University of Rochester Medical Center, Rochester, NY
James Olson, | Department of Pharmacology and Toxicology, State University of New York at Buffalo, Buffalo, NY
Arnold Schecter, | College of Medicine, State University of New York, Health Science Center, Binghamton, NY

## Draft 1991

Thomas Gasiewicz, | University of Rochester Medical Center, Rochester, NY
Arleen Rifkind, | Cornell University of Medical College, New York, NY
Arnold Schecter, | College of Medicine, State University of New York, Health Science Center, Binghamton, NY
Jay Silkworth, | Wadsworth Center for Laboratories and Research, New York State Department of Health, Albany, NY