# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding CDDs in air, water, and other media are summarized in Table 7-1.

It is ATSDR’s policy (see Appendix B) to use health guidance values (i.e., MRLs and EMEGs) derived for 2,3,7,8-TCDD for other dioxin-like compounds expressed as total TEQs.

ATSDR has derived an acute-duration oral MRL of 0.0002 µg/day (2×10^−4^ µg/kg/day) for 2,3,7,8-TCDD based on its ability to suppress serum total hemolytic complement activity in B6C3F_1_ mice (White et al. 1986).

An intermediate-duration oral MRL of 0.00002 µg/day (2×10^−5^ µg/kg/day) was derived based on observed decreases in thymus weight in guinea pigs (Decaprio et al. 1986).

A chronic-duration oral MRL of 0.000001 µg/day (1×10^−6^ µg/kg/day) was derived for 2,3,7,8-TCDD based on altered social interactions with peers in monkeys exposed to 2,3,7,8-TCDD prenatally and during lactation (Schantz et al. 1992).

Neither a reference concentration (RfC) nor a reference dose (RfD) is listed in IRIS (IRIS 1998) for any of the CDDs.

The IRIS database does not contain a weight-of evidence cancer classification for 2,3,7,8-TCDD. The EPA is currently in the final stages of re-evaluating the risks and hazards from exposures to CDDs and CDD-like-like compounds. In its proposed rule to add a chemical category that includes dioxin and dioxin-like compounds to the list of toxic chemicals subject to release reporting requirements, EPA acknowledged that existing data shows “2,3,7,8-TCDD is a potent toxicant in animals and has the potential to a produce a wide spectrum of toxic effects in humans” (EPA 1997c). In the preamble of the rule EPA further states that “Available human data cannot clearly demonstrate whether a cause and effect relationship exists between 2,3,7,8-TCDD exposure and increased incidence of cancer. However, there are a number of epidemiological studies associating exposure to 2,3,7,8,-TCDD with cancer mortality” (EPA 1997c). Making reference to the 1985 cancer slope factor (1.56 × 10^5^ [mg/kg/day]^−1^) (EPA 1985d) for 2,3,7,8-TCDD and considering its own weight-of-evidence classification criteria, EPA states that “there is sufficient evidence to conclude that the compound is a probable human carcinogen” (EPA 1997c). In February, 1997, the International Agency for Research on Cancer (IARC) evaluated the evidence for CDDs being risk factors for human cancer (IARC 1997). Consequently, IARC currently identifies 2,3,7,8-TCDD as being carcinogenic to humans; Group 1 carcinogen (IARC 1997). IARC concluded that there is limited evidence in humans for the carcinogenicity of 2,3,7,8-TCDD; however, data from studies involving experimental animals provided sufficient evidence of carcinogenicity. Giving consideration to supporting evidence such as 2,3,7,8-TCDD being a multi-site carcinogen in experimental animals; its acting through a mechanism involving Ah receptor which functions the same way in humans as in experimental animals; and similar tissue concentrations both in heavily exposed human populations and rats exposed to carcinogenic dosages, IARC’s overall evaluation for 2,3,7,8-TCDD is that it is carcinogenic to humans (IARC 1997). The Department of Health and Human Services (DHHS), National Toxicology Program (NTP) considers it to be a substance that is “reasonably anticipated to be a carcinogen.” Again, the supporting data indicate that the evidence of 2,3,7,8-TCDD carcinogenicity in humans is limited, but that there is sufficient evidence of carcinogenic effects in studies involving experimental animals (NTP 1998). NTP is currently considering a reclassification of 2,3,7,8-TCDD and the decision is pending.

EPA regulates dioxins as hazardous air pollutants (HAPs) in accordance with the provisions of the Clean Air Act (CAA). EPA has promulgated guidelines and performance standards limiting dioxin and other HAP emissions from various sources (i.e., major, stationary, and area). A wide variety of health effects (e.g., cancer, respiratory problems, developmental and/or reproductive effects) have been associated with exposure to HAP emissions (EPA 1998c). Some of the sources for which EPA has most recently promulgated or proposed guidelines and standards under the authority of the CAA are municipal waste combustors (MWCs), hospital/medical/infectious/waste combustors (HMIWI), and process operations in the Portland Cement industry (EPA 1997a, 1997b, 1998c).

Owners and operators of facilities that have chemicals subject to “The Emergency Planning and Community Right-to-Know Act (EPCRA) of 1986” on their sites in amounts exceeding a designated “reporting threshold level” are required to annually report releases of such chemicals to any environmental media (U.S. Congress 1986). On May 7, 1997, EPA proposed adding a chemical category that includes dioxin and 27 dioxin-like compounds to the list of toxic chemicals subject to the EPCRA reporting requirements (EPA 1997c).

2,3,7,8-TCDD is also regulated as a drinking water contaminant. As an impurity in the production of some pesticides, 2,3,7,8-TCDD may get into drinking water by industrial discharge of waste. EPA has set a drinking water standard (Maximum Contaminant Level [MCL]) for dioxin at 3×10^−8^ ppm (EPA 1994d). People who drink water containing dioxin in excess of the MCL over many years could experience problems with their reproductive systems and may have an increased risk of cancer (EPA 1998d). There is little to no risk associated with drinking-water that meets the MCL (EPA 1994d). In February 1998, as mandated by the Safe Drinking Water Act (SDWA), EPA issued a proposed rule that would require community water systems to inform the public as to the quality of the water delivered by the system (EPA 1998). The community right-to-know provisions of the SDWA mandate a reporting which informs the public of where their water comes from, shows them the process by which safe drinking water is delivered to their homes, provide access to information concerning source water assessments, and allows them to make informed decisions about their drinking water (EPA 1998d). The SDWA provisions also include requirements for timely notifications of violations. Within 24 hours, people served by public water systems must be notified of any violations of the national drinking water standard that have the potential to have serious adverse health effects (EPA 1998d). The SDWA amendments of 1996 required the FDA to issue monitoring requirements for nine allowable contaminants in bottled water (FDA 1998a, 1998b). 2,3,7,8-TCDD is included among these nine chemicals.

2,3,7,8-TCDD is regulated by the Clean Water Effluent Guidelines for the following industrial point sources: electroplating (EPA 1981a), steam electric power generating (EPA 1982a), and metal finishing (EPA 1986g). Limitations depend on the type of industry and plant. If waters and their sediments become contaminated from sources such as atmospheric deposition and discharges from industrial, municipal, or agricultural operations, toxic substances could concentrate in the tissue of fish and wildlife. Sixty-six advisories have been issued by 21 states recommending consumers limit their consumption of fish and shellfish (EPA 1998b). For 14 states (Wisconsin, Rhode Island, New Hampshire, West Virginia, Louisiana, Arkansas, Virginia, Michigan, Mississippi, Florida, Massachusetts, Oregon, Tennessee, and Delaware) advisories were issued for freshwater fish (EPA 1998b). Only two states (Texas and California) issued advisories for marine waters only (EPA 1998b). An advisory for woodduck (migratory fowl) was issued for the state of Arkansas. This information is current as of December 1997, based on the EPA Fish and Wildlife Advisory Database searched October 1998 at: http://www.epa.gov/OST/fishadvice/. More detailed information can be obtained from the state Public Health Department or the state Department of Natural Resources. A fish or wildlife advisory will specify the bodies of water or hunting areas with restrictions. The advisory will indicate what species and size of fish or game are of concern. The advisory may completely ban consumption or recommend limiting meals of a certain fish or wildlife species to a particular frequency. For example, an advisory may recommend that a person eat a certain type of fish no more than once a month. The advisory may indicate that only certain parts of the fish or game should be consumed and recommend preparation methods that minimize exposure. Fish and wildlife advisories may also provide restrictions specifically targeting pregnant women, nursing mothers, and young children. Each state, Native American Tribe, or U.S. Territory chooses its own criteria for issuing fish and wildlife advisories.

2,3,7,8-TCDD is regulated as a hazardous waste constituent under the requirements of the Resource Conservation and Recovery Act (RCRA) (EPA 1988d). Non-specific sources of 2,3,7,8-TCDD-containing waste are wastes from the production or manufacturing use of tri-, tetra-, or pentachlorophenols and their pesticide derivatives, discarded or unused formulations containing these compounds, and residues from incineration or thermal treatment of soil contaminated with these compounds. RCRA prohibits land disposal of hazardous waste unless it meets treatment standards established by the EPA. On May 12, 1997, the EPA promulgated universal treatment standards (UTSs) for hazardous constituents in wood preserving waste. These wastes have been assigned EPA hazardous waste codes F032, F034, and F035 (EPA 1997d). The final rule also promulgated a compliance alternative for dioxin constituents in nonwastewater and wastewater forms of F032 waste which allowed combustion to be used as a method of treatment (EPA 1997d).

The Toxic Substance Control Act (TSCA) authorizes the EPA to determine whether the use of a chemical substance is a “significant new use” (EPA 1998e). Once it has been determined that a use of a chemical is a significant new use, it must be reported to the EPA prior to manufacturing, importing, or processing for the new use. The required notice will provide the EPA with an opportunity to evaluate the intended use, and if necessary, to prohibit or limit the activity before it occurs (EPA 1998e). For example, brominated phthalate ester was included among the 163 chemical substances for which the EPA promulgated significant new use rules (SNURs). The toxicity concern for the new use was that when similar chemicals have been incinerated under combustion conditions of municipal incinerators, dibenzodioxins and dibenzofurans were formed (EPA 1998e). Persons providing notice of this new use would need to characterize, through an incineration simulation, the potential for dioxin and furan formation and agree not to exceed the production volume limit without performing the characterization (EPA 1998e).

Table 7-1 Regulations and Guidelines Applicable to CDDs

Agency | | Description | Information | | References
[underlined: INTERNATIONAL]
IARC | | Carcinogenic classification (2,3,7,8-TCDD) | Group 1^a^ | | IARC 1997
WHO | | Total daily intake (TDI) range | 1–4 pg /kg body weight | | WHO 1998a
WHO | | 2,3,7,8-TCDD or total TEQs | | | WHO 1998b
HCN | | Health-based exposure limit (2,3,7,8-TCDD or total TEQs) | 1 pg/kg/day | | HCN 1996
[underlined: NATIONAL]
a. | Air:
a. | OSHA | Meets criteria for OSHA medical records (2,3,7,8-TCDD) | Yes | | 29CFR 1910.20; OSHA 1987
a. | EPA OAR | Section 112(b) Hazardous Air Pollutant | Yes | | Clean Air Act Amendments; U.S. Congress 1990
a. | EPA OAR | Standards of Performance for New Stationary Sources | Yes | | 40 CFR 60, Subpart Cb; EPA 1995b
a. | EPA OAR | Emission guidelines an compliance times for municipal waste combustors
a. | EPA OAR | Emissions Guideline for existing sources and standards of performance for new stationary sources: Large municipal waste combustion units; Final rule | Yes | | 62 FR 45124; EPA 1997f
a. | EPA OAR | Municipal waste combustors constructed between December 20, 1989 and September 20, 1994 | Yes | | 40 CFR 60, Subpart Ea; EPA 1995f
a. | EPA OAR | Municipal waste combustors constructed after September 20, 1994 | Yes | | 40 CFR 60, Subpart Eb; EPA 1995d
a. | EPA OAR | Large municipal waste combustion units; emission guidelines; Final rule | Yes | | 62 FR 45116; EPA 1997a
a. | EPA OAR | National Emission Standards for Hazardous Air Pollutants for Source Categories | Yes | | 40 CFR 63, Subpart JJ; EPA 1995e
a. | EPA OAR | Wood Furniture Operations
a. | EPA OAR | Hazardous Waste Combustors; Revised Standards—Final rule | Yes | | 63 FR 33782; EPA 1998i
b. | Water:
b. | EPA OW | Regulated under SDWA of 1986 (2,3,7,8-TCDD) | Yes | | FSTRAC 1990
b. | EPA OW | Guidelines Establishing Test Procedures for the Analysis of Pollutants; EPA Method 1613 | Yes | | 62 FR 48394; EPA 1997g
b. | EPA OW | Maximum Contaminant Level—2,3,7,8-TCDD (Dioxin) | 3.0×10^−8^mg/L | | 40 CFR 141; EPA 1994d
b. | EPA OW | EPA drinking water standard
b. | EPA OW | Variances and exemptions from the maximum contaminant levels for organic and inorganic chemicals—Best available technologies | Treatment technology required is granular activated carbon | | 40 CFR 142.62; EPA 1994e
b. | EPA OW | Permit required for underground injection of 2,3,7,8-TCDD containing wastes designated hazardous under RCRA | Yes | | 40 CFR 144.1; EPA 1983a
b. | EPA OW | Hazardous Waste Injection Restrictions | Yes | | 40 CFR 148.11; EPA 1988h
b. | EPA OW | Waste specific prohibitions; dioxin-containing wastes | | | 40 CFR 148.11; EPA 1988h
b. | EPA OW | Hazardous Waste Injection Restrictions: Treatment Standards for Hazardous Wastes (proposed) (TCDD, PCDD, HCDD) | <1 ppb | | 40 CFR 148; EPA 1993b
b. | EPA OW | General pretreatment regulations for existing and new sources of pollution (2,3,7,8-TCDD) | Yes | | 40 CFR 403.2, App. B; EPA 1986d
b. | EPA OW | Application for an National Pollutant Discharge Elimination System permit (TCDD) | Yes | | 40 CFR 122.21; EPA 1983b
b. | EPA OW | Designated as a toxic pollutant under Section 307(a)(1) of the Federal Water Pollution Control Act and is subject to effluent limitations (2,3,7,8-TCDD) | Yes | | 40 CFR 401.15; EPA 1979c
b. | EPA OW | Electroplating Point Source Category | Yes | | 40 CFR 413.02; EPA 1981a
b. | EPA OW | General definition | | | 40 CFR 413.02; EPA 1981a
b. | EPA OW | Steam Electric Power Generating Point Source Category | Yes | | 40 CFR 423.17; EPA 1982a
b. | EPA OW | Pretreatment standards for new sources (PSNS)
b. | EPA OW | Effluent Limitations Guidelines, Pretreatment Standards, and New Source Performance Standards for the Transportation Equipment Cleaning Point source Category—Proposed rule | Yes | | 63 FR 34686; EPA 1998f
b. | EPA OW | Effluent Limitations Guidelines, Pretreatment Standards, and new source performance Standards for the Industrial Waste Combustor Subcategory of the Waste Combustors Point source Category—Proposed rule | Yes | | 63 FR 6392; EPA 1998g
b. | EPA OW | Effluent Limitations Guidelines, Pretreatment Standards, and New Source Performance Standards for the Landfill Point source Category— Proposed rule | Yes | | 63 FR 6426; EPA 1998h
b. | EPA OW | 2,3,7,8-TCDD Excluded from Subcategory 1 - Organic Pesticide Chemicals Manufacturing Regulations | Yes | | 40 CFR 455; EPA 1978
c. | Food:
c. | EPA | Tolerances and exemptions from tolerances for pesticide chemicals in or on raw agricultural commodities concentration limit of 2,3,7,8-TCDD in technical grade hexachlorophene | 0.1 ppm | | 40 CFR 180.302; EPA 1971b
c. | FDA | Requirements for Specific Standardized Beverages | 3×10^−8^ mg/L | | 21 CFR 165.110; FDA 1995
c. | FDA | Bottled water
c. | FDA | Analysis to determine compliance—Methods for Chemical Analysis of Water and Waste | Method 1613
d. | Other:
d. | DOT | Designated as a hazardous material subject to requirements for packaging, labeling, and transportation (dioxins) | Yes | | 49 CFR 172.101, App. A; DOT 1989b
d. | EPA OERR | Regulated under the MPRSA; ocean dumping prohibited except when in trace amounts (2,3,7,8-TCDD) | Yes | | 40 CFR 227.6; EPA 1977
d. | EPA OERR | Reportable quantity (2,3,7,8-TCDD) | 1 pound | | 40 CFR 302.4; EPA 1985g
d. | EPA OERR | Addition of Dioxin and Dioxin-like Compounds; Toxic Chemical Release Reporting; Community Right-to-Know—Proposed rule | Yes | | 62 FR 24887; EPA 1997c
d. | EPA OPTS | TSCA regulates the use, disposal, and distribution in commerce of process waste water treatment sludges intended for land application from pulp and paper mills employing chlorine or chlorine derivative based bleaching processes (2,3,7,8-TCDD) | Yes | | 40 CFR 744; EPA 1991f
d. | EPA OSW | Identification and Listing of Hazardous Wastes: (F033) Hazardous Wastes from Non-specific Sources (proposed) (TCDD, PCDD, HxCDD, HpCDD, OcCDD) | Yes | | 58 FR 25706; 40 CFR 261.31; EPA 1993c
d. | EPA OSW | Listing as a hazardous constituent (2,3,7,8-TCDD) | Yes | | 40 CFR 261, App. VIII; EPA 1988d
d. | EPA OSW | Hazardous Waste Combustors; Revised Standards—Final rule | Yes | | 63 FR 33782; (40 CFR 262 and 270); EPA 1998i
d. | EPA OSW | Identification and Listing of Hazardous Wastes: Wastes Excluded Under 260.20 and 260.22 (TCDD, PCDD, HxCDD, HpCDD) | Yes | | 40 CFR 261, App. IX; EPA 1984d
d. | EPA OSW | Standards for Owners and Operators of Hazardous Waste Treatment, Storage, and Disposal Facilities | Yes | | 40 CFR 264.343; EPA 1981b
d. | EPA OSW | Performance standards for incinerators
d. | EPA OSW | Groundwater monitoring requirement (dioxins) | Yes | | 40 CFR 264, App. IX; EPA 1987b
d. | EPA OSW | Recyclable Materials Used in a Manner Constituting Disposal | Yes | | 40 CFR 266.23; EPA 1985h
d. | EPA OSW | Standards applicable to users
d. | EPA OSW | Interim status standards for burners | Yes | | 40 CFR 266.103; EPA 1991g
d. | EPA OSW | Standards to control organic emissions, hazardous waste codes F021, F022, F023, F026, and F027 | 99.9999% DRE | | 40 CFR 266.104; EPA 1991h
d. | EPA OSW | Hazardous Waste Burned in Boilers and Industrial Furnaces | Yes | | 40 CFR 266.112; EPA 1985i
d. | EPA OSW | Regulation of residues
d. | EPA OSW | Procedure for Estimating the Toxicity Equivalency of Chlorinated dibenzo-p-dioxin and dibenzofuran congeners | Yes | | 40 CFR 266, App. IX; EPA 1989f
d. | EPA OSW | Land disposal of certain dioxin-containing wastes prohibited (2,3,7,8-TCDD) | Yes | | 40 CFR 268.31; EPA 1988f
d. | EPA OSW | Land Disposal Restrictions | Wastewaters | | 62 FR 25998; EPA 1997d
d. | EPA OSW | Treatment Standards for hazardous waste—waste code F032 | 6.3 × 10^−5^ mg/L or combustion | | 62 FR 25998; EPA 1997d
d. | EPA OSW | | Nonwastewaters | | 62 FR 25998; EPA 1997d
d. | EPA OSW | | 0.001 mg/L or combustion | | 62 FR 25998; EPA 1997d
d. | EPA OSW | Land Disposal Restrictions | Yes | | 40 CFR 268.48; EPA 1991i
d. | EPA OSW | Prohibitions on storage of restricted wastes | Yes | | 40 CFR 268.50; EPA 1986l
d. | EPA OSW | Land Disposal Restrictions: List of Halogenated Organic Compounds Regulated Under 268.32 (PCDD, TCDD, HxCDD) | Yes | | 40 CFR 268, App. III; EPA 1987m
Guidelines:
a. | Air:
a. | NIOSH | C_a_ = Potential Human Carcinogen | Carcinogen; lowest feasible concentrations | | NIOSH 1997
b. | Water:
b. | EPA ODW
b. | EPA ODW | MCLG in drinking water (2,3,7,8-TCDD) | Zero | | EPA 1995a
b. | EPA ODW | Health Advisories (2,3,7,8-TCDD): | | | EPA 1996a
b. | EPA ODW | 1-day (child) | 1.0×10^−6^ mg/L (1.0×10^−3^ µg/L)
b. | EPA ODW | 10-day (child) | 1.0×10^−7^ mg/L (10×10^−4^ µg/L)
b. | EPA ODW | Longer term (child) | 1.0×10^−8^ mg/L (1.0×10^−5^ µg/L)
b. | EPA ODW | Longer term (adult) | 4.0×10^−8^ mg/L (4.0×10^−5^ µg/L)
b. | EPA ODW | 10^−4^ Cancer risk level | 2.0×10^−8^ mg/L (2.0×10^−5^ µg/L)
b. | EPA OW | Ambient Water Quality Criteria for Protection of Human Health: | | | EPA 1984a
b. | EPA OW | Ingesting water and organisms (2,3,7,8-TCDD):
b. | EPA OW | 10^−5^ | 1.3×10^−7^ µg/L
b. | EPA OW | 10^−6^ | 1.3×10^−8^ µg/L
b. | EPA OW | 10^−7^ | 1.3×10^−9^ µg/L
b. | EPA OW | Ingesting organisms only (2,3,7,8-TCDD):
b. | EPA OW | 10^−5^ | 1.4×10^−7^ µg/L
b. | EPA OW | 10^−6^ | 1.4×10^−8^ µg/L
b. | EPA OW | 10^−7^ | 1.4×10^−9^ µg/L
b. | NAS | ADI (2,3,7,8-TCDD) | 10^−4^ µg/kg/day | | NAS 1977
c. | Food:
c. | FDA | Levels in fish (2,3,7,8-TCDD): | | | EPA 1985d
c. | FDA | No serious health effects | <25 ppt
c. | FDA | Fish should not be consumed | >50 ppt
d. | Other:
d. | EPA | RfD (oral) | Not Determined | | IRIS 1998
d. | EPA | Carcinogen classification (HxCDD) | B2^c^ | | EPA 1996a
d. | EPA | Unit risk (air) (HxCDD) | 1.3 µg/m^3^ | | IRIS 1998
d. | EPA | Unit risk (water) (HxCDD)^b^ | 1.8×10^−1^ (µg/L)^−1^
d. | NTP | Cancer Classification—Reasonably anticipated to be a human carcinogen | Limited evidence in humans; sufficient evidence in animals | | NTP 1998
d. | FDA | Risk-specific dose | 0.057 pg/kg/day | | FDA 1990
d. | DHHS | Risk-specific dose for total TEQs | 0.057 pg/kg/day | | PHS 1992
[underlined: STATE]
Regulations and Guidelines:
a. | Air: | Acceptable Ambient Air Concentrations | | | NATICH 1992
a. | AZ | (1 hour) (2,3,7,8-TCDD) | 4.2×10^−2^µg/m^3^
a. | AZ | (24 hour) (2,3,7,8-TCDD) | 1.1×10^−2^µg/m^3^
a. | AZ | (Annual) (2,3,7,8-TCDD) | 3.0×10^−5^µg/m^3^
a. | FL - Pinella | (Annual) (2,3,7,8-TCDD) | 2.2×10^−8^µg/m^3^
a. | IN | (Annual) (2,3,7,8-TCDD) | 3.0×10^−8^µg/m^3^
a. | KS | (1 year) (2,3,7,8-TCDD) | 3.03×10^−8^µg/m^3^
a. | ME | (24 hour) (2,3,7,8-TCDD) | 3.5×10^−6^µg/m^3^
a. | ME | (Annual) (2,3,7,8-TCDD) | 2.5×10^−7^µg/m^3^
a. | MI | (Annual) (2,3,7,8-TCDD) | 2.3×10^−8^µg/m^3^
a. | NC | (Annual) (2,3,7,8-TCDD) | 3.01×10^−6^µg/m^3^
a. | NC - Forco | (Annual) (2,3,7,8-TCDD) | 8.00×10^−6^µg/m^3^
a. | ND | (2,3,7,8-TCDD) (avg. time NA) | 4.5×10^−1^µg/m^3^
a. | PA - Phil | (1 year) (2,3,7,8-TCDD) | 1.00×10^−4^µg/m^3^
a. | PA - Phil | (Annual) (2,3,7,8-TCDD) | 3.50×1^−5^µg/m^3^
a. | VA | (24 hour) (2,3,7,8-TCDD) | 3.00 µg/m^3^
a. | VT | (Annual) (dioxins) | 2.00×10^−2^µg/m^3^
a. | KY | Significant emission levels of toxic air pollutants (2,3,7,8-TCDD) | 5.1×10^−7^ pounds/hour | | 401 KAR 63:022; NREPC 1986
a. | WA-SW | (Annual) (2,3,7,8-TCDD) | 3.0×10^−8^µg/m^3^ | | NATICH 1992
a. | WI | Hazardous air contaminants without acceptable ambient concentrations (2,3,7,8-TCDD) | .0001 pounds/year | | WAC 1988
b. | Water:
b. | CA | Water Quality Standards; Establishment of Numeric Criteria for Priority Toxic Pollutants for the State of California—Porposed rulex | Yes | | 62 FR 42160; EPA 1997
b. | FL | Drinking water monitoring for unregulated contaminants (2,3,7,8-TCDD) | Yes | | CELDS 1994
b. | KS | Applied action levels for groundwater (2,3,7,8-TCDD) | 2 pg/L | | KBWP 1988
b. | KS | Drinking Water Quality Guidelines and Standards (2,3,7,8-TCDD) | 2.2×10^−6^µg/L | | FSTRAC 1990
b. | ME | Drinking Water Quality Guidelines and Standards (2,3,7,8-TCDD) | 2.2×10^−6^µg/L | | FSTRAC 1990
b. | MO | Surface water criterion (2,3,7,8-TCDD): | | | 10 CSR 20-7.031; MDNR 1987
b. | MO | Aquatic life | 0.014 pg/L | | 10 CSR 20-7.031; MDNR 1987
b. | MO | Drinking water supplies | 0.130 pg/L | | 10 CSR 20-7.031; MDNR 1987
b. | MN | Recommended allowable limits (proposed) (2,3,7,8-2,3,7,8-TCDD) | 20 pg/L | | MWQS 1988a
b. | MN | Chronic criteria (proposed) (2,3,7,8-TCDD): | | | MWQS 1988b
b. | MN | Groundwater | 2 pg/L
b. | MN | Surface water | 0.002 pg/L
b. | NH | Drinking Water Guideline | 2×10^−7^µg/L | | FSTRAC 1990
b. | NY | Ambient water quality standard aquatic life (2,3,7,8-TCDD) | 1 pg/L | | NYWQSGV1987; NYPDWS 1989
b. | NY | Maximum concentration level in drinking water (2,3,7,8-TCDD) | 5 µg/L
b. | NY | Water quality standard (2,3,7,8-TCDD) | 1 pg/L
b. | RI | Drinking Water Guideline | 2×10^−7^µg/L | | FSTRAC 1990
b. | SD | Maximum allowable concentrations in ground water (2,3,7,8-TCDD) | 0 | | SDGWQS 1989
b. | VT | Groundwater protection regulations (2,3,7,8-TCDD): | | | VANR 1988
b. | VT | Preventive action limit | 2×2^−8^µg/L
b. | VT | Enforcement standard | 2×2^−7^µg/L
b. | WI | Human cancer criteria (2,3,7,8-TCDD): | | | WDNR 1987
b. | WI | Public water supply:
b. | WI | Warm water sport fish communities | 0.097 pg/L; 0.03 pg/L; 0.03 pg/L
b. | WI | Cold water communities | 0.1 pg/L
b. | WI | Great Lakes communities | 0.03 pg/L; 450 pg/L
b. | WI | Non-water supply:
b. | WI | Warm water sport communities
b. | WI | Cold water communities
b. | WI | Warm water forage and limited forage fish communities and limited aquatic life
b. | WI | [underlined: Water Quality Criteria: Human Health]
b. | AZ | Domestic Water Source | 2×10^−7^µg/L | | CELDS 1994
b. | AZ | Fish Consumption | 4×10^−9^µg/L
b. | AZ | Fullbody contact | 9×10^−6^µg/L
b. | CT | Consumption of Organisms | 1.4×10^−9^µg/L
b. | CT | Consumption of Water and Organisms | 1.3×10^−9^µg/L
b. | CT | Health Designation | C-HB^d^
b. | DE | Freshwater Fish Ingestion | 1.7×10^−6^ ng/L
b. | DE | Freshwater Fish and Water Ingestion | 1.6×10^−6^ ng/L
b. | DE | Marine/Estuarine Fish/Shellfish Ingestion | 2.4×10^−7^ ng/L
b. | DE | Human Health Concern (carcinogen) | CA
b. | IN | Continuous Criterion Concentration (4-d avg.)
b. | IN | Outside mixing zone | 1×10^−7^µg/L
b. | IN | Point of water intake | 1×10^−7^µg/L
b. | KY | Fish Consumption | 1.4×10^−9^µg/L
b. | KY | Domestic Water Supply | 1.3×10^−9^µg/L
b. | MO | Fish Consumption | 1.4×10^−6^ng/L
b. | MO | Drinking Water Supply | 1.3×10^−6^ng/L
b. | MO | Groundwater | 1.3×10^−6^ng/L
b. | NY | Groundwater | 3.5×10^−6^µg/L
b. | OH | Outside Mixing Zone (30-d avg.) | 0.14 pg/L
b. | OR | Water and Fish Ingestion | 1.3×10^−6^ng/L
b. | OR | Fish Ingestion | 1.4×0^−6^ng/L
b. | SD | Domestic Water Supply | 1.3×10^−9^µg/L
b. | SD | All Others | 1.4×10^−9^µg/L
b. | VT | Class A or B Waters | 1.3×10^−6^ng/L
b. | VT | Class C Waters | 1.4×10^−6^ng/L
b. | WI | Public Water Supplies
b. | WI | Warm Water | 0.097 pg/L
b. | WI | Cold Water | 0.03 pg/L
b. | WI | Great Lakes | 0.03 pg/L
b. | WI | Non-public Water Supplies
b. | WI | Warm Water Sport | 0.1 pg/L
b. | WI | Cold Water Forage | 0.3 pg/L
b. | WI | Groundwater | 450 pg/L
b. | WI | Groundwater | 2.2×10^−8^µg/L
b. | WI | [underlined: Water Quality Criteria: Aquatic Life]
b. | AZ | Acute-Cold Water Fishery | 0.01 µg/L | | CELDS 1994
b. | AZ | Acute-Warm Water Fishery | 0.01 µg/L
b. | AZ | Acute-Effluent Dominated Water | 0.12 µg/L
b. | AZ | Acute-Ephemeral | 0.1 µg/L
b. | AZ | Chronic-Coldwater Fishery | 0.005 µg/L
b. | AZ | Chronic-Warm Water Fishery | 0.005 µg/L
b. | AZ | Chronic-Effluent Dominated Water | 0.01 µg/L
b. | AZ | Chronic-Ephemeral | 0.01 µg/L
b. | HI | Acute-Freshwater | 0.03 µg/L
b. | HI | Fish Consumption | 5×10^−9^µg/L
b. | OR | Acute-Freshwater | 0.01 µg/L
b. | OR | Chronic-Freshwater | 38 pg/L
b. | OR | [underlined: Water Quality Criteria: Recreational Use]
b. | TN | | 1×10^−6^ng/L
b. | TN | [underlined: Groundwater Monitoring]
b. | IL | | Yes | | CELDS 1994
b. | LA | | Yes
b. | MN | | Yes
b. | WV | | Yes
b. | WI | | Yes
b. | | Fish and Wildlife Advisories | Number of Advisories Issued for 1997
b. | | | Fish | Wildlife
b. | AR | Freshwater | 1 | 1 (wood duck) | EPA 1998b
b. | CA | Saltwater | 1
b. | DE | Freshwater | 1
b. | FL | Freshwater | 1
b. | LA | Freshwater | 2
b. | MA | Freshwater | 1
b. | ME | Freshwater and saltwater (statewide) | 8 | | EPA 1998a; EPA 1998b
b. | Ml | Freshwater | 8 | | EPA 1998b
b. | MS | Freshwater | 1
b. | NC | Freshwater and Saltwater | 5
b. | NH | Freshwater | 1
b. | NJ | Freshwater and Saltwater (statewide) | 9 | | EPA 1998a; EPA 1998b
b. | NY | Freshwater and Saltwater (statewide) | 10 | | EPA 1998a; EPA 1998b
b. | OR | Freshwater | 1 | | EPA 1998b
b. | RI | Freshwater | 1
b. | TN | Freshwater | 1
b. | TX | Saltwater | 1
b. | VA | Freshwater | 2
b. | WA | Freshwater and Saltwater | 2
b. | WI | Freshwater | 2
b. | WV | Freshwater | 6
c. | Food:
c. | WI | Health standards for contaminants commonly found in sport fish (2,3,7,8-TCDD) | 50 ppt | | WAC 1988
d. | Other:
d. | | [underlined: Hazardous Constituent]
d. | CA | Total Threshold Limit Concentration | 1 mg/kg | | CELDS 1994
d. | CA | Toxic Materials Limits (30-d avg.) | 0.0039 pg/L
d. | CO | | Yes
d. | IL | | Yes
d. | KY | Defined as hazardous waste constituent (dioxins) | Yes | | 401 KAR 31:160; NREPC 1988
d. | KY | Dioxin-containing wastes are prohibited from land disposal (dioxins) | Yes | | 401 KAR 37:030; NREPC 1988
d. | KY | Treatment standards; constituent concentration in waste extract (dioxins) | <1 ppb | | 401 KAR 37:040; NREPC 1988
d. | LA | | Yes | | CELDS 1994
d. | MA | | Yes
d. | MN | | Yes
d. | ND | | Yes
d. | WV | | Yes
d. | WI | | Yes
d. | | [underlined: Groundwater Effluent Standards]
d. | NY | | 3.5×10^−6^µg/L | | CELDS 1994

a Group 1: carcinogenic to humans

b Because of its carcinogenic potential the EPA-recommended concentration for dioxins in ambient water is zero. However, because attainment of this level may not be possible, levels that correspond to upper-bound incremental lifetime cancer risks of 10^−5^,10^−6^, and 10^−7^ are estimated.

c Group B2: probable human carcinogens

d C: Carcinogenic (probable or possible); HB: high potential to bioaccumulate or bioconcentrate

ADI = Acceptable Daily Intake; CELDS = Computer-environment legislative data systems database. CDDs = chlorinated dibenzo-p-dioxins; DOT = Department of Transportation; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FR = Federal Register; HCN = Health Council of the Netherlands; HxCDD = Hexachlorodibenzo-p-dioxin; IARC = International Agency for Research on Cancer; KBWP = Kansas Bureau of Water Protection; MCL = Maximum Contaminant Level; MCLG = Maximum Contaminant Level Goal; MDNT = Missouri Department of Natural Resources; MPRSA = Marine Protection Research and Sanctuaries Act; MWQS = Minnesota Water Quality Standards; NAS = National Academy of Sciences; NATICH = National Air Toxics Information Clearinghouse; NIOSH = National Institute of Occupational Safety and Health; NREPC = National Resources and Environmental Protection Cabinet; NYPDWS = New York Public Drinking Water Standards; NYWQSGV = New York Water Ambient Quality Ambient Standards and Guidance Values; OAR = Office of Air and Radiation; OCDD = octachlorodibenzo-[underlined: p]-dioxin; ODW = Office of Drinking Water; OERR = Office of Emergency and Remedial Response; OPP = Office of Pesticide Programs; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Wastes; OPTS = Office of Pesticides and Toxic Substances; OW = Office of Water; Penta-CDD = Pentachlorodibenzo-p-dioxin; RCRA = Resource Conservation and Recovery Act; RfD = Reference Dose; SDGWQS = South Dakota Ground-Water Quality Standards; SDWA = Safe Drinking Water Act; TEQ = TCDD = 2,3,7,8-tetrachlorodibenzo-[underlined: p]-dioxin; TDI = Tolerable Daily Intake; TSCA = Toxic Substance Control Act; VANR = Vermont Agency of Natural Resources; WAC = Wisconsin Administrative Code; WDNR = Wisconsin Department of Natural Resources; WHO = World Health Organization