# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur. MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

## 2,3,7,8-Tetrachlorodibenzo-p-dioxin (2,3,7,8-TCDD) Acute Oral

MRL WORKSHEET

Chemical Name: | 2,3,7,8-Tetrachlorodibenzo-p-dioxin (2,3,7,8-TCDD)
CAS Number: | 1746-01-6
Date: | December 10, 1998
Profile Status: | Final Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [X ] Acute [ ] Intermediate [] Chronic
Key to Figure: | 78m
Species: | Mice

[underlined: Minimal Risk Level]: 0.0002 (2×10^−4^) [X] µg/kg/day [ ] ppm

[underlined: Reference]: Burleson et al. 1996

[underlined: Experimental design:] (human study details or strain, number of animals per exposure/control groups, sex, dose administration details):

Groups of 20 female B6C3F1 mice were administered a single gavage dose of 0, 0.001, 0.005, 0.01, 0.05, or 0.1 µg/kg 2,3,7,8-TCDD in corn oil. Seven days after 2,3,7,8-TCDD exposure, the mice were infected intranasally with influenza A/Hong Kong/8/68 (H3N2) virus diluted at 10^−48^, 10^−50^, 10^−52^, or 10^−54^. In a separate experiment, groups of 18 female mice received a single gavage dose of 0, 0.001, 0.01, or 0.1 µg/kg 2,3,7,8-TCDD and were infected 7 days later with influenza A virus at a dose not known to cause mortality (10^−54^ and 10^−58^) or were sham-infected. Body weight, thymus weight, and wet lung weights were measured 3, 9, or 12 days postinfection. Pulmonary virus titers were determined in groups of 72 mice exposed to 0, 0.001, 0.01, or 0.01 µg/kg 2,3,7,8-TCDD and infected with influenza A virus seven days later. For the virus titer study, groups mice were killed 2 hours, 1, 4, 6, 7, 8, 9, 10, and 11 days post-infection.

[underlined: Effects noted in study and corresponding doses]:

Statistically significant increases in mortality were observed in the influenza A infected mice exposed to 0.01, 0.05, or 0.1 µg/kg 2,3,7,8-TCDD. However, no between group differences in mortality were observed at these 2,3,7,8-TCDD dosages. Mortality in mice receiving 0.001 or 0.005 µg/kg did not significantly differ from the mortality in the control group. Exposure to 2,3,7,8-TCDD did not enhance the increase in relative lung weight normally seen in mice infected with influenza A virus. As compared to controls, no significant alterations in thymus weights were observed in 2,3,7,8-TCDD-exposed mice sham-infected or those infected with influenza A virus. 2,3,7,8-TCDD exposure did not result in a significant increase in viral titers in the lung, as compared to titers from the control group. The authors noted that the lack of dose-response in mortality and the lack of effect on the relative lung weight, thymus weight, and viral titers suggest that 2,3,7,8-TCDD may be exerting an effect via an indirect mechanism such as through an effect on cytokines.

[underlined: Dose and end point used for MRL derivation]: Impaired resistance to influenza A virus infection, as evidence by the significant increase in mortality, was observed in female B6C3F_1_ mice administered a single gavage dose of ≥0.01 µg/kg. No significant effects were observed at lower doses. Thus, 0.005 and 0.01 µg/kg are the NOAEL and LOAEL, respectively, for impaired resistance.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans- A comparison of species sensitivity suggests that even though there are wide ranges of sensitivity for some 2,3,7,8-TCDD-induced health effects, for most health effects, the LOAELs for the majority of animal species cluster within an order of magnitude. Based on the weight of evidence of animal species comparisons and human and animal mechanistic data, it is reasonable to assume that human sensitivity would fall within the range of animal sensitivity.
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

No. A modifying factor of 0.7 was applied to adjust for the difference in higher bioavailability of 2,3,7,8-TCDD from gavage with an oil vehicle than from food. Support for this modifying factor comes from toxicokinetic studies in Sprague Dawley rats. In rats fed 0.35 or 1 µg/kg/day 2,3,7,8-TCDD in the diet for 42 days, approximately 60% of the administered dose was absorbed (Fries and Marrow 1975). In contrast, 70-84% of a single or repeated gavage dose of 0.01-50 µg/kg 2,3,7,8-TCDD in corn oil was absorbed in rats (Piper et al. 1973; Rose et al. 1976). Thus, the ratio of 2,3,7,8-TCDD absorption from the diet to gavage with an oil vehicle is 0.71-0.85.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

NA

[underlined: Was a conversion used from intermittent to continuous exposure?]

No

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

2,3,7,8-TCDD is a known immunosuppressant in animals in acute-, intermediate, and chronic-duration studies (Kerkvliet 1995). Suppression of the antibody response to sheep erythrocytes was observed in B6C3F1 mice administered 14 daily doses of 0.1 µg 2,3,7,8-TCDD/kg/day (Holsapple et al. 1986), and a significant increase in mortality was observed in B6C3F_1_ mice administered 1.0 µg/kg/day 2,3,7,8-TCDD for 14 days and challenged with Streptococcus pneumoniae (White et al. 1986). Decreased survival after viral infection was also reported in female B6C3F1 mice after a single intraperitoneal dose of 0.1 µg 2,3,7,8-TCDD/kg (House et al. 1990). A significant suppression of complement hemolytic activity was observed in mice administered 0.01 µg/kg/day via gavage for 14 days (White et al. 1986). Furthermore, 2,3,7,8-TCDD alters the immune system of offspring when exposed through lactation and/or in utero. For example, a dose-related decrease in relative thymus weights were seen in offspring of rats dosed at levels of 0.005-0.35 µg 2,3,7,8-TCDD/kg on day 16 of pregnancy (Madsen and Larsen 1979).

[underlined: Agency Contact (Chemical Manager):] Hana Pohl

## 2,3,7,8-Tetrachlorodibenzo-p-dioxin (2,3,7,8-TCDD) Intermediate Oral

MRL WORKSHEET

Chemical Name: | 2,3,7,8-Tetrachlorodibenzo-p-dioxin (2,3,7,8-TCDD)
CAS Number: | 1746-01-6
Date: | December 10, 1998
Profile Status: | Final Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X ] Intermediate [] Chronic
Key to Figure: | 187g
Species: | Guinea pig

[underlined: Minimal Risk Level]: 0.00002 (2×10^−5^) [X] µg/kg/day [ ] ppm

[underlined: Reference]: DeCaprio et al. 1986

[underlined: Experimental design:] (human study details or strain, number of animals per exposure/control groups, sex, dose administration details):

Groups of weanling Hartley guinea pigs (10/sex) were administered a diet containing 2, 10, 76 or 430 ppt for 90 days. These diets provided an average of 0.0001, 0.0007, 0.005, or 0.028 µg 2,3,7,8-TCDD/kg/day. The average doses were estimated by the investigators. A group of control guinea pigs was fed a diet without added 2,3,7,8-TCDD. Body weights and food consumption were monitored throughout the experiment. At the end of the dosing period the animals were sacrificed and clinical chemistries, hematology, organ weights and histopathology examinations were performed. The recovery following treatment was studied in groups of 10 guinea pigs fed a diet containing 430 ppt 2,3,7,8-TCDD for 11, 21, or 35 days and allowed to recover for 79, 69, or 55 additional days, respectively.

[underlined: Effects noted in study and corresponding doses]:

The highest dietary level of 2,3,7,8-TCDD caused net body weight loss and mortality. Four males and four females died and additional animals had to be sacrificed due to poor health. Food consumption was significantly reduced in the highest dose group only. Body weight gain in the 0.0007 and 0.005 µg/kg/day male groups was reduced by 9% and 20%, respectively. In the corresponding female groups, body weight gain was reduced by 6% and 15%. Gross lesions were observed only in the highest dose group and included thymic atrophy, depletion of body fat, and liver enlargement. Significant changes in organ weights included a decrease in absolute kidney weight and in absolute and relative thymus weight in males dosed with 0.005 µg/kg/day, increase in relative liver weight in males and females at the 0.005 µg/kg/day level, and increase in relative brain weight in males at this same dose level. Organ weights from high dose animals were not monitored. Administration of 2,3,7,8-TCDD did not cause any significant hematological effect (blood was not collected from the highest dose group). In the 0.005 µg/kg/day groups, serum ALT was significantly reduced in females whereas triglycerides were elevated in males. No other significant changes in clinical chemistries were observed. Treatment-related histological alterations were observed only in the two higher dose groups and consisted of hepatocellular cytoplasmic inclusion bodies and atrophy of the thymic cortex. In the recovery study there was 10% mortality in the groups treated for 11 and 21 days and 70% mortality in the group treated for 35 days. Surviving animals in all groups exhibited significantly reduced body weight gain.

[underlined: Dose and end point used for MRL derivation]: The dose of 0.0007 µg/kg/day represents a NOAEL for decreased thymus weight, whereas the 0.005 µg/kg/day is a LOAEL.

[X ] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans-A comparison of species sensitivity suggests that even though there are wide ranges of sensitivity for some 2,3,7,8-TCDD-induced health effects, for most health effects, the LOAELs for the majority of animal species cluster within an order of magnitude. Based on the weight of evidence of animal species comparisons and human and animal mechanistic data, it is reasonable to assume that human sensitivity would fall within the range of animal sensitivity.
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

No. The doses were estimated by the investigators.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

NA

[underlined: Was a conversion used from intermittent to continuous exposure?]

No

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

2,3,7,8-TCDD is a known immunosuppressant in animals in acute-, intermediate, and chronic-duration studies (Kerkvliet 1995). Reduction of thymus weight was also observed in intermediate-duration oral studies in rats (Van Birgelen et al. 1995; Viluksela et al. 1994). Another sensitive species for immunological effects of 2,3,7,8-TCDD is the marmoset monkey in which alterations in lymphocyte subsets have been reported after subcutaneous application of an average 0.0015 µg 2,3,7,8-TCDD/kg/day for 26 weeks (Neubert et al. 1992). Furthermore, 2,3,7,8-TCDD alters the immune system of offspring when exposed through lactation and/or in utero. For example, a dose-related decrease in relative thymus weights were seen in offspring of rats dosed at levels of 0.005-0.35 µg 2,3,7,8-TCDD/kg on day 16 of pregnancy (Madsen and Larsen 1979).

[underlined: Agency Contact (Chemical Manager):] Hana Pohl

## 2,3,7,8-Tetrachlorodibenzo-p-dioxin (2,3,7,8-TCDD) Chronic Oral

MRL WORKSHEET

Chemical Name: | 2,3,7,8-Tetrachlorodibenzo-p-dioxin (2,3,7,8-TCDD)
CAS Number: | 1746-01-6
Date: | December 10, 1998
Profile Status: | Final Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Key to Figure: | 226k
Species: | Monkey

[underlined: Minimal Risk Level]: 0.000001 (1×10^−6^) [X] µg/kg/day [ ] ppm

[underlined: Reference]: Schantz et al. 1992

[underlined: Experimental design:] (human study details or strain, number of animals per exposure/control groups, sex, dose administration details):

Groups of 8 female rhesus monkeys were fed a diet containing 0, 5, or 25 ppt 2,3,7,8-TCDD for a total of 16.2 ± 0.4 months. After 7 months of exposure, the monkeys were mated with unexposed males. (Only 1 monkey in the 25 ppt group delivered a viable offspring; this offspring was not studied behaviorally). The monkeys were fed the 2,3,7,8-TCDD diet throughout the mating period, gestation, and lactation. The authors estimated that the total 2,3,7,8-TCDD intake over the course of the study was 59.6 ± 5.0 ng/kg for the 5 ppt group. The offspring were weaned at 4 months and individually housed. Mesenteric fat samples were collected from the offspring at age 5 months; the average 2,3,7,8-TCDD levels in the fat samples was 377 ±141 ppt (range of 290-950) for the 5 ppt group and below the detection limit of 2-200 ppt for the controls. When the offspring were 8.6 months of age, they were placed in peer groups of 4 monkeys and allowed to play for 1.5 hours without interference. The peer groups consisted of two 2,3,7,8-TCDD-exposed monkeys and two control monkeys. Behavioral patterns (social interactions and other behaviors such as vocalization, locomotion, self-directed behavior and environmental exploration) were monitored 4 days/week for 9 weeks.

[underlined: Effects noted in study and corresponding doses]:

No overt signs of toxicity were observed in the mothers or offspring, and birth weights and growth were not adversely affected by 2,3,7,8-TCDD exposure. Significant alterations were observed in play behavior, displacement, and self-directed behavior in the 2,3,7,8-TCDD -exposed offspring. 2,3,7,8-TCDD-exposed monkeys tended to initiate more rough-tumble play bouts and retreated less from play bouts than controls, were less often displaced from preferred positions in the playroom than the controls, and engaged in more self-directed behavior than controls. No other significant alterations in behavior were observed.

[underlined: Dose and end point used for MRL derivation]:

Although the mothers were exposed to 5 or 25 ppt 2,3,7,8-TCDD, only the offspring from the 5 ppt group underwent behavioral testing. The 5 ppt dietary concentration is equivalent to a daily dose of 1.2 × 10^−4^ µg/kg/day. This dose is a LOAEL for altered social behavior.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [X] 3 for extrapolation from animals to humans A comparison of species sensitivity suggests that even though there are wide ranges of sensitivity for some 2,3,7,8-TCDD-induced health effects, for most health effects, the LOAELs for the majority of animal species cluster within an order of magnitude. Based on the weight of evidence of animal species comparisons and human and animal mechanistic data, it is reasonable to assume that human sensitivity would fall within the range of animal sensitivity.
- [X] 10 for human variability.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

Monkeys were exposed to a dietary concentration of 5 ppt 2,3,7,8-TCDD; the authors estimated that the total maternal intake during the 16.2 months of exposure (492 days) was 59.6 ng/kg.

Daily dose = (59.6 ng/kg) / (492 days) = 0.12 ng/kg/day (1.2 × 10^−4^ µg/kg/day)

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

NA

[underlined: Was a conversion used from intermittent to continuous exposure?]

No

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

A behavioral teratology test battery was performed in monkey infants exposed to 2,3,7,8-TCDD during gestation and lactation; the results of this test battery was published in a series of papers (Bowman et al. 1989a; Schantz and Bowman 1989; Schantz et al. 1992). No significant alterations in reflex development, visual exploration, locomotor activity, or fine motor control were found (Bowman et al. 1989a). In tests of cognitive function, object learning was significantly impaired, but no effect on spatial learning was observed (Schantz and Bowman 1989). When the monkey infants were placed in social groups, altered social behavior was observed (Bowman et al. 1989a; Schantz et al. 1992). Additional data on the neurodevelopmental toxicity of 2,3,7,8-TCDD are limited to a study in which prenatal exposure to 2,3,7,8-TCDD resulted in masculinized behavior in female rats (Schantz et al. 1991). No chronic duration animal neurotoxicity studies were located, decreased motor activity was reported in rats acutely exposed to 2 (Giavini et al. 1983) or 5 (Seefeld et al. 1984a) µg/kg/day. The Schantz and Bowman studies are the only available chronic developmental toxicity studies. Acute and intermediate duration studies provide evidence that 2,3,7,8-TCDD is a potent developmental toxicant. Other sensitive developmental effects that have been observed included cleft palate [lowest LOAEL- 0.1 µg/kg/day (Giavini et al. 1982)], hydronephrosis [lowest LOAEL- 1 µg/kg (Moore et al. 1973)], immunosuppression [lowest LOAEL-0.005 µg/kg (Madsen and Larsen 1979)], impaired development of the reproductive system [lowest LOAEL- 0.064 µg/kg (Mably et al. 1992a, 1992b, 1992c)], and increased newborn mortality [lowest LOAEL-0.7 µg/kg (Bjerke et al. 1994a)]; NOAELs were not identified for these effects in the most sensitive species or strain.

Some human studies have reported effects on the central and peripheral nervous systems shortly after exposure to high levels of 2,3,7,8-TCDD (Filippini et al. 1981; Moses et al. 1984; Pazderova-Vejlupkova et al. 1981; Pocchiari et al. 1979; Suskind 1977). However, follow-up studies did not find neurological effects years after exposure termination (Barbieri et al. 1988), suggesting that the effects may be transient. No human studies examined the effect of 2,3,7,8-TCDD on the developing neurologic system.

It should be also noted that 10 years after termination of 2,3,7,8-TCDD exposure in the Schantz et al. (1992) study, Rier et al. (1993) reported a dose-related increase in the incidence and severity of endometriosis in these same rhesus monkeys. Rier et al. (1993) identified a less serious LOAEL of 5 ppt (0.00012 µg/kg/day) for moderate endometriosis. However, monkeys appear to be more susceptible to endometriosis, based on a background incidence of endometriosis in monkeys of 30% (Rier et al. 1993) compared to a background incidence of 10% in humans (Wheeler et al. 1992). Thus, derivation of a chronic oral MRL based on endometriosis would necessitate using an uncertainty factor of less than 1 (or at most, 1) to account for the increased sensitivity of monkeys to endometriosis as compared to humans. If the Rier et al. (1993) study was used to calculate an oral MRL, the LOAEL of 0.00012 µg/kg/day would be divided by an uncertainty factor of 100 (10 to extrapolate from a LOAEL, 10 for human variability and 1 for interspecies differences). This would result in a computed MRL essentially the same as the chronic oral MRL of 1 pg/kg/day based on developmental toxicity as described in the preceding paragraph. Moreover, (1) the clinical history for these rhesus monkeys during the 10 year period between the Schantz et al. (1992) study and examination by Rier et al. (1993) is unknown (not reported); (2) Boyd et al. (1995) did not find an association between exposure to CDDs, CDFs, or PCBs and endometriosis in a clinical study in women; and (3) the EPA (1997) concluded that “the evidence for supporting the hypothesis that CDDs and PCBs are causally related to human endometriosis via an endocrine-disruption mechanism is very weak.” So, even though there is information to indicate that endometriosis may also be a sensitive toxicological end point for 2,3,7,8-TCDD exposure, the developmental end point (altered social behavior) reported in the Schantz et al. (1992) study was determined to be the most appropriate end point for derivation of an MRL for chronic oral 2,3,7,8-TCDD exposure.

[underlined: Agency Contact (Chemical Manager):] Hana Pohl