# CHAPTER 8 REFERENCES

*Cited in text

*ACGIH. 1991. Threshold limit values and biological exposure indices for 1988-1989. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 14.
*ACGIH. 2001. Chlordane. Documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists. July 26, 2017.
*ACGIH. 2016. Chlordane. TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists. July 26, 2017.
*Adeshina F. 1989. Organochlorine compounds in human adipose tissue and carcinogenic risk: A case study of chlordane/heptachlor. Diss Abstr Int 49:5207B.
*Adeshina F, Todd EL. 1990. Organochlorine compounds in human adipose tissue from north Texas. J Toxicol Environ Health 29:147–156.1688952
*Ahmed FE, Hart RW, Lewis NJ. 1977a. Pesticide induced DNA damage and its repair in cultured human cells. Mutat Res 42:161–174.190533
*Ahmed FE Lewis NJ, Hart RW. 1977b. Pesticide induced ouabain resistant mutants in Chinese hamster V-+9 cells. Chem Biol Interact 19:369–374.413633
*AIHA. 2015. Current ERPG Values (2015). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2015%20ERPG%20Levels.pdf. March 22, 2016.
*Al-Hachim GM, Al-Baker A. 1973. Effects of chlordane on conditioned avoidance response, brain seizure threshold and open-field performance of prenatally-treated mice. Br J Pharmacol 49:311–315.4793333
*Albers PH, Sileo L, Mulhem BM. 1986. Effects of environmental contaminants on snapping turtles of a tidal wetland. Arch Environ Contam Toxicol 15:39–49.
*Albrecht R, Manchon P. 1974. Environmental influence on the metabolism of exogenic materials in liver microsomes. Ann Nutr Aliment 28:351–363.4157001
Albright L, Oloffs PC, Szeto SY. 1972. Fate and behavior of five chlorinated hydrocarbons in three natural waters. Can J Microbiol 18:1393–1398.4116057
*Aldrich FD, Holmes JH. 1969. Acute chlordane intoxication in a child: Case report with toxicological data. Environ Health 19:129–132.
*Alford-Stevens AL, Eichelberger JW, Budde WL. 1988. Multi-laboratory study of automated determinations of polychlorinated biphenyls and chlorinated pesticides in water, soil, and sediment by gas chromatography/mass spectrometry. Environ Sci Technol 22:304–312.22288865
*Al-Omar MA, Abbas AK, Al-Obaidy SA. 2000. Combined effect of exposure to lead and chlordane on the testicular tissues of swiss mice. Toxicol Lett 115(1):1–8.10817625
*Alvarez, WC, Hyman S. 1953. Absence of toxic manifestations in workers exposed to chlordane. Arch Ind Hyg Occup Med 8:480–483.
*Ambrose AM, Christenson HC, Robbins DJ, . 1953a. Toxicological and pharmacological studies on chlordane. Arch Ind Hyg Occup Med 7:197–210.
*Ambrose AM, Christenson HC, Robbins DJ. 1953b. Pharmacological observations on chlordane [Abstract]. Fed Am Soc Exp Biol 12:298.
*Anderson DJ, Hites RA. 1988. Chlorinated pesticides in indoor air. Environ Sci Technol 22:717–720.
*Anderson DJ, Hites RA. 1989. Indoor air: Spatial variations of chlorinated pesticides. Atmos Environ 23:2063–2066.
*Anderson JF, Wojtas MA. 1986. Honey bees (Hymenoptera: Apidae) contaminated with pesticides and polychlorinated biphenyls. J Econ Entomol 79:1200–1205.
*Anonymous. 1988. Chlordane. Rev Environ Contam Toxicol 104:47–62.3062701
*Arnold DW, Kennedy Jr GL, Keplinger ML, . 1977. Dominant lethal studies with technical chlordane, HCS-3260, and heptachlor:heptachlor epoxide. J Toxicol Environ Health 2:547–555.846003
*Aronson KJ, Wilson JW, Hamel M, . 2010. Plasma organochlorine levels and prostate cancer risk. J Expo Sci Environ Epidemiol 20(5):434–445. 10.1038/jes.2009.33.19513097
*Arruda JA, Cringan MS, Gilliland D, . 1987. Correspondence between urban areas and the concentrations of chlordane in fish from the Kansas River. Bull Environ Contam Toxicol 39:563–570.3689987
*Asakawa F, Jitsunari F, Shiraishi H, . 1996. Accumulation of chlordanes in adipose tissues of mice caused by long-term exposure of low level technical chlordane. Bull Environ Contam Toxicol (6):909–916.8875838
*Ashby J, Tennant RW. 1988. Chemical structure, Salmonella mutagenicity and extent of carcinogenicity as indicators of genotoxic carcinogenesis among 222 chemicals tested in rodents by the U.S. NCI/NTP. Mutat Res 204:17–115.3277047
*Atallah YH, Whitacre DM, Hoo BL. 1979. Comparative volatility of liquid and granular formulations of chlordane and heptachlor from soil. Bull Environ Contam Toxicol 22:570–574.486757
*Atkinson R. 1985. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds under atmospheric conditions. Chem Rev 85:69–201.
*Atkinson R. 1987. A structure-activity relationship for the estimation of rate constants for the gas-phase reactions of OH radicals with organic compounds. Int J Chem Kinet 19:799–828.
*Atlas E, Giam CS. 1988. Ambient concentrations and precipitation scavenging of atmospheric organic pollutants. Water Air Soil Pollut 38:19–36.
*Atlas E, Foster R, Giam CS. 1982. Air-sea exchange of high molecular weight organic pollutants: Laboratory studies. Environ Sci Technol 16:283–286.22257254
*ATSDR. 1989a. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services.
*ATSDR. 1989b. Health assessment for Velsicol Chemical Corporation NPL site, Marshall, Clark County, Illinois, Region 5. CERCLIS No. ILD000814673. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*ATSDR. 1992. 1989 and 1990 Biennial report. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*ATSDR. 2017. Chlordane. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
*Aulagnier F, Poissant L. 2005. Some pesticides occurrence in air and precipitation in Quebec, Canada. Environ Sci Technol 39(9):2960–2967.15926539
*Aust SD. 1990. Degradation of environmental pollutants by Phanerochaete chrysoporium. Microb Ecol 20:197–209.24193974
*Aust SD. 1992. Persistence of pesticide residues: Transport, fate and effects. Utah State University, Chemistry & Biochemistry, Logan, UT.
*Ault JA, Spurgeon TE. 1984. Multi-residue gas chromatographic method for determining organochlorine pesticides in poultry fat: Collaborative study. J Assoc Off Anal Chem 67:284–289.6725198
*Ault JA, Spurgeon TE, Gillard DS, . 1985. Multi-residue gas chromatographic method for determining organochlorine pesticides in meats validation study for swine and beef fats. J Assoc Off Anal Chem 68:941–944.4055641
*Azamoff DL. 1977. Insecticides: Effect on drug metabolism [Abstract]. Clin Pharmacol Ther 22:817–822.334442
*Bagchi D, Bagchi M, Hassoun EA, . 1995. In vitro and in vivo generation of reactive oxygen species, DNA damage and lactate dehydrogenase leakage by selected pesticides. Toxicology 104(1–3):129–140.8560491
*Balash KJ, Al-Omar MA, Abdul Latif BM. 1987. Effect of chlordane on testicular tissues of Swiss mice. Bull Environ Contam Toxicol 39:434–442.3663997
*Balba HM, Saha JG. 1978. Studies on the distribution, excretion, and metabolism of alpha and gamma isomers of (14^C^) chlordane in rabbits. J Environ Sci Health 13:211–233.
*Balistreri WF, Partin JC, Schubert WK. 1973. Hepatic necrosis following accidental chlordane exposure [Abstract]. Pediatr Res 7:319.
*Barbehenn KR, Reichel WL. 1981. Organochlorine concentrations in bald eagles: Brain/body lipid relations and hazard evaluation. J Toxicol Environ Health 8:325–330.7328713
*Barnes R. 1967. Poisoning by the insecticide chlordane. Med J Austr 54:972–973.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:47l–486.
*Barnett JR, Dorough HW. 1974. Metabolism of chlordane in rats. J Agric Food Chem 22:612–619.4841430
*Barnett JB, Blaylock BL, Gandy J, . 1990a. Long-term alteration of adult bone marrow colony formation by prenatal chlordane exposure. Fundam Appl Toxicol 14:688–695.2193845
*Barnett JB, Blaylock BL, Gandy J, . 1990b. Alteration of fetal liver colony formation by prenatal chlordane exposure. Fundam Appl Toxicol 15:820–822.2086321
*Barnett RW, D’Ercole AJ, Cain JD, . 1979. Organochlorine pesticide residues in human milk samples from women living in north-west and north-east Mississippi, 1973-1975. Pestic Monit J 13:47–51.514793
*Barnett JB, Holcomb D, Menna JH, . 1985a. The effect of prenatal chlordane exposure on specific anti-influenza cell-mediated immunity. Toxicol Lett 25:229–238.2990071
*Barnett JB, Soderberg LSF, Menna JH. 1985b. The effect of prenatal chlordane exposure on the delayed hypersensitivity response of Balb/c mice. Toxicol Lett 25:173–183.3159128
*Barquet A, Morgade C, Pfaffenberger CD. 1981. Determination of organochlorine pesticides and metabolites in drinking water, human blood serum, and adipose tissue. J Toxicol Environ Health 7:469–479.7288899
*Barrass N, Stewart M, Warburton S, . 1993. Cell proliferation in the liver and thyroid of C57Bl/10J mice after dietary administration of chlordane. Environ Health Perspect 101 Suppl 5:219–223.
Barril CR, Obillo MLA. 1979. Determination of organochlorine pesticide residues in milk by a rapid gas chromatographic methodology. Philippine Agriculturalist 62:296–308.
*Becker FF, Sell S. 1979. α-Fetoprotein levels and hepatic alterations during chemical carcinogenesis in C57BL/6N mice. Cancer Res 39:3491–3494.89897
*Beeman RW, Matsumura F. 1981. Metabolism of cis-and trans-chlordane by a soil microorganism. J Agric Food Chem 29:84–89.
*Ben-Dyke R, Sanderson DM, Noakes DN. 1970. Acute toxicity data for pesticides. Wildlife Review Pesticides Control 9:119.
*Bennett GW, Ballee EL, Hall RC, . 1974. Persistence and distribution of chlordane and dieldrin applied as termiticides. Bull Environ Contam Toxicol 11:64–69.4433785
*Bernad PG. 1989. Review: EEG and pesticides. Clin Electroencephalogr 20:9–10.
*Bessi H, Rast C, Rether B, . 1995. Synergistic effects of chlordane and TPA in multistage morphological transformation of SHE cells. Carcinogenesis 16(2):237–244.7859354
*Beyer WN, Kaiser TE. 1984. Organochlorine pesticide residues in moths from the Baltimore, MD, Washington, DC area. Environ Monit Assess 4:129–137.24259218
Bhatnagar VK, Patel JS, Variya MR, . 1992. Levels of organochlorine insecticides in human blood from Abmedabad (rural), India. Bull Environ Contam Toxicol 48:302–307.1537002
*Biberhofer J, Stevens RJJ. 1987. Organochlorine contaminants in ambient waters of Lake Ontario. Scientific Series - Canada, Inland Waters/Lands Directorate 159:1–11.
*Bidleman TF, Foreman WT. 1987. Vapor-particle partitioning of semivolatile organic compounds. Adv Chem Ser 216:27–56.
*Bidleman TF, Alegria H, Ngabe B, . 1998. Trends of chlordane and toxaphene in ambient air of Columbia, South Carolina. Atmos Environ 32(11):1849–1856.
*Bidleman TF, Billings WN, Foreman WT. 1986. Vapor-particle partitioning of semivolatile organic compounds: Estimates from field collections. Environ Sci Technol 20:1038–1043.22257405
*Bidleman TF, Wideqvist U, Jansson B, . 1987. Organochlorine pesticides and polychlorinated biphenyls in the atmosphere of southern Sweden. Atmos Environ 21:641–654.
*Bidleman TF, Cotham WE, Addison RF, . 1992. Organic contaminants in the northwest Atlantic atmosphere at Sable Island, Nova Scotia, 1988-1989. Chemosphere 24:1389–1412.
*Billings WN, Bidleman TF. 1980. Field comparison of polyurethane foam and tenax-GC resin for high-volume air sampling of chlorinated hydrocarbons. Environ Sci Technol 14:679–683.22296474
*Billings WN, Bidleman TF. 1983. High volume collection of chlorinated hydrocarbons in urban air using 3 solid adsorbents. Atmos Environ 17:383–392.
*Biros FJ, Enos HF. 1973. Oxychlordane residues in human adipose tissue. Bull Environ Contam Toxicol 10:257–260.4766127
*Blaylock BL, Soderberg LSF, Gandy J, . 1990a. Cytotoxic T-lymphocyte and NK responses in mice treated prenatally with chlordane. Toxicol Lett 51:41–49.2315958
*Blevins BD, Sholes TE. 1978. Response of HeLa cells to selected pesticides and hallucinogens. Growth 42:478–485.108181
*Blus L, Cromartie E, McNease L, , 1979. Brown pelican: Population status, reproductive success, and organochlorine residues in Louisiana, 1971-1976. Bull Environ Contam Toxicol 22:128–135.111734
*Blus LJ, Pattee OH, Henny CJ, . 1983. First records of chlordane-related mortality in wild birds. J Wildl Manage 47:196–198.
*Blyler G, Landreth KS, Barnett JB. 1994. Gender-specific effects of prenatal chlordane exposure on myeloid cell development. Fundam Appl Toxicol 23(2):188–193.7982527
*Boellstorff DE, Ohlendorf HM, Anderson DW, . 1985. Organochlorine chemical residues in white pelicans and western grebes from the Klamath Basin, California. Arch Environ Contam Toxicol 14:485–493.
*Bondy GS, Newsome WH, Armstrong CL, . 2000. trans-Nonachlor and cis-nonachlor toxicity in Sprague-Dawley rats: Comparison with technical chlordane. Toxicol Sci 58(2):386–398.11099650
*Bordet F, Mallet J, Borrel S, . 1993. Organochlorine pesticide and PCB congener content of French human milk. Bull Environ Contam Toxicol 50:425–32.8428123
*Borgmann U, Whittle DM. 1991. Contaminant concentration trends in Lake Ontario lake trout (Salvelinus-namuycush)- 1977 to 1988. J Great Lakes Res 17:368–381.
*Boyd EM, Taylor FI. 1969. The acute oral toxicity of chlordane in albino rats. Ind Med Surg 38:42–49.
*Brandt WN, Flamm WG, Bemheim NJ. 1972. The value of hydroxyurea in assessing repair synthesis of DNA in HeLa cells. Chem Biol Interact 5:327–339.4345371
*Brimfield AA, Street JC. 1981. Microsomal activation of chlordane isomers to derivatives that irreversibly interact with cellular macromolecules. J Toxicol Environ Health 7:193–206.6164795
*Brimfield AA, Street JC, Futrell J, . 1978. Identification of products arising from the metabolism of cis-and trans-chlordane in rat liver microsomes in vitro: Outline of a possible metabolic pathway. Pestic Biochem Physiol 9:84–95.
*Brock JW, Melnyk LJ, Caudill SP, . 1998. Serum levels of several organochlorine pesticides in farmers correspond with dietary exposure and local use history. Toxicol Ind Health 14(1–2):275–289. 10.1177/074823379801400117.9460180
*Brodtmann Jr NV. 1976. Continuous analysis of chlorinated hydrocarbon pesticides in the lower Mississippi River. Bull Environ Contam Toxicol 15:33–39.1276488
*Brown DP. 1992. Mortality of workers employed at organochlorine pesticide manufacturing plants: An update. Scand J Work Environ Health 18:155–161.1615289
*Buchert H, Class T, Ballschmiter, K. 1989. High-resolution gas chromatography of technical chlordane with electron-capture and mass-selective detection. Fresenius J Anal Chem 333:211–217.
*Bunck CM, Prouty RM, Krynitsky AJ. 1987. Residues of organochlorine pesticides and polychlorobiphenyls in starlings (Sturnus vulgaris) from the continental USA, 1982. Environ Monit Assess 8:59–76.24253771
*Buser HR, Muller MD, Rappe C. 1992. Enantioselective determination of chlordane components using chiral high-resolution gas chromatography-mass spectrometry with application to environmental samples. Environ Sci Technol 26:1533–1540.
*Cahill WP, Stumphy MK, and Raltech Scientific Services, Inc. 1979. Applicator and inhabitant exposure to chlordane during and after termiticide applications in California. Velsicol Chemical Corporation.
*Callahan CA, Menzie CA, Burmaster DE, . 1991. On-site methods for assessing chemical impact on the soil environment using earthworms: A case study at the Baird and McGuire Superfund site, Holbrook, MA. Environ Toxicol Chem 10:817–826.
*Camanzo J, Rice CP, Jude DJ, . 1987. Organic priority pollutants in nearshore fish from 14 Lake Michigan tributaries and embayments, 1983. J Great Lakes Res 13:296–309.
*Campbell MA, Gyorkos J, Leece B, . 1983. The effects of twenty-two organochlorine pesticides as inducers of the hepatic drug-metabolizing enzymes. Gen Pharmacol 14:445–454.
*Cantor KP Blair A, Everett G, . 1992. Pesticides and other agricultural risk factors for non-Hodgkin’s lymphoma among men in Iowa and Minnesota. Cancer Res 52:2447–2455.
*Cantor KP, Strickland PT, Brock JW, . 2003. Risk of non-Hodgkin’s lymphoma and prediagnostic serum organochlorines: β-hexachlorocyclohexane, chlordane/heptachlor-related compounds, dieldrin, and hexachlorobenzene. Environ Health Perspect 111(2):179–183.
*Carey AE, Douglas P, Tai H, . 1979a. Pesticide residue concentrations in soils of five United States cities, 1971. Pestic Monit J 13:17–22.492926
*Carey AE, Gowen JA, Tai H, 1978. Pesticide residue levels in soils and crops, 1971 - National Soils Monitoring Program (III). Pestic Monit J 12:117–136.740515
*Carey AE, Gowen JA, Tai H, . 1979b. Pesticide residue levels in soils and crops from 37 States, 1972 - National Soils Monitoring Program (IV). Pestic Monit J 12:209–229.461116
*Carey AE Wiersma GB, Tai H, . 1973. Pesticides in soil. Organochlorine pesticide residues in soils and crops of the corn belt region, United States, 1970. Pestic Monit J 6:369–376.4198496
*Carter FL, Stringer CA. 1971. Soil persistence of termite insecticides. Pestic Contr 39:13, 14, 16, 18, 20, 22.
*CAS. 1987. Chemical Abstracts Vol. 107 Chemical Substance Index, Bi-D July-December, 1987. Columbus, OH: Chemical Abstract Service.
*CAS. 1988. CAS Registry File. Chemical Abstract Service, Columbus, OH. August, 1988.
*CAS. 1992. Chemical Abstracts Service, Columbus, Oh. March 24, 1992.
*Cassidy RA, Hastings L, Vorhees CV. 1992. Effects of chronic pre- and postnatal chlordane exposure, food deprivation and caffeine on neurobehavioral indices in the rat [Abstract]. Teratology 45:535.
*Cassidy RA, Vorhees CV, Minnema DJ, . 1994. The effects of chlordane exposure during pre- and postnatal periods at environmentally relevant levels on sex steroid-mediated behaviors and functions in the rat. Toxicol Appl Pharmacol 126(2):326–337. 10.1006/taap.1994.1123.
*Casterline JL, Williams CH. 1971. The effects of 28-day pesticide feeding on serum and tissue enzyme activities of rats fed diets of varying casein content. Toxicol Appl Pharmacol 18:607–618.5569834
*CDC. 1976. Chlordane contamination of a municipal water system -Tennessee. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control. Morbidity and Mortality Weekly Report 25:117.
*CDC. 1981. Chlordane contamination of a public water supply-Pittsburgh, Pennsylvania. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control. Morbidity and Mortality Weekly Report 30:571–572.
*CDC. 2009. Fourth national report on human exposure to environmental chemicals. Atlanta, GA: Centers for Disease Control and Prevention, Department of Health and Human Services. http://www.cdc.gov/exposurereport. August 28, 2017.
*CDC. 2017. Fourth national report on human exposure to environmental chemicals. Updated tables, January 2017, Volume two. Atlanta, GA: Centers for Disease Control and Prevention, Department of Health and Human Services. https://www.cdc.gov/biomonitoring/pdf/FourthReport_UpdatedTables_Volume2_Jan2017.pdf. August 28, 2017.
*CDC/ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary and immune systems. Atlanta, GA: CDC/ATSDR Subcommittee on Biomarkers of Organ Damage and Dysfunction, Centers for Disease Control, Agency for Toxic Substances and Disease Registry. Summary report, August 27, 1990.
*CELDS. 1992. Computer-Aided Environmental Legislative Data System. University of Illinois, Urbano. March 1992.
*Chadwick RW, Chadwick CJ, Freal JJ, . 1977. Comparative enzyme induction and lindane metabolism in rats pre-treated with various organochlorine pesticides. Xenobiotica 7:235–246.68630
*Chambers C, Dutta SK. 1976. Mutagenic tests of chlordane on different microbial tester strains [Abstract]. Genetics 3:13.
*Chan CH, Perkins LH. 1989. Monitoring of trace organic contaminants in atmospheric precipitation. J Great Lakes Res 15:465–475.
*Chernoff N, Kavlock RJ. 1982. An in vivo teratology screen utilizing pregnant mice. J Toxicol Environ Health lo:541–550.
*Chuang LF, Liu Y, Killam K Jr, . 1992. Modulation by the insecticides heptachlor and chlordane of the cell-mediated immune proliferative responses of Rhesus monkeys. In vivo 6:29–32.1627739
*Clark Jr DR, Krynitsky AJ. 1985. DDE residues and artificial incubation of loggerhead sea turtle eggs. Bull Environ Contam Toxicol 34:121–125.3971053
*Clark Jr DR, Lamont TG. 1976. Organochlorine residues in females and nursing young of the big brown bat (Eptesicusfuscus). Bull Environ Contam Toxicol 15:1–8.
*Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
*Cohen SZ, Nickerson S, Maxey R, . 1990. A ground water monitoring study for pesticides and nitrates associated with golf courses on Cape Cod. Ground Water Monit Rev 10:160–173.
*Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56:898–908.
*Colt JS, Davis S, Severson RK, . 2006. Residential insecticide use and risk of non-Hodgkin’s lymphoma. Cancer Epidemiol Biomarkers Prev 15(2):251–257. 10.1158/1055-9965.epi-05-0556.16492912
*Cook MB, Trabert B, McGlynn KA. 2011. Organochlorine compounds and testicular dysgenesis syndrome: Human data. Int J Androl 34(4 Pt 2):e68–84; discussion e84-65. 10.1111/j.1365-2605.2011.01171.x.21668838
*Corneliussen PE. 1970. Residues in food and feed. Pesticide residues in total diet samples. V. Pestic Monit J 4:89–105.5489544
*Corneliussen PE. 1972. Residues in food and feed: Pesticide residues in total diet samples. VI. Pestic Monit J 5:313–330.4208741
*Cortes DR, Basu I, Sweet CW, . 1998. Temporal trends in gas-phase concentrations of chlorinated pesticides measured at the shores of the Great lakes. Environ Sci Technol 32:1920–1927.
*Cotham Jr WE, Bidelman TF. 1991. Estimating the atmospheric deposition of organochlorine contaminants to the Arctic. Chemosphere 22:165–188.
*Cox S, Niskar AS, Narayan KM, . 2007. Prevalence of self-reported diabetes and exposure to organochlorine pesticides among Mexican Americans: Hispanic Health and Nutrition Examination Survey, 1982-1984. Environ Health Perspect 115(12):1747–1752. 10.1289/ehp.10258.18087594
*Cram RL, Juchau MR, Fouts JR. 1956. Stimulation by chlordane of hepatic drug metabolism in the squirrel monkey. J Lab Clin Med 66:906–911.
*Cranmer JM, Cranmer MF, Goad PT. 1984. Prenatal chlordane exposure: Effects on plasma corticosterone concentrations over the lifespan of mice. Environ Res 35:204–210.6489289
*Cueto Jr C, Biros FJ. 1967. Chlorinated insecticides and related materials in human urine. Toxicol Appl Pharmacol 1:261–269.
*Curley A, Garrettson LK. 1969. Acute chlordane poisoning. Clinical and chemical studies. Arch Environ Health 18:211–215.5773973
*Dadey JL, Kammer AG. 1953. Chlordane intoxication. J Am Med Assoc 153:723.13096283
*Dai K-S, Hasan ZA, Woolley DE. 1989. Effects of RO-5-4864 and chlordane on limbic evoked potentials in the freely behaving female rat [Abstract]. Society for Neuroscience 15:669.
*Datta KK, Gupta PC, Dikshith TSS. 1977. Effect of chlordane on the skin of male guinea pigs. In: Zaida SH, ed. Environmental pollution and human health. Lucknow, India: Industrial Toxicology Research Centre, 608–611.
*Dearth MA, Hites RA. 1991a. Chlordane accumulation in people. Environ Sci Technol 25:1279–1285.
*Dearth MA, Hites RA. 1991b. Depuration rates of chlordane compounds from rat fat. Environ Sci Technol 25:1125–1128.
*Dearth MA, Hites RA. 1991c. Complete analysis of technical chlordane using negative ionization mass spectrometry. Environ Sci Technol 25:245–254.
*Deichmann WB, Keplinger ML. 1970. Protection against the acute effects of certain pesticides by pretreatment with aldrin, dieldrin and DDT. Toxicol Occup Med 6:121–123.
*Delaplane KS, LaFage JP. 1990. Variable chlordane residues in soil surrounding house foundations in Louisiana, USA. Bull Environ Contam Toxicol 45:675–680.2265268
*Demers A, Ayotte P, Brisson J, . 2000. Risk and aggressiveness of breast cancer in relation to plasma organochlorine concentrations. Cancer Epidemiol Biomarkers Prev 9(2):161–166.10698476
*Den Tonkelaar EM, Van Esch GJ. 1974. No-effect levels of organochlorine pesticides based on induction of microsomal liver enzymes in short-term toxicity experiments. Toxicology 2:371–380.4137085
*Derbes VJ, Dent JH, Forrest W, . 1955. Fatal chlordane poisoning. J Am Med Assoc 158:1367–1369.13242360
*Dewailly E, Mulvad G, Pedersen HS, . 1999. Concentration of organochlorines in human brain, liver, and adipose tissue autopsy samples from Greenland. Environ Health Perspect 107(10):823–828.
*Ditraglia D, Brown DP, Namekata T, . 1981. Mortality study of workers employed at organochlorine pesticide manufacturing plants. Scand J Work Environ Health 7:140–146.7330625
*DOE. 2016a. Table 3: Protective Action Criteria (PAC) Rev. 29 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. May 2016. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/teel/Revision_29_Table3.pdf. February 28, 2017.
*DOE. 2016b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29 for Chemicals of Concern - May 2016. Oak Ridge, TN: U.S. Department of Energy. https://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-29-chemicals-concern-may-2016. February 28, 2017.
*Dougherty RCMJ, Whitaker LM, Smith LM, . 1980. Negative chemical ionization studies of human and food chain contamination with xenobiotic chemicals. Environ Health Perspect 36:103–l18.7428739
*Dowd PF, Mayfield GU, Coulon DP, . 1985. Organochlorine residues in animals from three Louisiana watersheds in 1978 and 1979. Bull Environ Contam Toxicol 34:832–841.4016291
*Dragun J. 1991. Geochemistry and soil chemistry reactions occurring during in situ vitrification. J Hazard Mater 26:343–364.
*Drummond L, Chetty KN, Desaiah D. 1983. Changes in brain ATPases in rats fed on chlordane mixed with iron-sufficient and deficient diet. Drug Chem Toxicol 6:259–266.6226517
Duggan RE, Barry HC, Johnson LY. 1966. Pesticide residues in total-diet samples. Science 151:101–104.5908960
*Duggan RE, Barry HC, Johnson LY. 1967. Residues in food and feed. Pesticide residues in total diet samples. II. Pestic Monit J 1:2–12.
*Duggan RE, Corneliussen PE, Duggan MB, . 1983. Pesticide residue levels in foods in the United States from July 1, 1969 to June 30, 1976. Washington, DC: Food and Drug Administration, Division of Chemical Technology.
*Eichelberger JW, Lichtenberg JJ. 1971. Persistence of pesticides in river water. Environ Sci Technol 5:541–544.
*Eichelberger JW, Kerns EH, Olynyx P, . 1983. Precision and accuracy in the determination of organics in water by fused silica capillary column gas chromatography/mass spectrometry and packed column gas chromatography/mass spectrometry. Anal Chem 55:1471–1479.
*Eisenberg M, Topping JJ. 1985. Organochlorine residues in finfish from Maryland Waters, 1976-1980. J Environ Sci Health B 20:729–742.3937849
*Elder JF, Mattraw HC. 1984. Accumulation of trace elements, pesticides, and polychlorinated biphenyls in sediments and the clam Corbiculu manilensis of the Apalachicola River, Florida. Environ Contam Toxicol 13:453–469.
*Elia VJ, Clark CS, Majeti VA, . 1983. Hazardous chemical exposure at a municipal wastewater treatment plant. Environ Res 32:360–371.6641669
*Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier Press, 1078–1080.
*EPA. 1977. Manual of analytical methods for the analysis of pesticide residues in human and environmental samples. Revisions by the Association of Official Analytical Chemists. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory, Environmental Toxicology Division.
*EPA. 1978. OPP-68004; FRL 871-3. Consolidated heptachlor/chlordane cancellation proceedings, Velsicol Chemical Co., et al. Fed Regist 43:12372–12379.
*EPA. 1980a. Summary of reported pesticide incidents involving chlordane. Pesticide Incident Monitoring System Report No. 360. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide Programs.
*EPA. 1980b. Ambient water quality criteria for chlordane. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. PB81117384.
*EPA. 1982a. Test methods for organic chemical analysis of municipal and industrial wastewater. Method No. S608 and S625. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory.
*EPA. 1982b. U.S. Environmental Protection Agency. Code of Federal Regulations (CFR), 40CFR261.32, 261.33. July 1, 1982.
*EPA. 1982c. Safe methods for estimating solid wastes. Method 8080, SW-846. U.S. Environmental Protection Agency.
*EPA. 1983. Analysis of the risks and benefits of seven chemicals used for subterranean termite control. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
*EPA. 1984. Analytical reference standards and supplemental data: The pesticides and industrial chemicals repository. Las Vegas, NV: U.S. Environmental Protection Agency, Office of Research and Development. EPA6001484082.
*EPA. 1985a. Memorandum. 6(a)(2) Data on chlordane. Chronic mouse and rat studies for oncogenicity testing. Act. Nos. 252267, 254665, 251815, Review No. 004635. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
*EPA. 1985b. Exposure Analysis Modeling System: Reference Manual for EXAMS II. EPA600385038. Environ Res Lab, Athens, GA.
*EPA. 1986a. Test methods for evaluating solid wastes. SW-846, Method no. 8080, Volume 1B: Laboratory manual: Physical/chemical methods, 3rd ed. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986b. Graphical Exposure Modeling System (GEMS). CLOGP Computer Program, Version PC 1,2, August 1, 1986.
*EPA. 1986c. Carcinogenicity assessment of chlordane and heptachlor, heptachlor epoxide. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. PB87208757.
*EPA. 1986d. Guidance for the reregistration of pesticide products containing chlordane as the active ingredient. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. PB87175816.
*EPA. 1987a. U.S. EPA contract laboratory program. Statement of work for organic analysis. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1987b. OPP-60011; FRL-3286-8. Chlordane and heptachlor termiticides; cancellation order. Fed Regist 52:42145–42149.
*EPA. 1987c. 40 CFR Parts 117 and 302. Reportable quantity adjustments. Proposed rule. Fed Regist 52:8140–8151.
*EPA. 1987d. 40 CFR Parts 300 and 355. Extremely hazardous substances list and threshold planning quantities; emergency planning and release notification requirements. Final Rule. Fed Regist 52:13378–13410.
*EPA. 1987e. Drinking water criteria document for heptachlor, heptachlor epoxide, and chlordane. Final. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Drinking Water.
*EPA. 1987f. Memorandum. Transmittal of 90-day chlordane inhalation study conducted in rats and monkeys. Act. No. 254322. Review No. 006331. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
*EPA. 1987g. Chlordane, heptachlor, aldrin, and dieldrin technical support document (Draft). July 1987. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide Programs and Office of Pesticides and Toxic Substances.
*EPA. 1988a. Analysis of clean water act effluent guidelines pollutants. Summary of the chemicals regulated by Industrial Point Source Category. 40 CFR Parts 400-475. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards.
*EPA. 1988b. Memorandum. Review of pathology working group slide reevaluation of livers of rats in a 30-month oral exposure to chlordane. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
*EPA 1988c. Chlordane/heptachlor termiticides; notification of cancellation and amendment of existing stocks determination. Fed Regist 53:11798–l 1805.
*EPA. 1988d. Determination of chlordane in soil by enzyme immunoassay. U.S. Environmental Protection Agency. EPA6OOD89.
*EPA. 1990a. Interim methods for development of inhalation reference doses. U.S. Environmental Protection Agency. EPA600890066A.
*EPA. 1990b. Nonoccupational Pesticide Exposure Study (NOPES). Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600390003. PB90152224.
*EPA. 1991. Burning of hazardous waste in boilers and industrial furnaces. Fed Regist 56:7134–7239.
*EPA. 1993. Standards for the use and disposal of sewage sludge. Fed Regist 58:9248–9415.
*EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
*EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA 816-F-09-0004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. February 28, 2017.
*EPA. 2012. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA 822-S-12-001. https://www.epa.gov/sites/production/files/2015-09/documents/dwstandards2012.pdf. February 28, 2017.
*EPA. 2016. Acute Exposure Guideline Levels (AEGLs) Values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-03/documents/compiled_aegl_update_.pdf. July 26, 2017.
*Epstein SS. 1976. Carcinogenicity of heptachlor and chlordane. Sci Total Environ 6:103–154.959811
*Epstein SS, Ozonoff D. 1987. Leukemias and blood dyscrasias following exposure to chlordane and heptachlor. Teratogen Carcinogen Mutagen 7:527–540.
*Epstein SS, Arnold E, Andrea J, . 1972. Detection of chemical mutagens by the dominant lethal assay in the mouse. Toxicol Appl Pharmacol 23:288–325.5074577
*Ercegovich CD, Rashid KA. 1977. Mutagenesis induced in mutant strains of Salmonella typhimurium by pesticides [Abstract]. Am Chem Soc 174:43.
Erstfeld KM, Simmons MS, Atallah TH. 1989. Determination of chlordane in laboratory-generated environmental fate samples. Int J Environ Anal Chem 37:119–211.
*Everett CJ, Matheson EM. 2010. Biomarkers of pesticide exposure and diabetes in the 1999-2004 National Health and Nutrition Examination Survey. Environ Int 36(4):398–401. 10.1016/j.envint.2010.02.010.20299099
*Ewing AD, Kadry AM, Dorough HW. 1985. Comparative disposition and elimination of chlordane in rats and mice. Toxicol Lett 26:233–239.4035715
*Fabacher DL, Kulkarni AP, Hodgson E. 1980. Pesticides as inducers of hepatic drug-metabolizing enzymes. I. Mixed function oxidase activity. Gen Pharmacol 11:429–435.7419035
*Falck F, Ricci A, Wolff MS, . 1992. Pesticides and polychlorinated biphenyl residues in human breast lipids and their relation to breast cancer. Arch Environ Health 47:143–146.1567239
*FAO/WHO. 1973. 1972 Evaluations of some pesticide residues in food. Rome: Food and Agriculture Organization of the United Nations. (Cited in WHO 1984)
*FAO/WHO. 1978. 1977 Evaluations of some pesticide residues in food. Rome: Food and Agriculture Organization of the United Nations. (Cited in WHO 1984)
*FDA. 1989a. Food and Drug Administration. Pesticide program - residues in foods - 1988. J Assoc Off Anal Chem 72:133A–152A.
*FDA. 1989b. Chlordane. Compliance policy guide 7141.01. U.S. Food and Drug Administration, Washington, DC.
*FDA. 1990. Food and Drug Administration. Pesticide program - residues in foods - 1989. J Assoc Off Anal Chem 73:127A–146A.
*FDA. 1991. Food and Drug Administration. Pesticide program - residues in foods - 1990. J Assoc Off Anal Chem 74:121A–141A.
*FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. February 28, 2017.
*FDA. 2016. Subpart B - Requirements for specific standardized beverages. Section 165.110 - Bottled water. Food and Drug Administration. Code of Federal Regulations 21 CFR 165.110 https://www.gpo.gov/fdsys/pkg/CFR-2016-title21-vol2/pdf/CFR-2016-title21-vol2-sec165-110.pdf. July 26, 2017.
*Fendinger NJ, Glotfelty DE, Freeman HP. 1989. Comparison of two experimental techniques for determining air/water Henry’s law constants. Environ Sci Technol 23:1528–1531.
*Fenske RA, Sternbach T. 1987. Indoor air levels of chlordane in residences in New Jersey. Bull Environ Contam Toxicol 39:903–910.3440146
*Fenster L, Eskenazi B, Anderson M, . 2006. Association of in utero organochlorine pesticide exposure and fetal growth and length of gestation in an agricultural population. Environ Health Perspect 114(4):597–602.16581552
*Feroz M, Kagan J, Ramesh S, . 1981. Photolysis of cis-chlordane: Identification of two isomers of cis-photochlordane. J Agric Food Chem 29:272–276.
*Fishbein WI, White JV, Isaacs HJ. 1964. Survey of workers exposed to chlordane. Ind Med Surg 10:726–727.
*Fishman BE, Gianutsos G. 1985. Inhibition of 4-aminobutyric acid (GABA) turnover by chlordane. Toxicol Lett 26:219–223.4035713
*Foreman WT, Bidleman TF. 1987. An experimental system for investigating vapor-particle partitioning of trace organic pollutants. Environ Sci Technol 21:869–875.
*Foreman WT, Bidleman TF. 1990. Semivolatile organic compounds in the ambient air of Denver, Colorado. Atmos Environ, 24A:2405–2416.
*Frank R, Braun HE, Stonefield KI, . 1990. Organochlorine and organophosphorus residues in the fat of domestic farm animal species, Ontario, Canada 1986-1988. Food Addit Contam 7:629–636.2253807
*Fricke C, Clarkson C, Lomnitz E, . 1985. Comparing priority pollutants in municipal sludges. BioCycle 26:35–37.
*Frings H, O’Tousa JE. 1950. Toxicity to mice of chlordane vapor and solutions administered cutaneously. Science 111:658–660.15424667
*Gaines TB. 1960. The acute toxicity of pesticides to rats. Toxicol Appl Pharmacol 2:88–90.13825957
*Gak JC, Graillot C, Truhaur R. 1976. Use of the golden hamster in toxicology. Lab Anim Sci 26(2), Part II:274–280.775193
*Gammon MD, Wolff MS, Neugut AI, . 2002. Environmental toxins and breast cancer on Long Island. II. Organochlorine compound levels in blood. Cancer Epidemiol Biomarkers Prev 11(8):686–697.12163320
*Gartrell MJ, Craun JC, Podrebarac DS, . 1985a. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1979-September 1980. J Assoc Off Anal Chem 68:1184–1197.4086442
*Gartrell MJ, Craun JC, Podrebarac DS, . 1985b. Pesticides, selected elements, and other chemicals in infant and toddler total diet samples, October 1979-September 1980. J Assoc Off Anal Chem 68:1163–l183.4086441
*Gartrell MJ, Craun JC, Podrebarac DS, . 1985c. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1978-September 1979. J Assoc Off Anal Chem 68:862–875.4055631
*Gartrell MJ, Craun JC, Podrebarac DS, . 1985d. Pesticides, selected elements, and other chemicals in infant and toddler total diet samples, October 1978-September 1979. J Assoc Off Anal Chem 68:842–861.4055630
*Gartrell MJ, Craun JC, Podrebarac DS, . 1986a. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1980-March 1982. J Assoc Off Anal Chem 69:146–161.3949687
*Gartrell MJ, Craun JC, Podrebarac DS, . 1986b. Chemical contaminants monitoring. Pesticides, selected elements, and other chemicals in infant and toddler total diet samples, October 1980-March 1982. J Assoc Off Anal Chem 69:123–145.3949685
*Gauthier M, Girard D. 2001. Activation of human neutrophils by chlordane: Induction of superoxide production and phagocytosis but not chemotaxis or apoptosis. Hum Exp Toxicol 20(5):229–235. 10.1191/096032701678227695.11476154
*Gentile JM, Gentile GJ, Bultman J, . 1982. An evaluation of the genotoxic properties of insecticides following plant and animal activation. Mutat Res 101:19–29.7043246
*Gilliom RJ. 1984. Pesticides in rivers of the United States. National Water Summary 1984 - Water Quality Issues, Hydrologic Perspectives, 85–92.
*Gladen BC, Shkiryak-Nyzhnyk ZA, Chyslovska N, . 2003. Persistent organochlorine compounds and birth weight. Ann Epidemiol 13(3):151–157 12604157
*Glotfehy DE, Schomburg CJ. 1989. Volatilization of pesticides from soil. In: Reactions and movement of organic chemicals in soils. Soil Science Society of America and American Society of Agronomy. SSSA Special Publication 22, 181–207.
*Glotfelty DE, Taylor AW, Turner BC, . 1984. Volatilization of surface-applied pesticides from fallow soil. J Agric Food Chem 32:638–644.
*Glynn AW, Michaelsson K, Lind PM, . 2000. Organochlorines and bone mineral density in Swedish men from the general population. Osteoporosis Int 11(12):1036–1042. 10.1007/s001980070025.
*Gobas FAPC, Muir DCG, Mackay D. 1988. Dynamics of dietary bioaccumulation and faecal elimination of hydrophobic organic chemicals in fish. Chemosphere 17:943–962.
*Goldberg MC. 1982. A method of calculating the pesticide partition between sediment and water for environmental systems. Sci Total Environ 24:73–84.
Gowen JA, Wiersma GB, Tai H, . 1976. Pesticide levels in hay and soils from nine states. Pestic Monit J 10:114–l16.1005064
*Griffin DE, Hill WE. 1978. In vitro breakage of plasmid DNA by mutagens and pesticides. Mutat Res 52:161–169.368611
*Griffith FD, Blanke RV. 1974. Microcoulometric determination of organochlorine pesticides in human blood. J Assoc Off Anal Chem 57:595–603.4833395
*Grimes GJ, Morrison SM. 1975. Bacterial bioconcentration of chlorinated hydrocarbon insecticides from aqueous systems. Microbial Ecol 2:43–59.
*Grutsch JF, Khasawinah A. 1991. Signs and mechanisms of chlordane intoxication. Biomed Environ Sci 4:317–326.1764223
*Gunderson EL. 1988. FDA total diet study April 1982- April 1984, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 71:1200–1209.3240978
*Gustafson DI. 1989. Groundwater ubiquity score: A simple method for assessing pesticide leachability. Environ Toxicol Chem 8:339–357.
*Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia, PA: WB Saunders Co., 1084–1085.
*Hall RJ, Kaiser TE, Robertson Jr WB, . 1979. Organochlorine residues in eggs of the endangered American crocodile (Crocodylus acutus). Bull Environ Contam Toxicol 23:87–90.115521
*Haque R, Freed VH. 1974. Behavior of pesticides in the environment: Environmental chemodynamics. Res Rev 52:89–l16.
Harbison RD. 1975. Comparative toxicity of some selected pesticides in neonatal and adult rats. Toxicol Appl Pharmacol 32:443–446.1154405
*Hardell L, Andersson SO, Carlberg M, . 2006. Adipose tissue concentrations of persistent organic pollutants and the risk of prostate cancer. J Occup Environ Med 48(7):700–707. 10.1097/01.jom.0000205989.46603.43.16832227
*Hardell L, Carlberg M, Hardell K, . 2007. Decreased survival in pancreatic cancer patients with high concentrations of organochlorines in adipose tissue. Biomed Pharmacother 61(10):659–664. 10.1016/j.biopha.2007.04.006.17560068
*Hardell L, Liljegren G, Lindstrom G, . 1996. Increased concentrations of chlordane in adipose tissue from non-Hodgkin’s lymphoma patients compared with controls without a malignant disease. Int J Oncol 9(6):1139–1142.21541622
*Hardell L, van Bavel B, Lindstrom G, . 2003. Increased concentrations of polychlorinated biphenyls, hexachlorobenzene, and chlordanes in mothers of men with testicular cancer. Environ Health Perspect 111(7):930–934.12782494
*Hardell L, van Bavel B, Lindstrom G, . 2005. In utero exposure to persistent organic pollutants in relation to testicular cancer risk. Int J Androl 29:228–234.16371110
*Hargrave BT, Harding GC, Vass WP, . 1992. Organochlorine pesticides and polychlorinated biphenyls in the Arctic Ocean food web. Arch of Environ Contam Toxicol 22:41–54.1554252
*Harrington JM, Baker Jr EL, Folland DS, . 1978. Chlordane contamination of a municipal water system. Environ Res 15:155–159.620658
*Harris CR, Sans WW. 1976. Persistence of Velsicol HCS-3260 (Ag-Chlordane) in mineral and organic soil. Proceedings of the Entomological Society of Ontario 106:34–38.
*Hart LG, Shultice RW, Fouts JR. 1963. Stimulatory effects of chlordane on hepatic microsomal drug metabolism in the rat. Toxicol Appl Pharmacol 5:371–386.13953039
*Hartley D, Kidd H, eds. 1983. The agrochemicals handbook. United Kingdom: The Royal Society of Chemistry.
*Hasan Z, Woolley D, Dai K-S, . 1989. Chlordane alters limbic evoked potentials [Abstract]. Proceedings of the Society of Toxicology, 28th Annual Meeting. Atlanta, GA. February 27, 1989-March 3, 1989.
*Hassoun E, Baggchi M, Bagchi D, . 1993. Comparative studies on lipid peroxidation and DNA-single strand breaks induced by lindane, DDT, chlordane and endrin in rats. Comp Biochem Physiol C Comp Pharmacol Toxicol 104(3):427–431.7689940
*Hawley GG. 1981. The condensed chemical dictionary. 10th ed. New York, NY: Van Nostrand Reinhold Co., 229.
*Heinz GH, Swineford DM, Katsma DE. 1984. High PCB residues in birds from the Sheboygan River, Wisconsin. Environ Monit Assess 4:155–161.24259220
*Hernandez HF, Lopez BFJ, Medina EJ, . 1987. Sulfuric acid cleanup and potassium hydroxide ethanol treatment for confirmation of organochlorine pesticides and polychlorinated biphenyls: Application to wastewater samples. J Assoc Off Anal Chem 70:727–733.3114228
*Hinckley DA, Bidleman TF. 1991. Atmospheric organochlorine pollutants and air-sea exchange of hexachlorocyclohexane in the Bering and Chukchi Seas. J Geophys Res 96:7201–7213.
*Hinman ML, Klaine SJ. 1992. Uptake and translocation of selected organic pesticides by rooted aquatic plant Hydrilh verticillatu Royle. Environ Sci Technol 26:609–613.
*Hirasawa F, Takizawa Y. 1989. Accumulation and declination of chlordane congeners in mice. Toxicol Lett 47:109–117.2741174
*Hirai Y, Tomokuni K. 1991a. Levels of chlordane, oxychlordane and nonachlor in human adipose tissues. Bull Environ Contam Toxicol 47:173–176.1912692
*Hirai Y, Tomokuni K. 1991b. Levels of chlordane oxychlordane and nonachlor in human blood. Bull Environ Contam Toxicol 46:670–676.2039866
*Hirai Y, Tomokuni K. 1993. Levels of chlordane, oxychlordane, and nonachlor on human skin and in human blood. Bull Environ Contam Toxicol 50:316–324.8422535
*Hirano T, Ishida T, Oh K, . 2007. Biodegradation of chlordane and hexachlorobenzenes in river sediment. Chemosphere 67(3):428–434.17123575
*Hodgson E, Kulkami AP, Fabacher DL, . 1980. Induction of hepatic drug metabolizing enzymes in mammals by pesticides: A review. J Environ Sci Health B 15:723–754.7002988
*Hoff RM, Muir DCG, Grift, NP. 1992. Annual cycle of polychlorinated biphenyls and organohalogen pesticides in air in southern Ontario. 1. Air concentration data. Environ Sci Technol 26:266–275.
*Hopper ML. 1982. Automated gel permeation system for rapid separation of industrial chemicals and organophosphate and chlorinated pesticides from fats. J Agric Food Chem 30:1038–1041.
*Houk VS, DeMarini DM. 1987. Induction of prophage lambda by chlorinated pesticides. Mutat Res 182:193–202.2956515
*Hrdina PD, Peters DA, Singhal RL. 1974. Role of noradrenaline, 5-hydroxytryptamine and acetylcholine in the hypothermic and convulsive effects of α-chlordane in rats. Eur J Pharmacol 26:306–312.4854166
*HSDB (Hazardous Substance Data Base). 1988. Record No. 802, On-line computer database, August 14, 1988. National Library of Medicine (NLM).
*Hsu JP, Wheeler Jr HG, Camann DE, . 1988. Analytical methods for detection of non-occupational exposure to pesticides. J Chromatogr Sci 26:181–189.3379124
*Huang JC. 1970. Fate of organic pesticides in the aquatic system. Engineering Extension Series (Purdue University), 449–457.
*Hung H, Halsall CJ, Blanchard P, . 2002. Temporal trends in organochlorine pesticides in the Canadian arctic atmosphere. Environ Sci Technol 36:862–868.11918008
*Hunter RG, Carroll JH, Randolph JC. 1980. Organochlorine residues in fish of Lake Texoma, October 1979. Pestic Monit J 14:102–107.7465323
Hyde KM, Falkenberg RL. 1976. Neuroelectrical disturbance as indicator of chronic chlordane toxicity. Toxicol Appl Pharmacol 37:499–515.973223
Hyde KM, Crandall JC, Kortman KE, . 1978. EEG, ECG and respiratory response to acute insecticide exposure. Bull Environ Contam Toxicol 19:47–55.630145
*IARC. 1987. IARC monographs on the evaluation of carcinogenic risks to humans. Update for volume 1 to 42. Lyon, France: World Health Organization.
*IARC. 2001. Chlordane and heptachlor. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 79. Some thyrotropic agents. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Monographs/vol79/mono79-17.pdf. July 26, 2017.
*IARC. 2017. Agents classified by the IARC Monographs, Volumes 1–119. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf. July 26, 2017.
*Infante P, Epstein SS, Newton Jr WA. 1978. Blood dyscrasias and childhood tumors and exposure to chlordane and heptachlor. Scand J Work Environ Health 4:137–150.278225
*Ingle L. 1952. Chronic oral toxicity of chlordane to rats. Arch Ind Hyg Occup Med 6:357–367.
*Ingle L. 1953. The toxicity of chlordane vapors. Science 118:213–214.13089649
*Ingle L. 1965. A monograph on chlordane toxicological and pharmacological properties. University of Illinois, Urbana, Illinois.
*Inoue K, Fujimori K, Nakazawa K, . 1989. The mechanism of action of chlordane a termiticide. Proceedings of the Japanese Pharmacological Society 62nd General Meeting, Kyoto, Japan, March 25-28, 1989.
*IRDC. 1973. (International Research and Development Corp.) Unpublished report to Velsicol Chemical Corporation, eighteen month oral carcinogenic study in mice. December 14. (Cited in Epstein, 1976).
*IRIS. 1992. Integrated Risk Information System. Cincinnati, OH: U.S. Environmental Protection Agency. Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. February 25, 1992.
*IRIS. 2002. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0142_summary.pdf. July 26, 2017.
*Isnard P, Lambert S. 1988. Estimating bioconcentration factors from octanol-water partition coefficient and aqueous solubility. Chemosphere 17:21–34.
*Ivie GW, Knox JR, Khalifa S, . 1972. Novel photoproducts of heptachlor epoxide, trans-chlordane, and trans-nonachlor. Bull Environ Contam Toxicol 7:376–382.4677557
*Iyengar L, Prabhakara Rao AVS. 1973. Metabolism of chlordane and heptachlor by Aspergillus niger. J Gen Appl Microbial 19:321–324. (Tokyo)
*Jaffe PR, Parker FL, Wilson DJ. 1982. Distribution of toxic substances in rivers. J Environ Eng 108:639–649.
Jang H, Talamantes F. 1977. Effects of chlordane on ova implantation in the mouse. Bull Environ Contam Toxicol 17:559–563.861409
*Jansson B, Wideqvist U. 1983. Analysis of toxaphene (PCC) and chlordane in biological samples by NCI mass spectrometry. Int J Environ Anal Chem 13:309–321.6402458
*Jantunen LMM, Bidleman TF, Harner T, . 2000. Toxaphene, chlordane, and other organochlorine pesticides in Alabama air. Environ Sci Technol 34:5097–5105.
*Jensen AA. 1983. Chemical contaminants in human milk. Residue Rev 89:1–128.6316441
*Johnson RD, Manske DD. 1976. Residues in food and feed. Pesticide residues in total diet samples. IX. Pestic Monit J 9:157–169.944415
Johnson RD, Manske DD. 1977. Pesticides in food and feed. Pesticide and other chemical residues in total diet samples. XI. Pestic Monit J 11:116–131.609510
*Johnson KW, Holsapple MP, Munson AE. 1986. An immunotoxicological evaluation of γ-chlordane. Fundam Appl Toxicol 6:317–326.3486141
*Johnson KW, Kaminski NE, Munson AE. 1987. Direct suppression of cultured spleen cell responses by chlordane and the basis for differential effects on in vivo and in vitro immunocompetence. J Toxicol Environ Health 22:497–515.3694709
Johnson RD, Manske DD, New DH, . 1979. Food and feed. Pesticides and other chemical residues in infant and toddler total diet samples. I. August 1974-July 1975. Pestic Monit J 13:87–98.583446
*Johnson RD, Manske DD, New DH, . 1981b. Food and feed. Pesticide, heavy metal, and other chemical residues in infant and toddler total diet samples. II. August 1975-July 1976. Pestic Monit J 15:39–50.6895107
*Johnson RD, Manske DD, New DH, . 1984a. Pesticide, heavy metal, and other chemical residues in infant and toddler total diet samples. III. August 1976-September 1977. J Assoc Off Anal Chem 67:145–154.6546565
*Johnson RD, Manske DD, New DH, . 1984b. Pesticide, metal, and other chemical residues in adult total diet samples. XIII. August 1976-September 1977. J Assoc Off Anal Chem 67:154–166.6546566
*Johnson RD, Manske DD, Podrebarac DS. 1981a. Pesticide, metal, and other chemical residues in adult total diet samples. XII. August 1975-July 1976. Pestic Monit J 15:54–69.7279595
*Johnson-Logan LR, Broshears RE, Klaine SJ. 1992. Partitioning behavior and the mobility of chlordane in groundwater. Environ Sci Technol 26:2234–2239.
*Jury WA, Focht DD, Farmer WJ. 1987a. Evaluation of pesticide groundwater pollution potential from standard indices of soil-chemical adsorption and biodegradation. J Environ Qual 16:422–428.
*Jury WA, Russo D, Streile G, . 1990. Evaluation of volatilization by organic chemicals residing below the soil surface. Water Resources Res 26:13–20.
*Jury WA, Winer AM, Spencer WF, . 1987b. Transport and transformation of organic chemicals in the soil-air-water ecosystem. Rev Environ Contam Toxicol 99:119–164.
*Kacew S, Singhal R. 1973. The influence of p,p’-DDT α-chlordane, heptachlor and endrin on hepatic and renal carbohydrate metabolism and cyclic AMP-adenyl cyclase system. Life Sci 13:1363–1371.4357693
*Kamble ST, Ogg CL, Gold RE, . 1992. Exposure of applicators and residents to chlordane and heptachlor when used for subterranean termite control. Arch Environ Contam Toxicol 22:253–259.1616308
*Kang JH, Park H, Chang YS, . 2008. Distribution of organochlorine pesticides (OCPs) and polychlorinated biphenyls (PCBs) in human serum from urban areas in Korea. Chemosphere 73(10):1625–1631. 10.1016/j.chemosphere.2008.07.087.18829066
Karel AK, Saxena SC. 1976. Chronic chlordane toxicity: Effect on blood biochemistry of Meriones hurriume Jerdon, the Indian desert gerbil. Pestic Biochem Physiol 6:111–114.
*Kawano M, Tatsukawa R. 1982. [Chlordane and related compounds in blood of pest control operators.] Nippon Nogeikaguku Kaishi 56:923. (Japanese)
*Kawano M, Inoue T, Wada T, . 1988. Bioconcentration and residue patterns of chlordane compounds in marine animals: Invertebrates, fish, mammals, and seabirds. Environ Sci Technol 22:792–797.22195663
*Kawano M, Nishiyama N, Tatsukawa R, . 1989. In vitro degradation of trans-chlordane and oxychlordane by rat liver microsomes. Chemosphere 19:1829–1833.
*Kazen C, Bloomer A, Welch R, . 1974. Persistence of pesticides on the hands of some occupationally exposed people. Arch Environ Health 29:315–318.4279630
*KDHE. 1988. Kansas Department of Health and Environment. A survey of pesticides in Tuttle Creek Lake, its tributaries, and the upper Kansas River, June 1988. Bureau of Water Protection, Topeka, KS.
*Kennedy DW, Aust AD, Bumpus JA. 1990. Comparative biodegradation of alkyl halide insecticides by the white rot fungus, Phancrochaete chrysosporium (BKM-F-1767). Appl Environ Microbial 56:2347–2353.
*Keplinger ML, Deichmann WB. 1967. Acute toxicity of combinations of pesticides. Toxicol Appl Pharmacol 10:586–595.6059673
*Khasawinah AM. 1989. Chlordane residues in rat and monkey tissues following subchronic inhalation exposure to technical chlordane. Bull Environ Contam Toxicol 43:459–466.2790253
*Khasawinah AM, Grutsch JF. 1989a. Chlordane thirty-month tumorigenicity and chronic toxicity test in rats. Regul Toxicol Pharmacol 10:95–109.2813873
*Khasawinah AM, Grutsch JF. 1989b. Chlordane: 24-month tumorigenicity and chronic toxicity test in mice. Regul Toxicol Pharmacol 10:244–254.2532379
*Khasawinah AM, Hardy CJ, Clark GC. 1989. Comparative inhalation toxicity of technical chlordane in rats and monkeys. J Toxicol Environ Health 28:327–347.2585538
*Kilburn KH, Thornton JC. 1995. Protracted neurotoxicity from chlordane sprayed to kill termites. Environ Health Perspect 103(7–8):690–694.7588480
King, KA, Krynitsky, AJ. 1986. Population trends, reproductive success and organochlorine chemical contaminants in waterbirds nesting in Galveston Bay, Texas. Arch Environ Contam Toxicol 15:367–376.3740946
Kinoshita FK, Kempf CK. 1970. Quantitative measurement of hepatic microsomal enzyme induction after dietary intake of chlorinated hydrocarbon insecticides [Abstract]. Toxicol Appl Pharmacol 17:288.
*Kinoshita FK, Frawley JP, DuBois KP. 1966. Quantitative measure of induction of hepatic microsomal enzymes by various dietary levels of DDT and toxaphene in rats. Toxicol Appl Pharmacol 9:505–513.
*Klaas EE, Belisle AA. 1977. Organochlorine pesticide and polychlorinated biphenyl residues in selected fauna from a New Jersey salt marsh: 1967 vs. 1973. Pestic Monit J 10:149–158.404626
*Klaas EE, Ohlendorf HM, Cromartie E. 1980. Organochlorine residues and shell thickness in eggs of clapper rail, common gallinule, purple gallinule, and limpkin (class Aves), Eastern and Southern United States, 1972-1974. Pestic Monit J 14:90–94.6780971
*Knap AH, Binkley KS. 1991. Chlorinated organic compounds in the troposphere over the Western North Atlantic Ocean measured by aircraft. Atmos Environ 25A:1507–1516.
*Knap AH, Binkley KS, Artz RS. 1988. The occurrence and distribution of trace organic compounds in Bermuda precipitation. Atmos Environ 22:1411–1423.
Korfmacher WA, Rushing LG, Siitonen PM, . 1987. Confirmation of heptachlor epoxide and octachlor [chlordane] epoxide in milk via fused-silica gas chromatography negative-ion chemical ionization mass spectrometry. J High Resolut Chromatogr Commun 10:332–336.
*Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Kuehl DW, Haebler R, Potter C. 1991. Chemical residues in dolphins from the U.S. Atlantic coast including Atlantic bottlenose obtained during the 1987/88 mass mortality. Chemosphere 22:1071–1084.
*Kuehl DW, Leonard EN, Butterworth BC, . 1983. Polychlorinated chemical residues in fish from major watersheds near the Great Lakes, 1979. Environ Int 9:293–299.
*Kuehl DW, Leonard EN, Welch KJ, . 1980. Identification of hazardous organic chemicals in fish from the Ashtabula River, Ohio, and Wabash River, Indiana. J Assoc Off Anal Chem 63:1238–1244.6778854
*Kuntz KW, Warry ND. 1983. Chlorinated organic contaminants in water and suspended sediments of the lower Niagara River. J Great Lakes Res 9:241–248
*Kutz FW. 1983. Chemical exposure monitoring. Residue Rev 85:277–292.6828798
*Kutz FW, Strassman SC, Sperling JF. 1979. Survey of selected organochlorine pesticides in the general population of the United States. Ann N Y Acad Sci 320:60–68.287404
*Kutz FW, Strassman SC, Sperling JF, . 1983. A fatal chlordane poisoning. J Toxicol Clin Toxicol 20:167–174.6887309
*Kutz FW, Wood PH, Bottimore DP. 1991. Organochlorine pesticides and polychlorinated biphenyls in human adipose tissues. Rev Environ Contam Toxicol 120:1–82.1899728
*Kutz FW, Yobs AR, Strassman SC. 1976. Organochlorine pesticide residues in human adipose tissue. Bull Soc Pharmacol Environ Pathol 4:17–19.
*Lau YL, OIiver BG, Krishnappan BG. 1989. Transport of some chlorinated contaminants by the water, suspended sediments, and bed sediments in the St. Clair and Detroit Rivers. Environ Toxicol Chem 8:293–301.
*Law LM, Goerlitz DF. 1974. Selected chlorinated hydrocarbons in bottom material from streams tributary to San Francisco Bay. Pestic Monit J 8:33–36.4216004
*Lawrence JH, Ban-on RP, Chen JYT; . 1970. Note on identification of a chlordane metabolite found in milk and cheese. J Assoc Off Anal Chem 53:261–262.
*Layher WG, Wood RD, Lambley D, . 1985. Pesticide residues in Kansas pheasants. Bull Environ Contam Toxicol 34:317–322.3978269
*LeBel GL, Williams DT. 1986. Determination of halogenated contaminants in human adipose tissue. J Assoc Off Anal Chem 69:451–458.3722093
*Lee DH, Steffes MW, Sjodin A, . 2010. Low dose of some persistent organic pollutants predicts type 2 diabetes: A nested case-control study. Environ Health Perspect 118(9):1235–1242. 10.1289/ehp.0901480.20444671
*Lehman AJ. 1951. Chemicals in foods: A report to the association of food and drug officials on current developments. Part II. Pesticides. Association of Food and Drug Officials Quarterly Bulletin 15:122–133.
*Leidy RB, Wright CG, Dupree Jr HE, . 1985. Subterranean termite control: Chlordane residues in soil surrounding and air within houses. American Chemical Society Symposium Series 273:265–277.
*Leidy RB, Wright CG. 1991. Trapping efficiency of selected adsorbents for various airborne pesticides. J Environ Sci Health [B] 26:367–382.
*Leiker TJ, Rostad CE, Barnes CR, . 1991. A reconnaissance study of halogenated organic compounds in catfish from the lower Mississippi River and its major tributaries. Chemosphere 23:817–830.
*Lensky P, Evans M. 1952. Human poisoning by chlordane. J Am Med Assoc 149:1394.14938194
*Leone AD, Amato S, Falconer RL. 2001. Emission of chiral organochlorine pesticides from agricultural soils in the cornbelt region of the U.S. Environ Sci Technol 35:4592–4596.11770760
*Lewis RG, Lee Jr RE. 1976. Air pollution from pesticides: Sources, occurrence and dispersion. In: Lee RE, ed. Air pollution from pesticide and agricultural processes. Cleveland, OH: CRC Press, 551.
*Lewis RG, Bond AE, Fitz-Simons TR, . 1986. Monitoring for non-occupational exposure to pesticides in indoor and personal respiratory air. In: Proceedings of the Air Pollution Control Association 79th Annual Meeting.
*Lewis RG, Bond AE, Johnson DE, . 1988. Measurement of atmospheric concentrations of common household pesticides: A pilot study. Environ Monit Assess 10:59–73.24248528
*Lichtenstein EP, Schulz KR. 1959. Persistence of some chlorinated hydrocarbon insecticides as influenced by soil types, rates of application, and temperature. J Econ Entomol 52:124–131.
*Livingston JM, Jones CR. 1981. Living area contamination by chlordane used for termite treatment. Bull Environ Contam Toxicol 27:406–411.7296075
Lopez-Avila V, Schoen S, Milanes J, . 1988. Single-laboratory evaluation of EPA Method 8080 for determination of chlorinated pesticides and polychlorinated biphenyls in hazardous wastes. J Assoc Off Anal Chem 71:375–387.2838450
Lopez-Avila V, Dodhiwala NS, Beckert WF. 1990a. Supercritical fluid extraction and its application to environmental analysis. J Chromatogr Sci 28:468–476.
Lopez-Avila V, Wesselman R, Edge11 K. 1990b. Gas chromatographic-electron capture detection method for determination of 29 organochlorine pesticides in finished drinking water: Collaborative study. J Assoc Off Anal Chem 73:276–286.2324039
*Louis JB, Kisselbach Jr KC. 1987. Indoor air levels of chlordane and heptachlor following termiticide applications. Bull Environ Contam Toxicol 39:91l–918.
*Lundholm CE. 1988. The effects of DDE, PCB and chlordane on the binding of progesterone to its cytoplasmic receptor in the eggshell gland mucosa of birds and the endometrium of mammalian uterus. Comp Biochem Physiol 89C:361–368.
*Lyman WJ. 1982. Adsorption coefficient for soils and sediments. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York: McGraw Hill Book Co., Chapter 4.
*Mackay D, Paterson S, Schroeder WH. 1986. Model describing the rates of transfer processes of organic chemicals between atmosphere and water. Environ Sci Technol 20:810–816.22196707
*MacMahon B, Mason RR, Wang HH, . 1988. A second follow-up of mortality in a cohort of pesticide applicators. J Occup Med 30:429–432.3373347
*Maddy KT, Johnson L, Cusick B, . 1979. A study in southern California in July 1979 of the potential dermal and inhalation exposure of applicators and other persons who might later enter or occupy areas treated with chlordane used against subterranean termites under houses. California Department of Food and Agriculture, Worker Health and Safety Unit, Division of Pest Management, Environmental Protection, and Worker Safety, Sacramento, CA.
*Maguire RJ, Kuntz KW, Hale EJ. 1983. Chlorinated hydrocarbons in the surface microlayer of the Niagara River. J Great Lakes Res 9:281–286.
*Mahon DC. 1977. Interactions, in rats, between carbon tetrachloride-induced liver cirrhosis and chronic treatment with the organochlorine insecticide chlordane [Abstract]. Diss Abstr Int 38(9):4012B.
*Mahon DC, Oloffs PC, Hardwick DF. 1978. Interactions, in rats, between CCl_4_-induced liver cirrhosis and chronic treatment with the organochlorine insecticide chlordane. Clin Biochem 11:435–438.
*Malarkey DE, Devereux TR, Dinse GE, . 1995. Hepatocarcinogenicity of chlordane in B6C3F1 and B6D2F1 male mice: Evidence for regression in B6C3F_1_ mice and carcinogenesis independent of ras proto-oncogene activation. Carcinogenesis 16(11):2617–2625.7586176
Manske DD, Corneliussen PE. 1974. Residues in food and feed. Pesticide residues in total diet samples. VII. Pestic Monit J 8:110–124.4475396
*Manske DD, Johnson RD. 1975. Residues in food and feed. Pesticide residues in total diet samples. VIII. Pestic Monit J 9:94–105.1208189
*Manske DD, Johnson RD. 1977. Residues in food and feed. Pesticide and other chemical residues in total diet samples. X. Pestic Monit J 10:134–148.857241
Marcus JM, Renfrow RT. 1990. Pesticides and PCBs in South Carolina estuaries. Mar Pollut Bull 21:96–99.
*Martin RJ, Duggan RE. 1968. Pesticide residues in total diet samples. III. Pestic Monit J 1:11–20.
*Martin H, Worthing CR, Eds. 1977. Pesticide Manual. 5th ed. British Crop Protection Council, 93.
*Martinez A, Erdman NR, Rodenburg ZL, . 2012. Spatial distribution of chlordanes and PCB congeners in soil in Cedar Rapids, Iowa, USA. Environ Pollut 161:222–228.22230089
*Marsalek J, Schroeter H. 1988. Annual loadings of toxic contaminants in urban runoff from the Canadian Great Lakes Basin. Water Pollut Res J Can 23:360–378.
*Maslansky CJ, Williams GM. 1981. Evidence for an epigenetic mode of action in organochlorine pesticide hepatocarcinogenicity: A lack of genotoxicity in rat, mouse, and hamster hepatocytes. J Toxicol Environ Health 8:121–130.7328699
*Matin MA, Kar PP, Hasan MZ, . 1977. Comparison of the chronic effects of alpha-chlordane and pp’ DDT on the level of cerebral amino acids and free ammonia in mice. Pharmacol Res Commun 9:613–619.896901
*McConnachie PR, Zahalsky AC. 1992. Immune alterations in humans exposed to the termiticide technical chlordane. Arch Environ Health 47:295–301.1497384
*McEwen LC, Stafford CJ, Hensler GL. 1984. Organochlorine residues in eggs of black-crowned night herons from Colorado and Wyoming. Environ Toxicol Chem 3:367–376.
*McGlynn KA, Quraishi SM, Graubard BI, . 2008. Persistent organochlorine pesticides and risk of testicular germ cell tumors. J Natl Cancer Inst 100(9):663–671. 10.1093/jnci/djn101.18445826
*McGregor DB, Brown A, Cattanach P, . 1988. Responses of the L5178Y tk+/tk− mouse lymphoma cell forward mutation assay: III. 72 coded chemicals. Environ Mol Mutagen 12:85–154.3383842
*Menconi S, Clark JM, Langenberg P, . 1988. A preliminary study of potential human health effects in private residences following chlordane applications for termite control. Arch Environ Health 431:349–352.
*Menna H, Barnett JB, Soderberg LSF. 1985. Influenza Type A virus infection of mice exposed in utero to chlordane; survival and antibody studies. Toxicol Lett 24:45–52.2983457
*Mes J, Marchand L, Davies DJ. 1990. Organochlorine residues in adipose tissue of Canadians. Bull Environ Contam Toxicol 45:681–688.2124937
*Mes J. 1992. Organochlorine residues in human blood and biopsy fat and their relationship. Bull Environ Contam Toxicol 48:815–820.1568057
*Millner GC, Shaddock JG, Harbison RD, . 1988. A comparison between the in vitro DNA repair assay and the in vivo/in vitro DNA repair and DNA replicative synthesis assays for detecting hepatocarcinogens [Abstract]. Environ Mol Mutagen 11:70.
*Mills PK, Yang R. 2005. Breast cancer risk in Hispanic agricultural workers in California. Int J Occup Environ Health 11(2):123–131. 10.1179/oeh.2005.11.2.123.15875887
*Minyard JP, Roberts WE. 1991. State findings of pesticide residues in foods - 1988 and 1989. J Assoc Off Anal Chem 74:438–452.1874687
*Miyagi T, Lam KM, Chuang LF, . 1998. Suppression of chemokine-induced chemotaxis of monkey neutrophils and monocytes by chlorinated hydrocarbon insecticides. In Vivo 12(5):441–445. (Retrieval in progress)9827349
*Miyazaki T, Yamagishi T, Matsumoto M. 1985. Isolation and structure elucidation of some components in technical grade chlordane. Arch Environ Contam Toxicol 14:475–483.
*Montgomery MP, Kamel F, Saldana TM, . 2008. Incident diabetes and pesticide exposure among licensed pesticide applicators: Agricultural Health Study, 1993-2003. Am J Epidemiol 167(10):1235–1246. 10.1093/aje/kwn028.18343878
*Moreau-Guigon E, Motelay-Massei A, Harner T, . 2007. Vertical and temporal distribution of persistent organic pollutants in Toronto. 1. Organochlorine pesticides. Environ Sci Technol 41(7):2172–2177.17438759
*Mortelmans K, Haworth S, Lawlor T, . 1986. Salmonella mutagenicity tests: II. Results from the testing of 270 chemicals. Environ Mutagen 8:1–119.
*Moser GJ, Smart RC. 1989. Hepatic tumor-promoting chlorinated hydrocarbons stimulate protein kinase C activity. Carcinogenesis 10:851–856.2706741
*Moser VC, Cheek BM, MacPhail RC. 1995. A multidisciplinary approach to toxicological screening: III. Neurobehavioral toxicity. J Toxicol Environ Health 45(2):173–210. 10.1080/15287399509531988.7783252
*Moye HA, Malagodi MH. 1987. Levels of airborne chlordane and chlorpyrifos in two plenum houses: Saranex S-15 as a vapor barrier. Bull Environ Contam Toxicol 39:533–540.2444294
*Mullins DE Johnson RE, Starr RI. 1971. Persistence of organochlorine insecticide residues in agricultural soils in Colorado. Pestic Monit J 5:368–375.
*Muir DCG, Norstrom RJ, Simon M. 1988. Organochlorine contaminants in Arctic marine food chains: Accumulation of specific polychlorinated biphenyls and chlordane-related compounds. Environ Sci Technol 22:1071–1079.22148662
*Murphy RS, Kutz FW, Strassman SC. 1983. Selected pesticide residues or metabolites in blood and urine specimens from a general population survey. Environ Health Perspect 48:81–86.6825639
*Mussalo-Rauhamaa H. 1991. Partitioning and levels of neutral organochlorine compounds in human serum, blood cells, and adipose and liver tissue. Sci Total Environ 103:159–175.1909054
*Mussalo-Rauhamaa H, Pyysalo H, Antervo K. 1988. Relation between the content of organochlorine compounds in Finnish human milk and characteristics of the mothers. J Toxicol Environ Health 25:119.3418742
*Nagayama J, Kohno H, Kunisue T, . 2007. Concentrations of organochlorine pollutants in mothers who gave birth to neonates with congenital hypothyroidism. Chemosphere 68(5):972–976. 10.1016/j.chemosphere.2007.01.010.17307219
*Nam KS, Kapila S, Viswanath DS, . 1989. Application of supercritical fluid extraction of biological tissue samples for the determination of polychlorinated organics. Chemosphere 19:33–38.
*Nam KS, Kapila S, Yanders AF, . 1990. Supercritical fluid extraction and cleanup procedures for determination of xenobiotics in biological samples. Chemosphere 20:873–880.
*Narotsky MG, Kavlock RJ. 1995. A multidisciplinary approach to toxicological screening: II. Developmental toxicity. J Toxicol Environ Health 45(2):145–171. 10.1080/15287399509531987.7783251
*Nash RG. 1983a. Comparative volatilization and dissipation rates of several pesticides from soil. J Agric Food Chem 31:210–217.
*Nash RG. 1983b. Determining environmental fate of pesticides with microagroecosystems. Residue Rev 85:199–215.
*Nash RG, Woolson EA. 1967. Persistence of chlorinated hydrocarbon insecticides in soils. Science 157:924–927.17792829
*NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
*NCI. 1977. National Cancer Institute. Bioassay of chlordane for possible carcinogenicity. Technical Report Series No. 8. U.S. Department of Health, Education and Welfare. NIH publication no. 77-808.
*Nightingale HI. 1987. Organic pollutants in soils of retention and recharge basins receiving urban runoff water. Soil Sci 144:373–382.
*NIOSH. 1984a. Health hazard evaluation report HETA 83-444-1481. Georgetown University, Washington, DC. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. PB85220895.
*NIOSH. 1984b. Health hazard evaluation report HETA 83-424-1403. Ozark National Scenic Riverways, Van Buren, MO. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
*NIOSH. 1988. Registry of Toxic Effects of Chemical Substances (RTECS). Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
*NIOSH. 1989a. National Occupation Exposure Survey. Cincinnati, OH. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
*NIOSH. 1989b. NIOSH manual of analytical methods. 3rd ed. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Center of Disease Control, National Institute for Occupational Safety and Health, 5510-l to 5510-4.
*NIOSH. 1992. NIOSH recommendations for occupational safety and health. Compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 60.
*NIOSH. 2014. Chlordane. Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/idlh/57749.html. July 26, 2017.
*NIOSH. 2016. Chlordane. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0112.html. July 26, 2017.
*Nomeir AA, Hajjar NP. 1987. Metabolism of chlordane in mammals. Rev Environ Contam Toxicol 100:l–22.
*NRC. 1982. National Research Council. An assessment of the health risks of seven pesticides used for termite control. Prepared for Department of Navy, Washington, DC. PB83136374.
*NRCC. 1974. Chlordane: Its effects on Canadian ecosystems and its chemistry. Ottawa, Canada: National Research Council of Canada. NRCC no. 14094.
*NTP. 2016. Report on Carcinogens, Fourteenth Edition. CASRN Index in MS Excel. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. February 28, 2017.
*Nye DE, Dorough HW. 1976. Fate of insecticides administered endotracheally to rats. Bull Environ Contam Toxicol 15:29 l–296.
*Oehme M. 1991. Dispersion and transport paths of toxic persistent organochlorines to the Arctic; levels and consequences. Sci Total Environ 106:43–53.1948014
*Offenberg JH, Naumova YY, Turpin BJ, . 2004. Chlordanes in the indoor and outdoor air of three U.S. cities. Environ Sci Technol 38(10):2760–2768.15212248
*Ogata M, Izushi F. 1991. Effects of chlordane on parameters of liver and muscle toxicity in man and experimental animals. Toxicol Lett 56:327–337.2035178
*Ogata M, Izushi F, Eto K, . 1989. Effect of chlordane of hepatic mitochondrial respiration. Toxicol Lett 48:67–74.2749781
*Ohlendorf HM, Harrison CS. 1986. Mercury, selenium, cadmium and organochlorines in eggs of three Hawaiian (USA) seabird species. Environ Pollut B 11:169–192.
*Ohlendorf HM, Swineford DM, Locke LN. 1981. Organochlorine residues and mortality of herons. Pestic Monit J 14:125–135.6793997
*OHM-TADS. 1988. Oil and Hazardous Materials Technical Assistance Data System. U.S. EPA-NIH (U.S. Environmental Protection Agency-National Institute of Health). August 12, 1988.
*Ohno Y, Kawanishi T, Takahashi A. 1986. Comparisons of the toxicokinetic parameters in rats determined for low and high dose of γ-chlordane. J Toxicol Sci 11:111–124.3723612
*Olanoff LS, Bristow WJ, Colcolough J, . 1983. Acute chlordane intoxication. J Toxicol Clin Toxicol 20:29l–306.
*Oliver BG, Niimi AJ. 1985. Bioconcentration factors of some halogenated organics for rainbow trout, limitation in their use for predictions. Environ Sci Technol 19:842–849.22196610
*Oloffs PC, Albright LJ, Szeto SY. 1972. Fate and behavior of five chlorinated hydrocarbons in three natural waters. Can J Microbial 18:1393–1398.
*Oloffs PC, Albright LJ, Szeto SY, . 1973. Factors affecting the behavior of five chlorinated hydrocarbons in two natural waters and their sediments. J Fish Res Board Can 30:1619–1623.
*Onuska FI, Comba ME. 1975. Isolation and characterization of the photoalteration products of cis and trans-chlordane. J Assoc Off Anal Chem 58:6–9.1141156
Orazio CE, Kapila S, Puri RK, . 1990. Field and laboratory studies on sources and persistence of chlordane contamination in the Missouri aquatic environment. Chemosphere 20:1581–1588.
*Ortega P, Hayes WJ, Durham WF. 1957. Pathologic changes in the liver of rats after feeding low levels of various insecticides. AMA Arch Pathol 64:614–622.13478250
*OSHA. 1989. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
*OSHA. 2016a. Subpart D Occupational health and environment controls. Section 1926.55 - Gases, vapors, fumes, dusts, and mists. Appendix A to Part 1926.55 - threshold limit values of airborne contaminants for construction. Occupational Safety and Health Standards. Code of Federal Regulations. 29 CFR 1926.55. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol8/pdf/CFR-2016-title29-vol8-sec1926-55.pdf. March 6, 2017.
*OSHA. 2016b. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Standards. Code of Federal Regulations. 29 CFR 1910.1000. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol6/pdf/CFR-2016-title29-vol6-sec1910-1000.pdf. March 6, 2017.
*OSHA. 2016c. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z - Shipyards. Occupational Safety and Health Standards. Code of Federal Regulations. 29 CFR 1915.1000. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol7/pdf/CFR-2016-title29-vol7-sec1915-1000.pdf. March 6, 2017.
OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment, U.S. Congress. OTA-BA-438, April 1990.
*Pacyna JM, Oehme M. 1988. Long-range transport of some organic compounds to the Norwegian Arctic. Atmos Environ 22:243–257.
*Page GW. 1981. Comparison of groundwater and surface water for patterns and levels of contamination by toxic substances. Environ Sci Technol 15:1475–1481.
*Parlar. 1978. [Transformation of some cyclodiene pesticides on leaf surfaces by the action of sunlight.] Chemosphere 7:721–728. (German)
*Parlar H, Korte F. 1973. [Studies on ecologic chemistry. LX: Photochemistry of chlordane derivatives.] Chemosphere 2:169–172. (German)
*Parlar H, Korte F. 1977. Photoreactions of cyclodiene insecticides under simulated environmental conditions. Chemosphere 6:665–705.
*Parlar H, Korte F. 1979. Photokinetic evaluation of dechlorination reactions of cyclodiene pesticides. Chemosphere 8:873–876.
*Parlar H, Korte F. 1980. [Phototransformation products of chlordane derivatives and their pesticidal activity.] Chemosphere 9:55–58. (German)
*Parlar H, Hustert K, Gaeb S, . 1979. Isolation, identification, and chromatographic characterization of some chlorinated C_10_ hydrocarbons in technical chlordane. J Agric Food Chem 27:278–283.
*Patton GW, Walla MD, Bidleman TF, . 1991. Polycyclic aromatic and organochlorine compounds in the atmosphere of northern Ellesmere Island, Canada. J Geophys Res 96:10,867–10,877.
*Peterman PH, Delfino JJ, Dube DJ, . 1980. Chloro-organic compounds in the Lower Fox River, Wisconsin. Environ Sci Res 16:145– 160.
*Phillips LJ, Birchard GF. 1991. Use of STORET data to evaluate variations in environmental contamination by census division. Chemosphere 22:835–848.
*Plumb Jr RH. 1991. The occurrence of Appendix IX organic constituents in disposal site ground water. Ground Water Monit Rev 11:157–164.
*Podowski AA, Banerjee BC, Feroz M, . 1979. Photolysis of heptachlor and cis-chlordane and toxicity of their photoisomers to animals. Arch Environ Contam Toxicol 8:509–518.539835
*Podrebarac DS. 1984a. Pesticide, metal, and other chemical residues in adult total diet samples. XIV. October 1977-September 1978. J Assoc Off Anal Chem 67:176–185.6546568
*Podrebarac DS. 1984b. Pesticide, heavy metal, and other chemical residues in infant and toddler total diet samples. IV. October 1977-September 1978. J Assoc Off Anal Chem 67:166–175.6546567
*Poonawalla NH, Korte F. 1964. Metabolism of insecticides. VIII (1): Excretion, distribution and metabolism of α-chlordane-^14^C by rats. Life Sci 3:1497–1500.
*Poonawalla NH, Korte F. 1971. Metabolism of trans-chlordane-^14^C and isolation and identification of its metabolites from the urine of rabbits. J Agric Food Chem 19:467–470.5131143
*Princi F, Spurbeck GH. 1951. A study of workers exposed to the insecticides chlordane, aldrin, dieldrin. Arch Ind Hyg Occup Med 3:64–72.
*Probst GS, Hill LE. 1981. Chemically induced DNA repair synthesis in primary rat hepatocytes: A correlation with bacterial mutagenicity. Ann N Y Acad Sci 349:405–406.
*Prouty RM, Bunck CM. 1986. Organochlorine residues in adult mallard and black duck wings, 198l-l982. Environ Monit Assess 6:49–57.24254543
*Purdue MP, Hoppin JA, Blair A, . 2006. Occupational exposure to organochlorine insecticides and cancer incidence in the Agricultural Health Study. Int J Cancer 120(3):642–649.
*Puri RK, Orazio CE, Kapila S, . 1990. Studies on the transport and fate of chlordane in the environment. In: Kurtz DA, ed. Long range transport of pesticides. Chelsea, MI: Lewis Publishers, 271–280.
*Quintana PJ, Delfino RJ, Korrick S, . 2004. Adipose tissue levels of organochlorine pesticides and polychlorinated biphenyls and risk of non-Hodgkin’s lymphoma. Environ Health Perspect 112(8):854–861.15175172
*Rashid KA, Mumma RO. 1986. Screening pesticides for their ability to damage bacterial DNA. J Environ Sci Health B 21:319–334.3531299
*Rathbun RE. 1992. Transport and degradation of organic substances in streams. U.S. Department of the Interior, U.S. Geological Survey, Water Resources Division, North-Central Colorado
*Ray LE, Murray HE, Giam CS. 1983. Organic pollutants in marine samples from Portland, Maine. Chemosphere 12:1031–1038.
*Reding R. 1987. Chromatographic monitoring methods for organic contaminants under the Safe Drinking Water Act. J Chromatogr Sci 25:338–344.
*RePORTER. 2017. Chlordane. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. August 30, 2017.
*Requejo AG, West RH, Hatcher PG, . 1979. Polychlorinated biphenyls and chlorinated pesticides in soils of the Everglades National Park and adjacent agricultural areas. Environ Sci Technol 13:931–935.
*Reuber MD. 1978. Carcinomas and other lesions of the liver in mice ingesting organochlorine pesticides. Clin Toxicol 13:231–256.216523
*Rhainds M, Levallois P, Dewailly E, . 1999. Lead, mercury, and organochlorine compound levels in cord blood in Quebec, Canada. Arch Environ Health 54(1):40–47.10025415
*Ritchie JM, Vial SL, Fuortes LJ, . 2003. Organochlorines and risk of prostate cancer. J Occup Environ Med 45(7):692–702. 10.1097/01.jom.0000071510.96740.0b.12855910
*Ritter WF. 1990. Pesticide contamination of groundwater in the United States- A review. J Environ Sci Health 25:1–31.
Rodriguez OM, Desideri PG, Lepri L, . 1991. Simultaneous separation and determination of hydrocarbons and organochlorine compounds by using a two-step microcolumn. J Chromatogr 555:221–228.1723731
*Roper EM, Wright CG. 1984. Sampling efficiency of five solid sorbents for trapping air-borne pesticides. Bull Environ Contam Toxicol 33:476–483.6487842
*Rought SE, Yau PM, Chuang LF, . 1999. Effect of the chlorinated hydrocarbons heptachlor, chlordane, and toxaphene on retinoblastoma tumor suppressor in human lymphocytes. Toxicol Lett 104(1–2):127–135.10048758
*Rumack BH, Lovejoy Jr FH. 1991. Clinical toxicology. In: Amdur MO, Doull J, Klaasen CD, eds. Casarett and Doull’s toxicology: The basic science of poisons, 4th ed. New York, NY: Pergamon Press, 924–946.
*Ruth RJ, Fransson R, Flodstrom S, . 1990. Inhibition of hepatocyte gap junctional intercellular communication by endosulfan, chlordane and heptachlor. Carcinogenesis 11:1097–l101.2372869
*Saiki MK, Schmitt CJ. 1986. Organochlorine chemical residues in bluegills and common carp from the irrigated San Joaquin Valley floor, California. Arch Environ Contam Toxicol 15:357–366.
*Saito I, Kawamura N, Uno K, . 1985. Determination of chlordane in human blood by gas chromatography. Analyst 110:263–267.3993959
*Saito I, Kawamura N, Uno K, . 1986. Relationship between chlordane and its metabolites in blood of pest control operators and spraying conditions. Arch Ind Hyg Occup Med 58:91–97.
*Sanbom JR, Metcalf RL, Bruce WN, . 1976. The fate of chlordane and toxaphene in a terrestrial-aquatic model ecosystem. Environ Entomol 5:533–538.
*Sanders M, Haynes BL. 1988. Distribution pattern and reduction of polychlorinated biphenyls PCB in bluefish Pomatomus-saltutrix (Zinnueus) fillets through adipose tissue removal. Bull Environ Contam Toxicol 41:670–677.3148339
*Santolucito JA, Whitcomb E. 1971. Mechanical response of skeletal muscle following oral administration of pesticides. Toxicol Appl Pharmacol 20:66–72.4999915
*Sarkar D, Sharma A, Talukder G. 1993. Differential protection of chlorophyllin against clastogenic effects of chromium and chlordane in mouse bone marrow in vivo. Mutat Res 301(1):33–38.7677941
*Sasaki K, Ishizaka T, Suzuki T, . 1991a. Accumulation levels of organochlorine pesticides in human adipose tissue and blood. Bull Environ Contam Toxicol 46:662–669.1710156
*Sasaki K, Ishizaka T, Suzuki T, . 1991b. Organochlorine chemicals in skin lipids as an index of their accumulation in the human body. Arch Environ Contam Toxicol 21:190–l94.1958075
*Sasaki K, Kawasaki Y, Sekita K, . 1992. Disposition of β-hexachlorocyclohexane, p,p’-DDT, and trans-chlordane administered subcutaneously to monkeys (Mucuca-fusciculuriss). Arch Environ Contam Toxicol 22:25–29.1372798
*Satoh A, Kikawa H, 1992. Metabolic fate of cis-and trans-chlordane in mice. Jpn J Hyg 47:818–825.
*Sawada N, Iwasaki M, Inoue M, . 2010. Plasma organochlorines and subsequent risk of prostate cancer in Japanese men: A nested case-control study. Environ Health Perspect 118(5):659–665. 10.1289/ehp.0901214.20435560
*Sauer TC Jr, Durell GS, Brown JS, . 1989. Concentrations of chlorinated pesticides and PCBs in microlayer and seawater samples collected in open-ocean waters off the U.S. East Coast and in the Gulf of Mexico. Mar Chem 27:235–257.
*Savage EP, Keefe TJ, Tessari JD, . 1981. National study of chlorinated hydrocarbon insecticide residues in human milk, USA. Am J Epidemiol 113:413–422.7211826
Savage EP. 1989. Termiticide use and indoor air quality in the United States. Rev Environ Contam Toxicol 110:117–130.2692087
*Schafer ML, Peeler JT, Gardner WS, . 1969. Pesticides in drinking water: Water from the Mississippi and Missouri Rivers. Environ Sci Technol 3:1261–1269.
*Schattenberg HJ III, Hsu JP. 1992. Pesticide residue survey of produce from 1989-1991. J AOAC Int 75:925–933.
*Schick CT, Brennan LA, Buchanan JB, . 1987. Organochlorine contamination in shorebirds from Washington state and the significance for their falcon predators. Environ Monit Assess 9:115–131.24254183
*Schmitt CJ, Zajicek JL, Peterman PH. 1990. National contaminant biomonitoring program: Residues of organochlorine chemicals in USA freshwater fish, 1976- 1984. Arch Environ Contam Toxicol 19:748–781.21318506
*Schmitt CJ, Zajicek JL, Ribick MA. 1985. National pesticide monitoring program: Residues of organochlorine chemicals in freshwater fish, 1980-81. Arch Environ Contam Toxicol 14:225–260.3920980
*Schop RN, Hardy MH, Goldberg, MT. 1990. Comparison of the activity of topically applied pesticides and the herbicide 2,4-D in two short-term in vivo assays of genotoxicity in the mouse. Fundam Appl Toxicol 15:666–675.2086312
Schuetz EG, Wrighton SA, Safe SH, . 1986. Regulation of cytochrome P-450 by phenobarbital and phenobarbital-like inducers in adult rat hepatocytes in primary monolayer culture and in vivo. Biochemistry 25:1124–1133.3083864
*Sears MK, Chapman RA. 1979. Persistence and movement of four insecticides applied to turfgrass. J Econ Entomol 72:272–274.
*Sericano JL, Atlas EL, Wade TL, . 1990. NOAA’s status and trends mussel watch program: Chlorinated pesticides and PCBs in oysters (Crassostrea virginica) and sediments from the Gulf of Mexico, 1986-1987. Mar Environ Res 29:161–203.
*Sethunathan N. 1973. Microbial degradation of insecticides in flooded soil and in anaerobic cultures. Residue Rev 47:143–166.4127764
*Shain SA, Shaeffer JC, Boesel RW. 1977. The effect of chronic ingestion of selected pesticides upon rat ventral prostate homeostasis. Toxicol Appl Pharmacol 40:115–130.867426
*Shen L, Wania F, Lei YD, . 2005. Atmospheric distribution and long-range transport behavior of organochlorine pesticides in North America. Environ Sci Technol 39(2):409–420.15707039
*Shindell S, Ulrich S. 1986. Mortality of workers employed in the manufacture of chlordane: An update. J Occup Med 28:497–501.3734918
*Simmon VF, Kauhanen K, Tardiff RG. 1977. Mutagenicity activity of chemicals identified in drinking water. Dev Toxicol Environ Sci 2:249–258.
*Singh G Higginson FR, Fenton IG, . 1990. Translocation of aged cyclodiene insecticide residues from soil into forage crops under optimal glasshouse conditions. J Environ Sci Health B 25:295–308.
*Singh G Kathpal TS, Spencer WF, . 1991. Dissipation of some organochlorine insecticides in cropped and uncropped soil. Environ Pollut 70:219–240.15092134
*Singhal RL and Kacew S. 1976. The role of cyclic AMP in chlorinated hydrocarbon-induced toxicity. Fed Proc 35:2618–2663.
*Sipes JG, Gandolfi AJ. 1991. Biotransformation of toxicants. In: Andur MO, Doull J, Klaassen CD, eds. Casarett and Doull’s toxicology. 4th ed. New York, NY: Pergamon Press, 112.
*Smith AG. 1991. Chlorinated hydrocarbon insecticides. In: Hayes Jr WJ, Laws Jr ER, eds. Handbook of pesticide toxicology, Vol. 2: Classes of pesticides. San Diego, CA: Academic Press, 731–915.
*Smith TJ, Wilcock RJ, Pridmore RD, . 1992. Persistence of chlordane applied to an intertidal sandflat. Bull Environ Contam Toxicol 49:129–136.1392286
*Snyder WS, Cook MJ, Nosset ES, . 1981. Report of the Task Group on Reference Man ICRP Report No. 23. New York: Pergamon Press, 33–34.
*Sobti RC, Krishan A, Davies J. 1983. Cytokinetic and cytogenetic effect of agricultural chemicals on human lymphoid cells in vitro. II. Organochlorine pesticides. Arch Toxicol 52:221–231.6860144
*Speidel HK, Bourquin AW, Mann JE, . 1972. Microbiological removal of pesticides from aqueous environments. Develop Ind Microbial 13:277–282.
*Sperling KR, Janssen D, Wulf T. 1985. Gas chromatographic-mass spectrometric investigations on lipophilic anthropogenic substances in marine organisms. I. A clean-up procedure consisting of liquid-liquid and reversed phase (octadecyl)-partitioning. Fresenius J Anal Chem 320:1–5.
*Spinelli JJ, Ng CH, Weber JP, . 2007. Organochlorines and risk of non-Hodgkin lymphoma. Int J Cancer 121(12):2767–2775. 10.1002/ijc.23005.17722095
*Spyker DA, Bond RR, Jylkka M, . 1989. Subacute home chlordane poisoning fact or fallacy [Abstract]. Vet Hum Toxicol 31:356.
*Spyker-Cranmer JM, Barnett JB, Avery DL, . 1982. Immunoteratology of chlordane: Cell mediated and humoral immune responses in adult mice exposed in utero. Toxicol Appl Pharmacol 62:402–408.7041330
*SRI. 1988. 1988 Directory of Chemical Producers: United States of America. Menlo Park, CA: Stanford Research Institute International.
*SRI. 1990. 1991 Directory of chemical producers: United States of America. Menlo Park, CA: Stanford Research Institute.
*Stanley CW, Barney II JE, Helton MR, . 1971. Measurement of atmospheric levels of pesticides. Environ Sci Technol 5:430–435.
*Starr Jr HG, Aldrich FD, McDougall WD, . 1974. Contribution of household dust to the human exposure to pesticides. Pestic Monit J 8:209–212.4142653
*State of Kentucky. 1986. New or modified sources emitting toxic air pollution. 401 KAR 63:022.
*Steffey KL, Mack J, MacMonegle CW, . 1984. A ten-year study of chlorinated hydrocarbon insecticide residues in bovine milk in Illinois, 1972-1981. J Environ Sci Health B 19:49–65.6715791
*Steichen J, Koelliker J, Grosh D, . 1988. Contamination of farmstead wells by pesticides, volatile organics and inorganic chemicals in Kansas. Ground Water Monit Rev 8:153.
*Stenger RJ, Porway M, Johnson EA, . 1975. Effects of chlordane pretreatment on the hepatotoxicity of carbon tetrachloride. Exp Mol Pathol 23:144–153.1157888
*Stevens RJJ, Neilson MA. 1989. Inter- and intralake distributions of trace organic contaminants in surface waters of the Great Lakes. J Great Lakes Res 15:377–393.
*Stewart DKR, Chisholm D. 1971. Long-term persistence of BHC, DDT, and chlordane in a sandy loam soil. Can J Soil Sci 51:379–383.
*Stewart DKR, Fox CJS. 1971. Persistence of organochlorine insecticides and their metabolites in Nova Scotian soil. J Econ Entomol 64:367–371.
*Stohlman EF, Thorp WTS, Smith MI. 1950. Toxic action of chlordane. Arch Ind Hyg Occup Med 1:13.15419852
*Stohs SJ, Bagchi D, Bagchi M, . 1997. Generation of reactive oxygen species, DNA damage and lipid peroxidation in liver by structurally dissimilar pesticides. In: Liver and environmental xenobiotics. New Delhi, India: Narosa Publishing House, 102–113. (Retrieval in progress)
*Strachan WMJ. 1985. Organic substances in the rainfall of Lake Superior (USA, Canada): 1983. Environ Toxicol Chem 4:677–684.
*Strassman SC, Kutz FW. 1977. Insecticide residues in human milk from Arkansas and Mississippi, 1973-74. Pestic Monit J 10:130–133.854395
*Street JC, Blau SE. 1972. Oxychlordane. Accumulation in rat adipose tissue on feeding chlordane isomers or technical chlordane. J Agric Food Chem 20:395–397.5016622
*Sun P, Blatnchard P, Brice K, . 2006. Atmospheric organochlorine pesticide concentrations near the Great Lakes: temporal and spatial trends. Environ Sci Technol 40(21):6587–6593.17144282
*Suntio LR, Shiu WY, Mackay D, . 1988. Critical review of Henry’s law constants for pesticides. Rev Environ Contam Toxicol 103:1–59.
*Suzaki E, Inoue B, Okimasu E, . 1988. Stimulative effect of chlordane on the various functions of the guinea pig leukocytes. Toxicol Appl Pharmacol 93:137–145.2832973
*Swackhamer DL, Hites RA. 1988. Occurrence and bioaccumulation of organochlorine compounds in fishes from Siskiwit Lake, Isle Royale, Lake Superior. Environ Sci Technol 22:543–548.22195625
*Szaro RC, Coon NC, Kolbe E. 1979. Pesticide and PCB of common eider, herring gull and great black-backed gull eggs. Bull Environ Contam Toxicol 22:394–399.111743
*Szeto SY, Price PM. 1991. Persistence of pesticide residues in mineral and organic soils in the Fraser Valley of British Columbia. J Agric Food Chem 39:1679–1684.
*Tabak HH, Quave SA, Mashni CI, . 1981a. Biodegradability studies for predicting the environmental fate of organic priority pollutants. In: Test protocols for environmental fate and movement of toxicants. Symposium proceedings of the Association of Official Anal Chem 94th annual meeting, Washington, DC, 267–328.
*Tabak HH, Quave SA, Mashni CI, . 1981b. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
*Tafuri F, Businelli M, Scarponi L, . 1977. Decline and movement of AG chlordane in soil and its residues in alfalfa. J Agric Food Chem 25:353–356.838974
*Taguchi S, Yakushiji T. 1988. Influence of termite treatment in the home on the chlordane concentration in human milk. Arch Environ Contam Toxicol 17:65–72.3337553
*Takamiya K. 1987. Residual levels of plasma oxychlordane and trans-nonachlor in pest control operators and some characteristics of these accumulations. Bull Environ Contam Toxicol 39:750–755.3690000
*Takeda M, Sekita H, Sasaki K, . 1984. [Distribution of chlordane components in rat tissues after daily oral administration of technical chlordane at low levels.] Eisei Shikensho Hokoku 102:113–116. (Japanese)
*Takei GH, Kauahikaua SM, Leong GH. 1983. Analysis of human milk samples collected in Hawaii for residues of organochlorine pesticides and polychlorobiphenyls. Bull Environ Contam Toxicol 30:606–613.6407553
Talamantes F, Jang H. 1977. Effects of chlordane isomers administered to female mice during the neonatal period. J Toxicol Environ Health 3:713–720.592433
*Tanabe S, Falandysz J, Higaki T, . 1993. Polychlorinated biphenyl and organochlorine insecticide residues in human adipose tissue in Poland. Environ Pollut 79(1):45–49.15091912
*Tanita R, Johnson JM, Chun M, . 1976. Organochlorine pesticides in the Hawaii Kai Marina. Pestic Monit J 10:24–29.940734
*Tashiro S, Matsumura F. 1977. Metabolic routes of cis-and trans-chlordane in rats. J Agric Food Chem 25:872–880.881509
*Tashiro S, Matsumura F. 1978. Metabolism of trans-nonachlor and related chlordane components in rat and man. Arch Environ Contam Toxicol 7:113–127.666363
*Telang S, Tong C, Williams GM. 1981. Induction of mutagenesis by carcinogenic polycyclic aromatic hydrocarbons but not by organochlorine pesticides in the ARL/HGPRT mutagenesis assay [Abstract]. Environ Mutagen 3:35.
*Telang S, Tong C, Williams GM. 1982. Epigenetic membrane effects of a possible tumor promoting type on cultured liver cells by the nongenotoxic organochlorine pesticides chlordane and heptachlor. Carcinogenesis 3:1175.6293735
*Theus SA, Lau KA, Soderberg LSF, . 1990. Macrophage protein changes associated with prenatal chlordane exposure [Abstract]. Fed Am Soc Exp Biol 4:A1750.
*Theus SA, Lau KA, Tabor DR, . 1992. In vivo prenatal chlordane exposure induces development of endogenous inflammatory macrophages. J Leukoc Biol 51:366–372.1564400
*Thomas TC, Nishioka YA. 1985. Sampling and analytical procedures for evaluation of airborne chlordane levels in family quarters. Environ Toxicol Chem 4:143–147.
*Tojo Y, Wariishi M, Suzuki Y, . 1986. Quantitation of chlordane residues in mothers’ milk. Arch Environ Contam Toxicol 15:327–332.3740945
*Tong CC, Williams GM. 1988. Detection of neoplasm promoters in the hepatocyte-liver epithelial cell system. Prog Cancer Res Ther 34:161–178.
*Tong C, Fazio M, Williams GM. 1981. Rat hepatocyte-mediated mutagenesis of human cells by carcinogenic polycyclic aromatic hydrocarbons but not organochlorine pesticides. Proc Soc Exp Biol Med 167:572–575.6269115
*Trabert B, Longnecker MP, Brock JW, . 2012. Maternal pregnancy levels of trans-nonachlor and oxychlordane and prevalence of cryptorchidism and hypospadias in boys. Environ Health Perspect 120(3):478–482. 10.1289/ehp.1103936.21975279
*TRI90. 1992. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI16. 2017. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: U.S. Environmental Protection Agency, Office of Information Analysis and Access, Office of Environmental Information. Toxics Release Inventory. http://www.epa.gov/triexplorer/. September 29, 2017.
*Trotter WJ, Corneliussen PE, Lasaki RR, . 1989. Levels of polychlorinated biphenyls and pesticides in bluefish before and after cooking. J Assoc Off Anal Chem 72:501–503.2501293
*Truhaut R Gak JC, Graillot C. 1974. [Organochlorine insecticides; research work on their toxic action (its modalities and mechanisms): I. Comparative study of the acute toxicity on the hamster and the rat.] J Eur de Toxicol 7:159–166. (French)
*Truhaut R, Graillot C, Gak JC. 1975. [The problem of selecting animal species for assessing the toxicity of organochlorine pesticide residues for extrapolation to man. Comparative study of the sensitivity of the rat, mouse and hamster.] Comm Eur Communities, (Rep) EUR 5196:477–498. (French)
*Tryphonas H, Bondy G, Hodgen M, . 2003. Effects of cis-nonachlor, trans-nonachlor and chlordane on the immune system of Sprague-Dawley rats following a 28-day oral (gavage) treatment. Food Chem Toxicol 41(1):107–118.12453735
*Tsushimoto G, Chang CC, Trosko JE, . 1983. Cytotoxic, mutagenic, and cell-cell communication inhibitory properties of DDT, lindane, and chlordane on Chinese hamster cells in vitro. Arch Environ Contam Toxicol 12:721–729.6197034
*Tucker WA, Preston AL. 1984. Procedures for estimating atmospheric deposition properties of organic chemicals. Water Air Soil Pollut 21:247–260.
*Usami M, Kawashima K, Nakaura S, . 1986. [Effects of chlordane on prenatal development of rats.] Eisei Shikenso Hokoku 104:68–73. [Japanese]
*Veith GD, Kuehl DW, Leonard EN, . 1979. Polychlorinated biphenyls and other organic chemical residues in fish from major watersheds of the United States, 1976. Pestic Monit J 13:1–l1.114967
*Venkat JA, Shami S, Davis K, . 1995. Relative genotoxic activities of pesticides evaluated by a modified SOS microplate assay. Environ Mol Mutagen 25(1):67–76.7875128
*Verbrugge DA, Othoudt RA, Grzyb KR, . 1991. Concentrations of inorganic and organic contaminants in sediments of six harbors on the North American Great Lakes. Chemosphere 22:809–820.
*VIEW. 1988. Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. October 1988.
*Vogel E. 1980. Genetical relationship between resistance to insecticides and procarcinogens in two Drosophila populations. Arch Toxicol 43:201–211.7369868
*Vollner L, Parlar H, Klein W, . 1971. [Concentrations in ecological chemistry - XXXI. Photoreactions of components of technical chlordane.] Tetrahedron 27:501–509. (German).
*Wallace LA. 1991. Comparison of risks from outdoor and indoor exposure to toxic chemicals. Environ Health Perspect 95:7–13.1821381
*Wang HH, MacMahon B. 1979a. Mortality of workers employed in the manufacture of chlordane and heptachlor. J Occup Med 21:745–748.556268
*Wang HH, MacMahon B. 1979b. Mortality of pesticide applicators. J Occup Med 21:741–744.512718
*Ward EM, Schulte P, Grajewski B, . 2000. Serum organochlorine levels and breast cancer: A nested case-control study of Norwegian women. Cancer Epidemiol Biomarkers Prev 9(12):1357–1367.11142422
*Wariishi M, Nishiyama K. 1989. Observations on the progress of chlordane contamination in humans by blood and sebum analysis. Arch Environ Contam Toxicol 18:501–507.2774667
*Wariishi M, Suzuki Y, Nishiyama K. 1986. Chlordane residues in normal human blood. Bull Environ Contam Toxicol 36:635–643.3708166
*Weiderpass E, Adami HO, Baron JA, . 2000. Organochlorines and endometrial cancer risk. Cancer Epidemiol Biomarkers Prev 9(5):487–493.10815693
*Weil VL, Dure G, Quentin KE. 1974. [Water solubility of chlorinated hydrocarbon insecticides and polychlorinated biphenyls in regards to loadings of water bodies with these substances.] Wasser- und Abwasser-Forsch 7:169–175. (German)
*Welch RM, Harrison Y. 1966. Reduced drug toxicity following insecticide treatment [Abstract], Pharmacologist 8:217.
*Welch HE, Muir DCG, Billeck BN, . 1991. Brown snow: A long-range transport event in the Canadian Arctic. Environ Sci Technol 25:280–286.
*Welch RM, Levine W, Kuntzman R, . 1971. Effect of halogenated hydrocarbon insecticides on the metabolism and uterotrophic action of estrogens in rats and mice. Toxicol Appl Pharmacol 19:234–246.4105824
*Wester RC, Maibach HI, Sedlik L, . 1992. Percutaneous absorption of [^14^C]chlordane from soil. J Toxicol Environ Health 35:269–277.1578510
*Whetstone RR. 1964. Chlorocarbons and chlorohydrocarbons. In: Standen A, ed. Kirk-Othmer encyclopedia of chemical technology, 2nd ed., vol. 5. New York, NY: John Wiley and Sons, 248–249.
*White DH. 1979. Nationwide residues of organochlorine compounds in wings of adult mallards and black ducks. Pestic Monit J 13:12–16.114968
*White DH, Krynitsky AJ. 1986. Wildlife in some areas of New Mexico and Texas accumulate elevated DDE residues. Environ Contam Toxicol 15:149–157.
*White DH, Mitchell CA, Stafford CJ. 1985. Organochlorine concentrations, whole body weights, and lipid content of black skimmers wintering in Mexico and in south Texas. Bull Environ Contam Toxicol 34:513–517.3986390
*White DH, Stendell RC, Mulhem BM. 1979. Relations of wintering canvasback to environmental pollutants - Chesapeake Bay, Maryland. Wilson Bulletin 91:279–287.
*WHO. 1982. Guidelines for drinking water quality. Vol 1: Recommendations. Geneva: World Health Organization. (EFPI82.39). (Cited in WHO 1984)
*WHO. 1984. Environmental Health Criteria 34: Chlordane. Geneva: World Health Organization.
*WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. January 08, 2014.
*WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
*WHO/FAO. 1978. Data Sheets on pesticides No. 36: Chlordane. Geneva: World Health Organization. (Cited in WHO 1984)
*Whysner J, Montandon F, McClain RM, . 1998. Absence of DNA adduct formation by phenobarbital, polychlorinated biphenyls, and chlordane in mouse liver using the 32P-postlabeling assay. Toxicol Appl Pharmacol 148(1):14–23. 10.1006/taap.1997.8311.9465259
*Wiemeyer SN, Lamont TG, Bunck CM, . 1984. Organochlorine pesticide, polychlorobiphenyl, and mercury residues in bald eagle eggs - 1969-79 - and their relationships to shell thinning and reproduction. Environ Contam Toxicol 13:529–549.
*Wiemeyer SN, Lamont TG, Locke LN. 1980. Residues of environmental pollutants and necropsy data for Eastern United States ospreys. Estuaries 3:155–167.
*Wiemeyer SN, Swineford DM, Spitzer PR, . 1978. Organochlorine residues in New Jersey osprey eggs. Bull Environ Contam Toxicol 19:56–63.415777
*Wiersma GB, Tai H, Sand PF. 1972. Pesticide residues in soil from eight cities. Pestic Monit J 6:126–129.5084557
*Wiese III, Basson NCJ. 1966. The degradation of some persistent chlorinated hydrocarbon insecticides applied to different soil types. S Afr J Agric Sci 9:945–969.
*Williams GM. 1980. Classification of genotoxic and epigenetic hepatocarcinogens using liver culture assays. Ann N Y Acad Sci 349:273–282.6939363
*Williams GM, Numoto S. 1984. Promotion of mouse liver neoplasms by the organochlorine pesticides chlordane and heptachlor in comparison to dichlorodiphenyltrichloroethane. Carcinogenesis 5:1689–1696.6499120
*Williams DT, LeBel GL, Junkins E. 1988a. Organohalogen residues in human adipose autopsy samples from six Ontario municipalities. J Assoc Off Anal Chem 71:410–414.3384793
*Williams WM, Holden PW, Parsons DW, . 1988b. Pesticides in groundwater data base: 1988 interim report. PB8164230AS.
*Wilson DM, Oloffs PC. 1973. Persistence and movement of α- and γ-chlordane in soils following treatment with high-purity chlordane (Velsicol HCS-3260). Can J Soil Sci 53:465–472.
*Windholz M, Ed. 1983. The Merck index. 10th ed. Rahway, NJ: Merck and Co., Inc., 291.
*Winger PV, Andreasen JK. 1985. Contaminant residues in fish and sediments from Lakes in the Atchafalaya River Basin (Louisiana). Arch Environ Contam Toxicol 14:579–586.
*Wittlinger R, Ballschmiter K. 1990. Studies of the global baseline pollution XIII. C_6_-C_l4_ organohalogens (α- and γ-HCH, HCB, PCB, DDT, 4,4’-DDE, cis-and trans-chlordane, trans-nonachlor, anisols) in the lower troposphere of the Southern Indian Ocean. Fresenius J Anal Chem 336:193–200.
*Wolff MS, Berkowitz GS, Brower S, . 2000. Organochlorine exposures and breast cancer risk in New York City women. Environ Res 84(2):151–161. 10.1006/enrs.2000.4075.11068929
*Wood LW, Jones PA, Richards A. 1986. Possible sediment scavenging of chlordane and contamination of the aquatic biota in Belmont Lake, New York. Bull Environ Contam Toxicol 36:159–167.3947750
*Woods JS, Polissar L. 1989. Non-Hodgkin’s lymphoma among phenoxy herbicide-exposed farm workers in western Washington state. Chemosphere 18:401–406.
*Worthing CR, Walker SB, eds. 1987. The pesticide manual, a world compendium. 8th ed. The British Crop Protection Council England, 145.
*Wright CG, Leidy RB. 1982. Chlordane and heptachlor in the ambient air of houses treated for termites. Bull Environ Contam Toxicol 28:617–623.7093559
*Xu X, Dailey AB, Talbott EO, . 2010. Associations of serum concentrations of organochlorine pesticides with breast cancer and prostate cancer in U.S. adults. Environ Health Perspect 118(1):60–66. 10.1289/ehp.0900919.20056587
*Yess NJ, Houston MG, Gunderson EL. 1991. Food and Drug Administration pesticide residue monitoring of foods: 1978-1982. J Assoc Off Anal Chem 74:265–272.2050608
Young SJV, Kamps LR. 1982. Gas-liquid chromatographic determination of nonpolar organochlorine pesticide residues in a crude vegetable oil and its refinery by-products. J Assoc Off Anal Chem 65:916–920.6889594
*Young S, Clower Jr M, Roach JAG. 1984. Method for determination of organohalogen pesticide residues in vegetable oil refinery by-products. J Assoc Off Anal Chem 67:95–106.6698936
*Zahm SH, Weisenburger DD, Babbitt PA, . 1988. A case-control study of non-Hodgkin’s lymphoma and agricultural factors in Eastern Nebraska, USA [Abstract]. Am J Epidemiol 128:901.
*Zaroogian GE, Heltshe JF, Johnson M. 1985. Estimation of bioconcentration in marine species using structure-activity models. Environ Toxicol Chem 4:3–12.
*Zheng T, Holford TR, Tessari J, . 2000. Oxychlordane and trans-nonachlor in breast adipose tissue and risk of female breast cancer. J Epidemiol Biostat 5(3):153–160.11051111