# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Jennifer Przybyla, Ph.D.
  ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA
- David W. Wohlers, Ph.D.
  SRC, Inc., North Syracuse, NY