# VERSION HISTORY

Date | Description
May 1994 | Final toxicological profile released
December 2013 | Addendum to the toxicological profile released
February 2018 | Update of data in Chapters 2 and 3, and 7