# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding chlordane in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for chlordane.

Table 7-1 Regulations and Guidelines Applicable to Chlordane

Agency | Description | Information | Reference
Air
EPA | RfC | 7×10^−4^ mg/m^3^ ^a^ | IRIS 2002
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water health advisories | | EPA 2012
EPA | 1-Day (10-kg child) | 0.06 mg/L | EPA 2012
EPA | 10-Day (10-kg child) | 0.06 mg/L | EPA 2012
EPA | DWEL | 0.02 mg/L | EPA 2012
EPA | Life-time | 0.004 mg/L | EPA 2012
EPA | mg/L at 10^−4^ cancer risk | 0.01 | EPA 2012
EPA | National primary drinking water regulations | | EPA 2009
EPA | MCL | 0.002 mg/L^b^ | EPA 2009
EPA | PHG | Zero | EPA 2009
EPA | RfD | 5×10^−4^ mg/kg-day^c^ | IRIS 2002
WHO | Drinking water quality guidelines | | WHO 2017
WHO | Guideline value | 0.0002 mg/L; (0.2 µg/L)^d,e^ | WHO 2017
| PTDI | 0.5 µg/kg body weight^f^ | WHO 2017
FDA | EAFUS | No data | FDA 2013
| Allowable level in bottled water | 0.002 mg/L | FDA 2016
Cancer
ACGIH | Carcinogenicity classification | A3^g,h^ | ACGIH 2001, 2016
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Carcinogenicity classification | B2^i,j^ | IRIS 2002
IARC | Carcinogenicity classification | Group 2B^k,l^ | IARC 2001
Occupational
ACGIH | TLV | 0.5 mg/m^3^ ^m^ | ACGIH 2016
OSHA | PEL (8-hour TWA) for general industry, shipyards and construction | 0.5 mg/m^3^ ^m^ | OSHA 2016a, 2016b, 2016c
NIOSH | REL (up to 10-hour TWA) | 0.5 mg/m^3^ ^m,n^ | NIOSH 2016
| IDLH | 100 mg/m3 ^n,o^ | NIOSH 2014
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2016
AIHA | ERPGs | No data | AIHA 2015
DOE | PACs-air | | DOE 2016a
DOE | PAC-1^p^ | 4.5 mg/m^3^ | DOE 2016a
DOE | PAC-2^p^ | 50 mg/m^3^ | DOE 2016a
DOE | PAC-3^p^ | 500 mg/m^3^ | DOE 2016a

a Based on hepatic effects in a rat subchronic inhalation study.

b Potential health effects from long-term exposure above the MCL: liver or nervous system problems; increased risk of cancer.

c Based on hepatic necrosis effects in a mouse 104-week oral study.

d Guideline value derivation based on allocation to water (1% of PTDI), weight (60 kg adult), and consumption (2L/day).

e Chlordane is listed under the Stockholm Convention on Persistent Organic Pollutants, so monitoring may occur in addition to that required by drinking water guidelines.

f Based on a NOAEL of 50 µg/kg-body weight/day for increased liver weights, serum bilirubin levels, and incidence of hepatocellular swelling, derived from a long-term dietary study in rats, and using an uncertainty factor of 100 (10 each for interspecies and intraspecies variation).

g A3: confirmed animal carcinogen with unknown relevance to humans.

h Based on liver cancer reported in mice fed chlordane in their diets.

i B2: probable human carcinogen.

j Based on sufficient evidence of carcinogenicity in animals.

k Group2B: possibly carcinogenic to humans.

l Based on inadequate evidence in humans and sufficient evidence in experimental animals for the carcinogenicity of chlordane.

m Skin notation: refers to the potential significant contribution to the overall exposure by the cutaneous route.

n Potential occupational carcinogen.

o Based on acute oral toxicity data in humans and animals.

p Definitions of PAC terminology are available from the U.S. Department of Energy (DOE 2016a).

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health concentrations; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; PHG = public health goal; PTDI = provisional tolerable daily intake; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TWA = time-weighted average; WHO = World Health Organization