# CHAPTER 5 POTENTIAL FOR HUMAN EXPOSURE

## 5.1 OVERVIEW

Chlordane has been identified in at least 285 of the 1,854 hazardous waste sites that have been proposed for inclusion on the EPA National Priorities List (NPL) (ATSDR 2017). However, the number of sites in which chlordane has been evaluated is not known. The number of sites in each state is shown in Figure 5-1. Of these sites, 283 are located within the United States and 1 is located in Puerto Rico (not shown).

Figure 5-1 Number of NPL Sites with Chlordane Contamination

This figure is a map showing the Number of NPL Sites with Chlordane Contamination

Source: ATSDR 2017

- The most likely sources of potential exposure of the general population to chlordane are from exposure in homes that were treated with chlordane to control termites or eating chlordane-contaminated food or drinking water than may have been contaminated from chlordane when it was used as a pesticide prior to 1988.
- People who live near hazardous waste sites containing chlordane may be exposed from contaminated air, surface water or groundwater, or soil.
- Daily intakes from food have been estimated.
- Chlordane would be expected to volatilize from surface water and surface soil; in air, chlordane is expected to degrade by photolysis and oxidation. Residues in soil that do not leach or volatilize appear to be persistent.

## 5.2 PRODUCTION, IMPORT/EXPORT, USE, AND DISPOSAL

### 5.2.1 Production

Chlordane is produced by chlorinating cyclopentadiene to form hexachlorocyclopentadiene and condensing the latter with cyclopentadiene to form chlordene. The chlordene is further chlorinated at high temperature and pressure to chlordane (Dearth and Hites 1991c; Whetstone 1964). EPA (1987g) estimated that ≈3.5–4.0 million pounds of chlordane were distributed in 1986. In 1990, Velsicol Chemical Company in Memphis, Tennessee, was the only U.S. manufacturer of chlordane; between 100,000 and 1 million pounds of chlordane were produced (SRI 1990; TRI90 1992). It was the only domestic manufacturer of chlordane at the time that the EPA canceled its registration for commercial production, delivery, sale, and use in the United States (EPA 1988c; SRI 1988). This cancellation became effective April 14, 1988 (EPA 1988c). Technical heptachlor contains 20–22% trans-chlordane (Kutz et al. 1991). The registration of heptachlor was also canceled by EPA. Table 5-1 summarizes information on U.S. companies that manufactured or used chlordane in 2016 (TRI16 2017).

Table 5-1 Facilities that Produce, Process, or Use Chlordane

State^a^ | Number of facilities | Minimum amount on site in pounds^b^ | Maximum amount on site in pounds^b^ | Activities and uses^c^
AR | 1 | 100,000 | 999,999 | 9, 12
CA | 1 | 100 | 999 | 12
ID | 1 | 1,000 | 9,999 | 12
IL | 1 | 0 | 99 | 12
IN | 1 | 0 | 99 | 1, 2, 9, 13, 14
NE | 1 | 10,000 | 99,999 | 12
OH | 2 | 100 | 99,999 | 12
OR | 1 | 10,000 | 99,999 | 12
TX | 2 | 1,000 | 99,999 | 1, 5, 11, 12
UT | 1 | 100,000 | 999,999 | 9, 12
VA | 1 | 100 | 999 | 9

a Post office state abbreviations used.

b Amounts on site reported by facilities in each state.

c Activities/Uses:

1. Produce
2. Import
3. Onsite use/processing
4. Sale/Distribution
5. Byproduct
6. Impurity
7. Reactant
8. Formulation Component
9. Article Component
10. Repackaging
11. Chemical Processing Aid
12. Manufacturing Aid
13. Ancillary/Other Uses
14. Process Impurity

Source: TRI16 2017 (Data are from 2016)

### 5.2.2 Import/Export

Chlordane is not produced in the United States and is not imported from any sources.

### 5.2.3 Use

As of April 14, 1988, all commercial use of chlordane in the United States was canceled (EPA 1988c). Between July 1, 1983 and April 14, 1988, the sole use for chlordane was to control subterranean termites (EPA 1987g). For this purpose, chlordane was applied primarily as a liquid that was poured or injected around the foundation of a building (Wallace 1991). Chlordane, in conjunction with heptachlor, was at one time widely used as a pesticide for the control of insects on various types of agricultural crops and vegetation. The use pattern for chlordane in the mid-1970s was as follows: 35% used by pest control operators, mostly on termites; 28% on agricultural crops, including corn and citrus; 30% for home lawn and garden use; and 7% on turf and ornamentals (HSDB 1988). On March 6, 1978, a final cancellation notice was issued, which called for the suspension of the use of chlordane except for subsurface injection to control termites and for dipping roots and tops of nonfood plants. Minor use of chlordane for treating nonfood plants was canceled by 1983 (EPA 1987g). The use of chlordane decreased drastically in the 1970s when EPA moved to cancel all uses other than subterranean termite control (Kutz et al. 1991).

### 5.2.4 Disposal

Chlordane may be disposed of by dissolving it in a flammable solvent and incinerating it under controlled conditions. The incinerator should be equipped with an afterburner and an acid scrubber to remove halo acids from the effluent gas, and adequate ash disposal procedures should be followed (EPA 1991; HSDB 1988; OHM-TADS 1988). Before disposing waste residue containing chlordane (including waste sludge) on land, environmental regulatory agencies should be consulted for guidance on acceptable disposal practices (HSDB 1988). EPA promulgated standards for the disposal of waste chlordane in sewage sludge (EPA 1993).

In situ vitrification is a thermal treatment technology in which substantial quantities of energy are introduced into contaminated soil, thereby destroying organic compounds and immobilizing inorganic compounds (Dragun 1991). This technology has been applied to chlordane-contaminated soils.

## 5.3 RELEASES TO THE ENVIRONMENT

The Toxics Release Inventory (TRI) data should be used with caution because only certain types of facilities are required to report (EPA 2005). This is not an exhaustive list. Manufacturing and processing facilities are required to report information to the TRI only if they employ ≥10 full-time employees; if their facility is included in Standard Industrial Classification (SIC) Codes 10 (except 1011, 1081, and 1094), 12 (except 1241), 20–39, 4911 (limited to facilities that combust coal and/or oil for the purpose of generating electricity for distribution in commerce), 4931 (limited to facilities that combust coal and/or oil for the purpose of generating electricity for distribution in commerce), 4939 (limited to facilities that combust coal and/or oil for the purpose of generating electricity for distribution in commerce), 4953 (limited to facilities regulated under RCRA Subtitle C, 42 U.S.C. section 6921 et seq.), 5169, 5171, and 7389 (limited S.C. section 6921 et seq.), 5169, 5171, and 7389 (limited to facilities primarily engaged in solvents recovery services on a contract or fee basis); and if their facility produces, imports, or processes ≥25,000 pounds of any TRI chemical or otherwise uses >10,000 pounds of a TRI chemical in a calendar year (EPA 2005).

### 5.3.1 Air

Estimated releases of 39 pounds (~0.02 metric tons) of chlordane to the atmosphere from 13 domestic manufacturing and processing facilities in 2016, accounted for about 0.13% of the estimated total environmental releases from facilities required to report to the TRI (TRI16 2017). These releases are summarized in Table 5-2.

Table 5-2 Releases to the Environment from Facilities that Produce, Process, or Use Chlordane^a^

State^c^ | RF^d^ | Reported amounts released in pounds per year^b^
State^c^ | RF^d^ | Air^e^ | Water^f^ | UI^g^ | Land^h^ | Other^i^ | Total release
State^c^ | RF^d^ | Air^e^ | Water^f^ | UI^g^ | Land^h^ | Other^i^ | On-site^j^ | Off-site^k^ | On- and off-site
AR | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 1
CA | 1 | 0 | 0 | 0 | 235 | 0 | 235 | 0 | 235
ID | 1 | 0 | 0 | 0 | 1,018 | 0 | 1,018 | 0 | 1,018
IL | 1 | No data | No data | No data | No data | No data | No data | No data | No data
IN | 1 | No data | No data | No data | No data | No data | No data | No data | No data
NE | 1 | 23 | 0 | 0 | 6,183 | 0 | 23 | 6,183 | 6,206
OH | 2 | 4 | 0 | 0 | 0 | 0 | 4 | 0 | 4
OR | 1 | 0 | 0 | 0 | 22,256 | 0 | 22,256 | 0 | 22,256
TX | 2 | 11 | 0 | 0 | 0 | 0 | 11 | 0 | 11
UT | 1 | No data | No data | No data | No data | No data | No data | No data | No data
VA | 1 | No data | No data | No data | No data | No data | No data | No data | No data
Total | 13 | 39 | 0 | 0 | 29,691 | 0 | 23,548 | 6,183 | 29,731

a The TRI data should be used with caution since only certain types of facilities are required to report. This is not an exhaustive list. Data are rounded to nearest whole number.

b Data in TRI are maximum amounts released by each facility.

c Post office state abbreviations are used.

d Number of reporting facilities.

e The sum of fugitive and point source releases are included in releases to air by a given facility.

f Surface water discharges, waste water treatment-(metals only), and publicly owned treatment works (POTWs) (metal and metal compounds).

g Class I wells, Class II-V wells, and underground injection.

h Resource Conservation and Recovery Act (RCRA) subtitle C landfills; other onsite landfills, land treatment, surface impoundments, other land disposal, other landfills.

i Storage only, solidification/stabilization (metals only), other off-site management, transfers to waste broker for disposal, unknown

j The sum of all releases of the chemical to air, land, water, and underground injection wells.

k Total amount of chemical transferred off-site, including to POTWs.

RF = reporting facilities; UI = underground injection

Source: TRI16 2017 (Data are from 2016)

### 5.3.2 Water

There were no releases of chlordane to surface water or publicly owned treatment works (POTWs from 13 domestic manufacturing and processing facilities in 2016 required to report to the TRI (TRI16 2017). These releases are summarized in Table 5-2.

### 5.3.3 Soil

Estimated releases of 29,691 pounds (~13.47 metric tons) of chlordane to soils from 13 domestic manufacturing and processing facilities in 2016, accounted for about 99.9% of the estimated total environmental releases from facilities required to report to the TRI (TRI16 2017). No chlordane was released via underground injection (TRI16 2017). These releases are summarized in Table 5-2.

## 5.4 ENVIRONMENTAL FATE

### 5.4.1 Transport and Partitioning

Chlordane may be transported long distances in the atmosphere. The United States appears to be the main source of chlordane in the air over the North Atlantic (Bidleman et al. 1987). Concentrations of cis-chlordane ≤0.0054 ng/m^3^ in the Norwegian Arctic are believed to originate in the Soviet Union, thousands of miles away (Pacyna and Oehme 1988). Similarly, the source of chlordane-related compounds in brown snow in the central Canadian Arctic, based on back-trajectories of air masses, was probably western China (Welch et al. 1991). It is estimated that ≈3,300 kg of chlordane were deposited annually in the Arctic regions (from 60° N latitude to the pole) (Cotham and Bidleman 1991).

There is a large body of information concerning the transport and partitioning of chlordane in the environment. In outdoor air, chlordane exists predominantly in the vapor phase (Atlas and Giam 1988; Bidleman et al. 1986; Bidleman and Foreman 1987; Foreman and Bidleman 1987), whereas particle-adsorbed chlordane will contribute relatively minor amounts to the environmental burden (Starr et al. 1974; Tucker and Preston 1984). Air monitoring data are derived by the following method: chlordane is first pulled through a fiber filter and then trapped on a solid adsorbent; the amounts of chlordane retained on the filter and on the adsorbent are used to estimate the proportion of particulate-bound and vapor-phase chemical. Air monitoring data derived by this method indicate that 0.7 and 11% of chlordane is bound to particulate matter at 20 and 0°C, respectively (Bidleman et al. 1986). At 28°C (the average temperature at which one of the arctic air monitoring studies was performed), about 45% of chlordane is bound to particulate matter (Patton et al. 1991). However, the small amount of adsorbed chlordane at ordinary temperatures appears to play an important role in atmospheric deposition. In samples collected in a rural area of Texas, 98% of the chlordane-scavenged rain was particle-bound chlordane, rather than vapor-phase chlordane that partitioned into rain drops (Atlas and Giam 1988). The chlordane concentration in rain was 1,900 times the concentration in air. The contribution of dry deposition to total (wet and dry) deposition in a 24-hour period was 8.9%. Chlordane applied to the foundation of homes for termite treatment can enter the home through cracks in the foundation or in heating ducts in the slabs. Chlordane disperses through the house by diffusion and convection (Livingston and Jones 1981).

Chlordane in water will both adsorb to bed and suspended sediments and volatilize. The partitioning of chlordane to sediment correlates with the organic carbon content of the sediment. The mean log K_oc_ for trans-chlordane to samples of suspended particulate matter from the St. Clair and Detroit Rivers was 6.3 (Lau et al. 1989). Where concentrations of suspended sediment are high, such as in rivers near sources of industrial discharge, substantial amounts of pollutants like chlordane would be transported with suspended sediment. The rate of volatilization of chlordane from water depends to a large extent on the amount, size, and composition (i.e., percent organic matter) of the suspended material in the water body, since adsorption to suspended solids and sediments attenuates the rate of volatilization (Oloffs et al. 1972, 1973). The rate of volatilization is also affected by temperature, wind, and water turbulence. Chlordane adsorbed almost completely to sediments in laboratory experiments over a period of ≈6 days (Oloffs et al. 1972, 1973). It also volatilizes reasonably rapidly from water (Huang 1970), and it appears that volatilization kinetics may be faster than adsorption kinetics. The majority of chlordane, however, probably enters water as runoff from urban and agricultural soils, and is adsorbed to particulates before entering a body of water. The chlordane repartitions in the water and volatilizes rapidly near the water surface. Using the EPA EXAMS model (EPA 1985b), the estimated volatilization half-lives of chlordane from a typical pond and lake are <10 days. Nonetheless, monitoring data indicate that sediment concentrations of chlordane are much higher than the overlying water, suggesting that volatilization from water may not be as fast as predicted. A field experiment was performed to study the persistence and mobility of technical chlordane applied to an intertidal sandflat (Smith et al. 1992). The chlordane was applied at mid-tide level to a depth of 10 cm and sediment cores to a depth of 10 cm were sampled before treatment and 1, 3, 5, 13, 19, 44, 71, 112, and 199 tides after treatment. The overall change of mass was about 62% over a period of 106 days with more than half occurring during the first tide cycle. The main decrease in concentration was in the top 2 cm where mass transport and bioaccumulation are most effective. Concentrations for the 2–5- and 5–10-cm depth intervals showed little change between tides 3 and 71. Thus, after some initial displacement, possibly into more organically-enriched sediment, there was little vertical movement of chlordane. The composition of the technical chlordane was essentially constant during the experiment, which suggested that processes such as hydrolysis, dechlorination, and volatilization were much less important pathways for chlordane removal from this environment than sediment transport.

Chlordane will bioconcentrate in both marine species (bioconcentration factor 3,000–12,000 [Zaroogian et al. 1985]) and fresh water species (bioconcentration factor 18,500 in rainbow trout [Oliver and Niimi 1985]), as well as bacteria (bioconcentration factor of 200–55,900 [Grimes and Morrison 1975]). See Gobas et al. (1988) and Isnard and Lambert (1988) for further information on bioaccumulation in fish. Biomagnification of chlordane-related compounds, including heptachlor epoxide, was studied at three trophic levels in the Arctic marine food chain, namely, Arctic cod, ringed seals, and polar bears (Muir et al. 1988). Biomagnification was 7.3/4.7 from fish to seal (male/female) and 6.6/9.5 between seal (male/female) and bear (resulting in an overall fish to bear biomagnification factor of 44.2). Both chlordane isomers decrease in higher trophic levels with only the metabolite oxychlordane present in polar bears (Hargrave et al. 1992). It should be noted that biomagnification of chlordane is a tricky concept because the compositional pattern of chlordane compounds and metabolites varies among different trophic levels and species (Kawano et al. 1988). Chlordane is taken up by rooted aquatic vascular plants both from the water and from the sediment. The bioconcentration factor of chlordane in the submerged vascular plant, Hydrillu verticillatu, was 1.060 (Hinman and Klaine 1992). Chlordane also bioconcentrates in the roots from contaminated sediment and translocates into the shoots. However, acropetal translocation is not extensive.

In soil, chlordane adsorbs to the organic matter and volatilizes slowly over time. Chlordane does not leach significantly. In general, chlordane remains in the top 20 cm of most soils and for some soils, it stays at this level for >20 years (Beeman and Matsumura 1981; Bennett et al. 1974). Its behavior is somewhat dependent on the composition of the soil (Bennett et al. 1974; Carter and Stringer 1971; Haque and Freed 1974; Jury et al. 1987a; Sears and Chapman 1979; Stewart and Chisholm 1971; Stewart and Fox 1971; Tafuri et al. 1977). A study by the California Department of Food and Agriculture classified chlordane as a “nonleacher” based on records of groundwater contamination following normal agricultural use (Gustafson 1989). The distribution coefficient between chlordane and geologic material collected near a hazardous waste site in Memphis, Tennessee, ranged from 18 to 220 mL/g or K_oc_ of 20,000–76,000 (Johnson-Logan et al. 1992). Chlordane will bind tenaciously to dissolved organic carbon (DOC) in water, which will result in increased apparent solubility and mobility in the presence of DOC. For example, the solubility of chlordane in groundwater downstream of a hazardous waste site in Memphis, Tennessee, was 150 μg/L, compared to 30 μg/L in purified water due to the presence of DOC (Johnson-Logan et al. 1992). Therefore, it is expected that chlordane mobility will be enhanced at this site. Volatilization from soil is a major loss mechanism for chlordane; the rate depends on such parameters as the soil organic content, water content, temperature, and relative humidity as well as its vapor pressure and adsorption to soil (Atallah et al. 1979; Glotfelty and Schomburg 1989; Glotfelty et al. 1984; Jury et al. 1987b; Nash 1983a, 1983b; Wilson and Oloffs 1973). In general, sandy soils and soils with small amounts of organic matter retain chlordane less than soils with high clay and/or organic content (Wiese and Basson 1966). Soil moisture, however, is the most important factor. Within an hour of being sprayed on the surface of moist bare soil in a pesticidal mixture, the vapor pressure of chlordane near the soil surface was 5.8×10^−7^ mmHg (Glotfelty and Schomburg 1989). The time for 50% of the chlordane to volatilize is 2–3 days. In time, the spray penetrates the soil and longer-term volatilization is controlled by back diffusion out of the soil layer. Losses are also highest near noon and lowest at night. It has been shown that the loss rate of chlordane applied to the surface of moist soil is proportional to the amount of remaining residue and inversely proportional to the square root of the daylight hours since application. In dry soil, the organic vapors are much more strongly adsorbed with a resulting decrease in volatilization (Glotfelty and Schomburg 1989; Nash 1983a). Incorporation of chlordane into the soil reduces volatilization because of dilution and because volatilization depends on slow diffusion and convective flow processes. It is estimated that 4.0 cm of sandy soil or 3.9 cm of clay soil is sufficient to restrict chlordane volatilization losses to <0.7% of the mass incorporated in the soil (Jury et al. 1990). Volatilization in some cases will continue for many years, as evidenced by the detection of indoor air concentrations of chlordane 15 years after application (Livingston and Jones 1981). Crop cover does not markedly alter the rate of volatilization. In a 3-year field experiment in which chlordane was incorporated into the top 10 cm of sandy loam soil, the half-lives of chlordane in cropped and fallow plots were 93.2 and 154 days, respectively (Singh et al. 1991). Initially, the dissipation rate of cis-chlordane was slightly higher in the fallow plots. trans-Chlordane disappeared from the soil column after 210 days, but then reappeared, suggesting that cis-chlordane was isomerizing to trans-chlordane. At the end of the experiment, the highest residues were in the top 10 cm of soil for both the cropped and fallow plots. However, the proportion of trans-chlordane was markedly lower in the cropped plots. Small amounts of chlordane can translocate from contaminated soil into plants, and there is some evidence that cis-chlordane can isomerize to trans-chlordane in plants (Singh et al. 1990, 1991). The amount taken up varies with species and stage of plant development.

### 5.4.2 Transformation and Degradation

Air. Chlordane degrades in air by both photolysis and oxidation. trans-Chlordane photochemically degrades more readily than cis-chlordane. This is indicated from the fact that the trans:cis ratio of chlordane transported long distances to the Norwegian Arctic changes from around 1 in the winter to 0.5 in the summer (Oehme 1991). Many papers have been published that detail the photoproducts of chlordane (principally cis-chlordane) and mechanisms of photoproduct formation (Feroz et al. 1981; Ivie et al. 1972; Onuska and Comba 1975; Parlar and Korte 1973, 1977, 1979, 1980; Podowski et al. 1979; Vollner et al. 1971). The most common photoproduct for cis-chlordane is the cage configuration that results from proton migration to the dichloroethylene moiety and carbon-carbon bond formation from one of the cyclopentane carbons. These photoreactions may also occur on leaf surfaces (Parlar 1978; Podowski et al. 1979), although the significance of this reaction to the overall removal of chlordane is not clear. Hydroxyl radical reactions of chlordane may be a significant removal mechanism in addition to photolysis. Atkinson (1987) developed a method to estimate the rate of reaction for hydroxyl radicals with organic vapors in the atmosphere. This method is based on the molecular structure of the organic compound. Using this method, an overall reaction rate of 12.4×10^−12^ cm^3^/molecule-second was calculated. Assuming an average ambient hydroxyl radical concentration of 5×10^5^ molecules/cm^3^, averaged over a 24-hour time period (Atkinson 1985), this reaction rate yields an atmospheric half-life of 1.3 days for chlordane vapor.

Water. The degradation of chlordane in water has not been extensively studied. Eichelberger and Lichtenberg (1971) reported results of a river die-away test in which 85% of the original concentration of chlordane added to river water remained at the end of 2 weeks and persisted at that level for 8 weeks. Oloffs et al. (1972) found that 2.3–50.7% of the chlordane added to three river water samples remained in the aqueous phase after 12 weeks. It was concluded that at least some of the loss was from volatilization. Speidel et al. (1972) reported that chlordane adsorbed to microbially-generated floe, and Tabak et al. (198la, 1981b) reported no degradation in 7 days using domestic waste water as a seed. These studies indicate that chlordane will not degrade rapidly in water and that transport is probably a faster removal mechanism than degradation. No information is available on whether chlordane undergoes photochemical reactions in the aquatic environment.

Sediment and Soil. Numerous papers have detailed the degradation of chlordane in soils. In general, chlordane appears to persist for potentially long periods of time (>20 years) in some soils, but much shorter times in other soils. Beeman and Matsumura (1981), Bennett et al. (1974), Lichtenstein and Schulz (1959), Nash and Woolson (1967), Stewart and Chisholm (1971), and Stewart and Fox (1971) all reported finding chlordane residues in excess of 10% of the initially applied amount, ≥10 years after application. Other authors (Harris and Sans 1976; Mullins et al. 1971; Tafuri et al. 1977; Wiese and Basson 1966) have reported faster removal from soils, but detectable concentrations appear to remain for at least 10 years for most application rates. At chlordane-treated subterranean sites on the University of Missouri-Columbia campus, >70% of the originally applied chlordane could be accounted for 7 years after application (Puri et al. 1990). The fact that the chromatographic profiles of the technical chlordane components were almost identical to the original formulation indicates that little chemical or biochemical transformation had occurred. Sethunathan (1973) reported that chlordane does not degrade under anaerobic conditions in flooded soils. A 1989 study of organochlorine pesticide residues in 12 vegetable farms (four of each of three soil types), in the Fraser Valley of British Columbia, found a marked difference in residue levels with soil type. Farms with loamy sand soil had no detectable chlordane, while one of those with silt loam soil contained mean concentrations of total chlordane of 170 ppb (dry weight), and three muck farms contained mean chlordane levels of 830 ppb (Szeto and Price 1991). Chlordane was used extensively on farms in this region as a soil insecticide on potatoes prior to the mid-1970s. These findings support the theory that organochlorine pesticides persist much longer in heavy soils with high organic content. The dissipation of chlordane from the loamy sand soil may be due to high initial volatilization. Hirano et al. (2007) evaluated the anaerobic biodegradation of cis- and trans-chlordane in sediment samples taken from a river in Japan; during 20 weeks of incubation in the dark at 30°C, an initial lag period of approximately 4 weeks was noted and 20-week residual ratios were 88 and 67%, respectively.

Only a few microorganisms have been isolated that are capable of degrading chlordane. Iyengar and Prabhakara Rao (1973) reported that a pure culture of Aspergillus niger degraded chlordane after adaptation, but Beeman and Matsumura (1981) found it to be inactive and speculated that the former authors had not considered other factors such as adsorption to glass and volatilization. Beeman and Matsumura (198l), however, reported that a Nocardiopsis sp. isolated from chlordane treated soil was capable of degrading chlordane to dichlorochlordene, oxychlordane, heptachlor, heptachlor endoepoxide, chlordane chlorohydrin, and 3-hydroxy-trans-chlordane. More recently, the lignin-degrading white rot fungus, Phanerochaete chrysosporium, was found to extensively degrade chlordane (Kennedy et al. 1990). In inoculated soil cultures, 28% of the chlordane degraded and 14.9% mineralized to carbon dioxide in 60 days. In liquid cultures, 36.8% of the chlordane degraded and 9.4% mineralized in 30 days. More mineralization occurs under low nutrient nitrogen concentrations (Aust 1990). The bulk of the literature indicates that chlordane does not degrade rapidly in soils and persists for over 20 years in some cases.

## 5.5 LEVELS IN THE ENVIRONMENT

Reliable evaluation of the potential for human exposure to chlordane depends, in part, on the reliability of supporting analytical data from environmental samples and biological specimens. Concentrations of chlordane in unpolluted atmospheres and in pristine surface waters are often so low as to be near the limits of current analytical methods. In reviewing data on chlordane levels monitored or estimated in the environment, it should also be noted that the amount of chemical identified analytically is not necessarily equivalent to the amount that is bioavailable.

Table 5-3 shows the lowest limit of detections that are achieved by analytical analysis in environmental media. An overview summary of the range of concentrations detected in environmental media is presented in Table 5-4.

Table 5-3 Lowest Limit of Detection Based on Standards^a^

Media | Detection limit | Reference
Air | 0.15 µg/m^3^ | Hsu et al. 1988
Drinking water | 0.002 µg/L | Reding 1987
Surface water and groundwater | 0.14 µg/L | EPA 1986a
Soil | 9.4 µg/kg | EPA 1986a
Sediment | 0.14 µg/L | EPA 1986a
Whole blood | 0.01 µg/L | Wariishi et al. 1986

a Detection limits based on using appropriate preparation and analytics. These limits may not be possible in all situations.

Table 5-4 Summary of Environmental Levels of Chlordane

Media | Low | High | For more information
Outdoor air (ng/m^3^) | <0.1 | 58 | Table 5-6
Indoor air (ng/m^3^) | 0.01 | 1 | Table 5-6
Surface water (ppb) | <0.1 | 8 | Table 5-7
Ground water (ppb) | <0.1 | 830 | Table 5-7
Drinking water (ppb) | <0.1 | 1,200,000 | Table 5-7
Soil | <1.0 | 14.46 | Table 5-8
Food (ppb) | <1.0 | 370 | Table 5-9

Detections of chlordane in air, water, and soil at NPL sites are summarized in Table 5-5.

Table 5-5 Chlordane Levels in Water, Soil, and Air of National Priorities List (NPL) Sites

Medium | Median^a^ | Geometric mean^a^ | Geometric standard deviation^a^ | Number of quantitative measurements | NPL sites
Chlordane
Water (ppb) | 0.6 | 0.81 | 22,000 | 29 | 20
Soil (ppb) | 8,200 | 12,700 | 38,300 | 110 | 66
Air (ppbv) | 0.008 | 0.027 | 1,897 | 10 | 8
cis-Chlordane
Water (ppb) | 0.15 | 1.55 | 109,000 | 12 | 11
Soil (ppb) | 44 | 98.8 | 17,400 | 33 | 27
Air (ppbv) | | | No data
trans-Chlordane
Water (ppb) | 0.077 | 0.0812 | 8,050 | 14 | 13
Soil (ppb) | 59 | 78.6 | 16,500 | 33 | 28
Air (ppbv) | | | No data

a Concentrations found in ATSDR site documents from 1981 to 2017 for 1,854 NPL sites (ATSDR 2017). Maximum concentrations were abstracted for types of environmental media for which exposure is likely. Pathways do not necessarily involve exposure or levels of concern.

### 5.5.1 Air

Table 5-6 summarizes results from studies that measured chlordane levels in air prior to 1992. Chlordane was detected in outside urban and rural air, in indoor air, and in the breathing zone during personal monitoring. In urban air, mean concentrations ranged from below detection limits (generally <0.1 ng/m^3^) to 58 ng/m^3^, whereas rural and background concentrations were much lower (generally <0.1–l ng/m^3^).

Chlordane concentrations in indoor air were much higher than in either urban or rural air. Indoor air levels in the living areas of treated homes often exceeded 1 μg/m^3^ in the vapor phase. These data, however, may be skewed since most of the indoor monitoring was performed on homes that had been sprayed with chlordane to control termites. Thus, the frequency of detection data may not be representative of the general population. Dust vacuumed from homes of controls, farmers, and formulators had mean chlordane levels of 7.6, 5.8, and 23.1 ppm, respectively (Starr et al. 1974). Since chlordane was poured or injected into soil around foundations of houses, the appearance of chlordane vapor in living quarters of treated houses may indicate the intrusion of soil gas through cracks, drains, or ducting in basements or ground floor spaces (Anderson and Hites 1989; Wallace 1991). Several studies indicate that concentrations of chlordane were much higher in the basement than in upper levels of homes (Anderson and Hites 1989; Fenske and Sternbach 1987). Anderson and Hites (1989) found that the basement concentrations of chlordane were often a factor of 3–10 higher than in upper areas and 2–3 orders of magnitude higher than outdoors. Fenske and Sternbach (1987) additionally reported that homes with crawl spaces and forced air heating systems had significantly higher levels of chlordane (11.2 µg/m^3^ median) than homes with basements and forced air heat (0.33 µg/m^3^), radiant heat (0.93 µg/m^3^), or in-slab ducts and forced air heat (3.42 µg/m^3^). However, misapplication of chlordane by the pest control company (as determined by the New Jersey Department of Environmental Protection) had occurred in all of the homes with the 11.2 µg/m^3^ median level and in 67% of the homes with the 3.42 µg/m^3^ median level. When misapplication occurred, living area samples had median levels of 3.28 µg/m^3^ with 40% of samples exceeding 5 µg/m^3^, compared with <0.1 µg/m^3^ and no samples exceeding 5 µg/m^3^ in homes with no misapplication (Fenske and Sternbach 1987).

Table 5-6 Detection of Chlordane in Air^a^

Media type/location | Sampling dates | Number of samples | Sample type | Analytical method | Concentration (ng/m^3^) | | Percent occurrence | Reference
Media type/location | Sampling dates | Number of samples | Sample type | Analytical method | Range | Mean | Percent occurrence | Reference
Urban air
Columbia, South Carolina | 5/79–10/80 | 4^b^ | High volume | GC/ECD | 0.54–1.74 | 1.3 | 100 | Billings and Bidleman 1983
Denver, Colorado | 1/80 | 3^b^ | High volume | GC/ECD | 0.012–0.080 | 0.063 | 100 | Billings and Bidleman 1983
New Bedford, Massachusetts landfill | 6/80 | 1^b^ | High volume | GC/ECD | 0.20–0.36 | 0.24 | 100 | Billings and Bidleman 1983
Baltimore, Maryland | 8/67–8/68 | 4 | Filter/impinger | GC/ECD | <0.1 | ND | 0 | Stanley et al. 1971
Fresno, California | 8/67–8/68 | 4 | Filter/impinger | GC/ECD | <0.1 | ND | 0 | Stanley et al. 1971
Riverside, California | 8/67–8/68 | 4 | Filter/impinger | GC/ECD | <0.1 | ND | 0 | Stanley et al. 1971
Salt Lake City, Utah | 8/67–8/68 | 4 | Filter/impinger | GC/ECD | <0.1 | ND | 0 | Stanley et al. 1971
Southeastern United States | 8/85 | 9^b^ | High/low volume | GC/ECD-MS | <1–210 | 58 | 67 | Lewis et al. 1986
Bloomington, Indiana | 11/85–10/86 | 2 | Low volume | GC/MS | 0.5–1.5 | 1.0 | 100 | Anderson and Hites 1988
Miami, Florida | 1973–1974 | 14 | NS | NS | ND–2.3 | 0.2 | 7 | Lewis and Lee 1976
Jacksonville, Florida | 8/86–9/86 | 60 | 24-hour/low volume | GC/ECD | ND–628 | 38.4 | 23 | EPA 1990b
Jacksonville, Florida | 3/87–4/87 | 72 | 24-hour/low volume | GC/ECD | ND–66 | 9.5 | 12 | EPA 1990b
Jacksonville, Florida | 1/88–2/88 | 70 | 24-hour/low volume | GC/ECD | ND–175 | 27.4 | 73 | EPA 1990b
Springfield/Chicopee, Massachusetts | 5/87–6/87 | 49 | 24-hour/low volume | GC/ECD | ND–75 | 3.1 | 8 | EPA 1990b
Springfield/Chicopee, Massachusetts | 3/88 | 50 | 24-hour/low volume | GC/ECD | ND–89 | 2.0 | 16 | EPA 1990b
Denver, Colorado | 10/85, 1/86 | 8 | High volume | GC/ECD | 0.026–0.104^c^ | 0.060 | 100 | Foreman and Bidleman 1990
Rural air
Buffalo, New York | 8/67–8/68 | 4 | Filter/impinger | GC/ECD | <0.1 | ND | 0 | Stanley et al. 1971
Dothan, Alabama | 8/67–8/68 | 4 | Filter/impinger | GC/ECD | <0.1 | ND | 0 | Stanley et al. 1971
Iowa City, Iowa | 8/67–8/68 | 4 | Filter/impinger | GC/ECD | <0.1 | ND | 0 | Stanley et al. 1971
Orlando, Florida | 8/67–8/68 | 4 | Filter/impinger | GC/ECD | <0.1 | ND | 0 | Stanley et al. 1971
Stoneville, Mississippi | 8/67–8/68 | 4 | Filter/impinger | GC/ECD | <0.1 | ND | 0 | Stanley et al. 1971
College Station, Texas | 1979–1980 | 16 | High/low volume | GC/ECD | 0.32–2.64 | 1.05 | 100 | Atlas and Giam 1988
Southern Ontario | 7/88–9/89 | 143 | High volume | GC/ECD | 0.00067–0.211^d^ | 0.039^d^ | 100 | Hoff et al. 1992
Background areas
Everglades National Park, Florida | 1973–1974 | 14 | NS | NS | ND–0.8 | 0.06 | 7 | Lewis and Lee 1976
Indian Ocean | 3/86 | 6 | High volume | GC/ECD | 0.010–0.016 | 0.013 | 100 | Wittlinger and Ballschmiter 1990
Adirondacks, New York^e^ | 1985 | 4 | High volume | GC/ECD | 0.390–0.650 | 0.480 | 100 | Knap and Binkley 1991
Newport News, Virginia^e^ | 1988 | 4 | High volume | GC/ECD | 0.015–0.129 | 0.054 | 100 | Knap and Binkley 1991
Bermuda^e^ | 1985–1988 | 24 | High volume | GC/ECD | 0.003–0.062 | 0.019 | 100 | Knap and Binkley
Canadian Arctic | 2/88–4/88 | 10 | High volume | GC/ECD | 0.0014–0.0081^f^ | 0.0039^f^ | 100 | Patton et al. 1991
Bering Sea | 7/88–8/88 | 4 | High volume | GC/MS | 0.0053–0.0141^g^ | 0.0093^g^ | 100 | Hinckley and Bidleman 1991
Northwest Atlantic | 1/88, 7/89–8/89 | 8 | High volume | GC/ECD | 0.0077–0.0242^g^ | 0.015^g^ | 100 | Bidleman et al. 1992
Indoor air
Southeastern United States | 8/85 | 9^h^ | High/low volume | GC/ECD-MS | <1–1,700 | 510 | 89 | Lewis et al. 1986
New Jersey (living areas) | 4/85–10/86 | 12^h^ | Low volume | GC/ECD | <90–1,400 | 165 | 20–47^j^ | Louis and Kisselbach 1987
New Jersey (nonliving areas) | 4/85–10/86 | 12^h^ | Low volume | GC/ECD | <90–5,870^i^ | 798 | 62–92^j^ | Louis and Kisselbach 1987
New Jersey (living areas) | 1976–1985 | 157^h^ | Low volume | GC/ECD | <200–55,400 | NS | 12–34^k^ | Fenske and Sternbach 1987
New Jersey (nonliving areas) | 1976–1985 | 157^h^ | Low volume | GC/ECD | <200–610,000 | NS | 44–48^k^ | Fenske and Sternbach 1987
Military base apartments | 1980 | 498^h^ | Low volume | GC/ECD | NS–37,800 | 1,900 | 73 | Livingston and Jones 1981
Military housing | 1981–1982 | 3,957 | NS | NS | ND–>5,000 | NS | 20.1 | EPA 1983
North Carolina | NS | 9h | Low volume | GC | 2,750–5,810 | NS | 100 | Wright and Leidy 1982
North Carolina | 6/83–10/83 | 60^h,l^ | NS | GC/ECD | <50–9,900 | 2,200 | NS | Leidy et al. 1985; Fenske and Sternbach 1987
Bloomington, Indiana | 11/85–10/86 | 12 | Low volume | GC/MS | 0.8–49 | NS | 100 | Anderson and Hites 1988
Gainesville, Florida | 1985–1986 | 11 | Low volume | GC/ECD | ND–335 | 134 | 27 | Moye and Malagodi 1987
Athens, Georgia | 1985–1986 | 9 | Low volume | GC/ECD | ND | ND | 0 | Moye and Malagodi 1987
Van Buren, Missouri | 8/83 | 21 | NS | NS | 330–27,000 | NS | NS | NIOSH 1984b
Jacksonville, Florida | 8/86–9/86 | 65 | 24-hour/low volume | GC/ECD | ND–3,020 | 324.0 | 62 | EPA 1990b
Jacksonville, Florida | 3/87–4/87 | 72 | 24-hour/low volume | GC/ECD | ND–4,380 | 245.5 | 72 | EPA 1990b
Jacksonville, Florida | 1/88–2/88 | 71 | 24-hour/low volume | GC/ECD | ND–2,050 | 220.3 | 71 | EPA 1990b
Springfield/Chicopee, Massachusetts | 5/87–6/87 | 49 | 24-hour/low volume | GC/ECD | ND–1,700 | 199.3 | 49 | EPA 1990b
Springfield/Chicopee, Massachusetts | 3/88 | 52 | 24-hour/low volume | GC/ECD | ND–735 | 34.8 | 51 | EPA 1990b
Lincoln/Omaha, Nebraska (pretreatment) | NS | 19^h^ | 4-hour at 2 L/minute | GC/ECD | NS | 250 | 100 | Kamble et al. 1992
Lincoln/Omaha, Nebraska (during treatment) | NS | 19^h^ | 4-hour at 2 L/minute | GC/ECD | NS | 1,210 | 100 | Kamble et al. 1992
Lincoln/Omaha, Nebraska (24-hour posttreatment) | NS | 19^h^ | 4-hour at 2 L/minute | GC/ECD | NS | 690 | 100 | Kamble et al. 1992
Lincoln/Omaha, Nebraska (180-day posttreatment) | NS | 19^h^ | 4-hour at 2 L/minute | GC/ECD | NS | 290 | 100 | Kamble et al. 1992
Breathing zone
Southeastern United States | 8/85 | 9^b^ | High/low volume | GC/ECD-MS | <1–4,200 | 680 | 67 | Lewis et al. 1986
Jacksonville, Florida | 8/86–9/86 | 63 | 24-hour/low volume | GC/ECD | ND–1,340 | 212.0 | 53 | EPA 1990b
Jacksonville, Florida | 3/87–4/87 | 71 | 24-hour/low volume | GC/ECD | ND–2,990 | 190.7 | 50 | EPA 1990b
Jacksonville, Florida | 1/88–2/88 | 71 | 24-hour/low volume | GC/ECD | ND–2,200 | 194.8 | 93 | EPA 1990b
Springfield/Chicopee, Massachusetts | 5/87–6/87 | 48 | 24-hour/low volume | GC/ECD | ND–2,200 | 252.9 | 50 | EPA 1990b
Springfield/Chicopee, Massachusetts | 3/88 | 52 | 24-hour/low volume | GC/ECD | ND–467 | 35.9 | 87 | EPA 1990b
Lincoln/Omaha, Nebraska (applicators) | NS | 29 | 30 minutes at 2 L/minute | GC/ECD | 610–116,330 | 16,600 | 100 | Kamble et al. 1992

a No distinction is made between the isomers of chlordane. In cases where the original papers made a distinction, the data were combined.

b Sample periods.

c A 9^th^ sample with vapor phase only contained 0.068 ng/m^3^ of chlordane.

d Annual mean and range of cis-chlordane, trans-chlordane, and trans-nonachlor.

e Samples taken from aircraft at various altitudes.

f Sum of cis-chlordane, trans-chlordane, and trans-nonachlor in total (vapor and particulate) sample.

g Sum of cis-chlordane, trans-chlordane, and trans-nonachlor.

h Sample locations.

i High detection was in sample taken prior to treatment.

j Percent detectable varied with the time after treatment.

k Percent >5,000 ng m^−3^.

l Site selection not influenced by application procedures.

GC = gas chromatography; ECD = electron capture detector; MS = mass spectroscopy; ND = not detected; NS = not specified

More recent reports are available regarding levels of chlordane compounds in outdoor and/or indoor air within various regions of North America (Aulagnier and Poissant 2005; Bidleman et al. 1998; Cortes et al. 1998; Hung et al. 2002; Jantunen et al. 2000; Leone et al. 2001; Moreau-Guigon et al. 2007; Offenberg et al. 2004; Shen et al. 2005; Sun et al. 2006). Chlordane levels in sampled outdoor air were consistently <1 ng/m^3^. One study reported higher average air concentrations indoors than outdoors at test locations in Los Angeles County, California; Elizabeth, New Jersey; and Houston, Texas (average indoor levels of 1.98, 1.3, and 4.18 ng/m^3^, respectively, versus average outdoor levels of 0.58, 0.17, and 0.28 ng/m^3^, respectively) (Offenberg et al. 2004).

### 5.5.2 Water

Table 5-7 summarizes results from studies that measured chlordane levels in water and sediments prior to 1990. Chlordane was detected in surface water, groundwater, suspended solids, sediments, bottom detritus, drinking water, sewage sludge, urban runoff, and rain. Concentrations of chlordane in ocean and lake water were <0.0001 ng/L. Studies in the Great Lakes indicate that the level of the cis-chlordane in water were roughly 2–3 times that of trans-chlordane (Biberhofer and Stevens 1987; Stevens and Neilson 1989). The presence of chlordane in drinking water appears to almost always result from an accidental event, such as back-siphoning during dilution of a pesticide spray (CDC 1976), but concentrations can persist for months.

Table 5-7 Detection of Chlordane in Water and Sediments^a^

Media type/location | Sampling dates | Number of samples | Sample type | Analytical method | Concentration (ppb) | | Percent occurrence | Reference
Media type/location | Sampling dates | Number of samples | Sample type | Analytical method | Range | Mean | Percent occurrence | Reference
Surface water
Wolf River, Tennessee | NS | 30 | Grab | NS | NS | 0.15 | NS | Jaffe et al. 1982
Wolf River, Tennessee | NS | 0 | Grab | NS | NS | 0.42 | NS | Jaffe et al. 1982
Mississippi River, Louisiana | 1974 | NS | Continuous | GC/ECD | 0.00045–0.00115 | NS | 100 | Brodtmann 1976
Niagara River, New York | 4/79–12/81 | NS | Continuous | GC/ECD | NS | 0.004 | 66 | Kuntz and Warry 1983
Lower Fox River, Wisconsin | 1976–1977 | 250 | Grab | GC+GC/MS | NS | NS | NS | Peterman et al. 1980
Surface waters in New Jersey | NS | 603 | NS | NS | <0.1–0.8 | 0.1^b^ | 56 | Page 1981
Hawaii Kai Marina, Hawaii | 4/74–7/74 | 12 | Grab | GC/ECD | NS | NS | 55 | Tanita et al. 1976
Hawaii Kai Marina, Hawaii | 4/72–11/72 | 5 | Grab | NS | <0.001–0.01 | NS | 40 | Tanita et al. 1976
Belmont Lake, New York | 1982 | NS | Grab | GC/ECD | 0.003–0.099 | NS | NS | Wood et al. 1986
177 River stations of the United States | 1975–1980 | 2,943 | Grab | NS | NS | NS | 0.6^c^ | Gilliom 1984
Gulf of Mexico and Southeast Coast^d^ | 1987 | 9 | Grab | GC/ECD | 0.000004–0.000034 | NS | NS | Sauer et al. 1989
Lake Ontario | 10/83 | 14 | Pump (1 m) | GC/ECD | 0.000034–0.000108 | 0.000060 | 100 | Biberhofer and Stevens 1987
Four Great Lakes, including Georgian Bay | 1986 | 95 | Pump (1 m) | GC/ECD | ND–0.000202 | NS | 71 | Stevens and Neilson 1989
Bering Sea | 7/88 | 1 | Grab | NS | 0.00014^e^ | 0.00014^e^ | 100 | Hinckley and Bidleman 1991
Suspended solids
Niagara River | NS | 15 | Grab | NS | 0.006–0.011 | 0.0085 | 13 | Maguire et al. 1983
Niagara River | 4/79–12/81 | NS | Continuous | GC/ECD | NS | 4.5 | 73 | Kuntz and Warry 1983
Sediments
Streams near San Francisco Bay | 2/72–3/72 | 29–39 | Grab | GC/ECD-MS | ND–800 | 120 | 90 | Law and Goerlitz 1974
Fore River and Back Cove, Maine | 11/80 | 8 | Grab | GC/ECD | <0.03–9.8 | 1.8 | 75 | Ray et al. 1983
Apalachicola River, Florida | 8/79–5/80 | 12 | Grab | GC | <1–3 | NS | 17 | Elder and Mattraw 1984
Hawaii Kai Marina, Hawaii | 4/74–7/74 | 12 | Grab | GC/ECD | 1.73–10.4 | 5.27 | 97 | Tanita et al. 1976
Hawaii Kai Marina, Hawaii | 1972–1973 | 11 | Grab | NS | NS | 5.32 | 100 | Tanita et al. 1976
Belmont Lake, New York | 1982 | NS | Grab | GC/ECD | 20–580 | NS | NS | Wood et al. 1986
171 River stations | 1975–1980 | 1,014 | Grab | NS | NS | NS | 30c | Gilliom 1984
Great Lakes harbors | 5/89 | 5 | Grab | GC/ECD | 1.44–14.34^f^ | 3.66^f^ | 100 | Verbrugge et al. 1991
NPL site (on-site) in Marshall, Illinois | NS | NS | NS | NS | ND–1,000,000 | NS | NS | ATSDR 1989b
NPL site (off-site) in Marshall, Illinois | NS | NS | NS | NS | ND–250,000 | NS | NS | ATSDR 1989b
Gulf of Mexico (51 site)^g^ | 1986 | 153 | Surface | GC/ECD | <0.02–8.66^h^ | 0.26 | 77 | Sericano et al. 1990
Gulf of Mexico (50 site)^g^ | 1987 | 148 | Surface | GC/ECD | <0.02–43.5^h^ | 1.18 | 72 | Sericano et al. 1990
Bottom detritus
Apalachicola River, Florida | 8/79–5/80 | 7 | Grab | GC | 1700–10,000 | NS | 100 | Elder and Mattraw 1984
Groundwater
Groundwaters in New Jersey | NS | 1,076 | NS | NS | <0.1–0.4 | <0.1^b^ | 40 | Page 1981
NPL site in Plumstead Township, New Jersey^i^ | NS | NS | NS | NS | 0.02 | NS | NS | VIEW 1988
NPL site in Cape Giradeau, Missouri^j^ | NS | NS | NS | NS | 830 | NS | NS | VIEW 1988
NPL site in Holbrook, Massachusetts^j^ | NS | NS | NS | NS | 48 | NS | NS | VIEW 1988
NPL sites at 11 other locations^k^ | NS | NS | NS | NS | NS | NS | NS | VIEW 1988
NPL site (on-site) in Marshall, Illinois | NS | NS | NS | NS | ND–0.6 | NS | NS | ATSDR 1989b
NPL site (off-site) in Marshall, Illinois | NS | NS | NS | NS | ND | NS | NS | ATSDR 1989b
Cape Cod golf courses | 1986–1987 | 16^l^ | Pump/bail | GC/ECD | ND–7.20 | NS | 44 | Cohen et al. 1990
Drinking water
Pittsburgh, Pennsylvania | 12/80 | NS | Grab | NS | <0.1–6600^m^ | NS | NS | CDC 1981
Seven U.S. cities | 1965–1967 | 63 | Grab | NS | NS | NS | 22 | Schafer et al. 1969
Chattanooga, Tennessee | 3/24/76 | NS | Grab | GC/ECD | NS–1,200,000 | NS | NS | Harrington et al. 1978
Kansas farmstead well survey^n^ | 12/85–2/86 | 103 | Grab | GC/ECD | ND–0.53 | NS | 0.97 | Steichen et al. 1988
Sewage sludge
Unspecified states | NS | 44 | NS | NS | NS | NS | 73 | Fricke et al. 1985
Urban runoff
Fresno, California | NS | NS | Grab | NS | 0.1–0.3 | 0.1^b^ | NS | Nightingale 1987
Lake Quinsigamond, Massachusetts and Kansas City, Missouri | NS–7/82 | NS | Grab | NS | 0.01–10^o^ | NS | 5 | Cole et al. 1984
11 Canadian Great Lakes basin sites | NS | 124 | Grab | GC/ECD | NS | 0.00121 | 20 | Marsalek and Schroeter 1988
Street sediment
11 Canadian Great Lakes basin sites | NS | 110 | Grab | GC/ECD | NS | 0.046 | 35 | Marsalek and Schroeter 1988
Rain
Lake Superior | 1983 | NS | NS | GC/ECD | <0.00005 | ND | 0 | Strachan 1985
College Station, Texas | 1979–1980 | NS | NS | GC/ECD | <0.00005 | ND | 0 | Strachan 1985
College Station, Texas | 1979–1980 | 24 | Collector | GC/ECD | 0.0006–0.0091 | 0.00214 | 100 | Atlas and Giam 1988
Great Lakes (4 remote sites) | 2/86–7/86 | 93 | Collector | GC/ECD | ND–0.0023 | NS | 33 | Chan and Perkins 1989
Bermuda | 1983–1984 | 36 | Collector | GC/ECD | ND–0.000486 | 0.000077 | 97 | Knap et al. 1988

a No distinction is made between the isomers of chlordane. In cases where the original papers made a distinction, the data were combined.

b Median.

c Percentage of stations with detections.

d Open-ocean seawater (filtrate) samples. Chlordane was not detected in microlayer samples.

e Sum of cis-chlordane, trans-chlordane, and trans-nonachlor.

f Wet weight.

g NOAA’s Status and Trends Mussel Watch Program.

h cis isomer.

i On-site.

j Off-site.

k Arlington, Tennessee; Brick Township, New Jersey; Brunswick, Maine; Sorreto, Louisiana; Gallaway, Tennessee; Niagara Falls, New York; Lewisburg, Tennessee; Sacramento, California; Toone, Illinois; Marshall, Illinois; Jacksonville, Arkansas.

l Sites, includes background, green, tee, and fairway sites at four golf courses.

m Concentrations above the solubility limit may be the result of a cosolvent such as kerosene.

n Random sample.

o Range of positive detections.

ECD = electron capture detector; GC = gas chromatography; MS = mass spectroscopy; ND = not detected; NPL = National Priorities List; NS = not specified

Groundwater monitoring data from 479 disposal site investigations detected chlordane in 23 samples at 10 sites, ranking it 80^th^ among the 208 RCRA Appendix IX organic chemicals investigated (Plumb 1991). According to the EPA database Pesticides in Groundwater, chlordane was confirmed in groundwater only in Massachusetts as a result of normal agricultural use and only in Idaho from a point source (Ritter 1990; Williams et al. 1988b). Based on average chlordane concentrations in EPA’s STORET database for 1978–1987, the western south-central section of the United States had the highest concentrations of chlordane in groundwater and New England had the lowest (Phillips and Birchard 1991). The presence of chlordane in groundwater at Cape Cod golf courses is thought to be due to macropore flow of particle-bound pesticide or contamination during well construction (Cohen et al. 1990). Chlordane was used at these golf courses from the 1950s to 1970s.

### 5.5.3 Sediment and Soil

Table 5-8 summarizes results from studies that measured chlordane levels in soils prior to 1990. Chlordane was detected in both rural and urban soils in concentrations from <1 ppb to 141 ppm. In general monitoring programs of rural and urban soils, chlordane was consistently found; however, detections generally mirrored use patterns and were, for the most part, from studies performed in the late 1960s to middle 1970s. Very few more recent general soil monitoring data were available; these data show that chlordane was still present in soils, but insufficient detections are available to estimate any trends. A sampling of soil around New Orleans’ houses treated with chlordane showed that chlordane levels were variable. Mean residue levels sampled at 30 houses varied from 22 to 2,540 ppm (Delaplane and LaFage 1990).

Sediment concentrations of chlordane in Great Lakes harbors and a tributary of the Missouri River in Missouri ranged from 1.4 to 14 ppb and 1.5 to 310 ppb, respectively (Puri et al. 1990; Verbrugge et al. 1991). A Missouri study performed in the 1980s demonstrated that chlordane in sediment of Missouri streams correlated with urban development (Puri et al. 1990). Chlordane levels in sediment from predominately agricultural areas were approximately 2 orders of magnitude lower than in urban areas. Based on average chlordane concentrations in EPA’s STORET database for 1978–1987, the western north-central section of the United States had the highest concentrations of chlordane in sediment, and New England had the lowest (Phillips and Birchard 1991).

Table 5-8 Detection of Chlordane in Soils^a^

Media type/location | Sampling dates | Number of samples | Sample type | Analytical method | Concentration (ppm) | | Percent occurrence | Reference
Media type/location | Sampling dates | Number of samples | Sample type | Analytical method | Range | Mean | Percent occurrence | Reference
Urban
Baltimore, Maryland | 1971 | 156 | NS | GC/ECD | 0.01–12.35 | 0.21 | 37 | Carey et al. 1979a
Gadsden, Alabama | 1971 | 55 | NS | GC/ECD | 0.04–0.46 | 0.07 | 5 | Carey et al. 1979a
Hartford, Connecticut | 1971 | 48 | NS | GC/ECD | 0.02–141 | 4.0 | 48 | Carey et al. 1979a
Macon, Georgia | 1971 | 43 | NS | GC/ECD | 0.07–0.91 | 0.8 | 26 | Carey et al. 1979a
Newport News, Virginia | 1971 | 78 | NS | GC/ECD | 0.09–7.29 | 0.16 | 13 | Carey et al. 1979a
Bakersfield, California | 1969 | 50 | Grab | GC/ECD | 0.07–20.5 | 0.78 | 30 | Wiersma et al. 1972
Camden, New Jersey | 1969 | 50 | Grab | GC/ECD | 0.39–5.90 | 0.36 | 16 | Wiersma et al. 1972
Houston, Texas | 1969 | 50 | Grab | GC/ECD | 0.04–12.9 | 0.66 | 34 | Wiersma et al. 1972
Manhattan, Kansas | 1969 | 50 | Grab | GC/ECD | 0.03–4.86 | 0.30 | 40 | Wiersma et al. 1972
Miami, Florida | 1969 | 50 | Grab | GC/ECD | 0.04–16.9 | 1.59 | 64 | Wiersma et al. 1972
Milwaukee, Wisconsin | 1969 | 50 | Grab | GC/ECD | 0.05–10.2 | 0.45 | 34 | Wiersma et al. 1972
Salt Lake City, Utah | 1969 | 50 | Grab | GC/ECD | 0.02–7.50 | 0.41 | 38 | Wiersma et al. 1972
Waterbury, Connecticut | 1969 | 50 | Grab | GC/ECD | 0.02–8.74 | 0.96 | 28 | Wiersma et al. 1972
Fresno-Clovis, California | NS | NS | Grab | NS | <0.03–2.70 | NS | NS | Nightingale 1987
Belmont Lake, New York bank soil | 1982 | NS | Grab | GC/ECD | <0.002–0.003 | NS | NS | Wood et al. 1986
New Orleans, Louisiana (30 treated homes) | 10/86 | 240 | Grab | GC/ECD | 0.6–14,464 | 854.9 | 100 | Delaplane and LaFage 1990
Rural
Illinois | 1970 | 69 | NS | GC/ECD | 0.05–1.32 | 0.09 | 23 | Carey et al. 1973
Indiana | 1970 | 36 | NS | GC/ECD | 0.29–4.30 | 0.20 | 8.3 | Carey et al. 1973
Iowa | 1970 | 76 | NS | GC/ECD | 0.17–3.35 | 0.13 | 15 | Carey et al. 1973
Kansas | 1970 | 28 | NS | GC/ECD | 0.32–0.54 | 0.03 | 7.1 | Carey et al. 1973
Kentucky | 1970 | 1 | NS | GC/ECD | ND | ND | 0 | Carey et al. 1973
Michigan | 1970 | 14 | NS | GC/ECD | ND | ND | 0 | Carey et al. 1973
Minnesota | 1970 | 37 | NS | GC/ECD | 0.87 | 0.02 | 3 | Carey et al. 1973
Missouri | 1970 | 31 | NS | GC/ECD | 0.14–0.53 | 0.02 | 6 | Carey et al. 1973
Nebraska | 1970 | 47 | NS | GC/ECD | ND | ND | 0 | Carey et al. 1973
Ohio | 1970 | 29 | NS | GC/ECD | ND | ND | 0 | Carey et al. 1973
South Dakota | 1970 | 26 | NS | GC/ECD | ND | ND | 0 | Carey et al. 1973
Wisconsin | 1970 | 5 | NS | GC/ECD | 0.05 | 0.01 | 20 | Carey et al. 1973
Everglades National Park | 5/76 | 25 | Grab | GC/ECD | <0.001–0.0048 | 0.00226 | 52 | Requejo et al. 1979
Agricultural land, Florida | 5/76 | 7 | Grab | GC/ECD | <0.001–0.195 | 0.088 | 43 | Requejo et al. 1979
Cropland, California | 1969 | NS | Grab | GC/ECD | NR | 0.01 | NR | Wiersma et al. 1972
Cropland, New Jersey, Delaware, Maryland | 1969 | NS | Grab | GC/ECD | NR | <0.01 | NR | Wiersma et al. 1972
Cropland, Florida | 1969 | NS | Grab | GC/ECD | NR | 0.36 | NR | Wiersma et al. 1972
Cropland, Wisconsin | 1969 | NS | Grab | GC/ECD | NR | 0.01 | NR | Wiersma et al. 1972
Urban
Cropland, Arizona, New Mexico, Nevada, Utah | 1969 | NS | Grab | GC/ECD | NR | 0.02 | NR | Wiersma et al. 1972
Cropland, Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut | 1969 | NS | Grab | GC/ECD | NR | 0.01 | NR | Wiersma et al. 1972
Cropland, 37 states | 1971 | 1,486 | Grab | GC/ECD | 0.01–6.98 | 0.06 | 8 | Carey et al. 1978
Cropland, 37 states | 1972 | 1,483 | Grab | GC/ECD | 0.01–7.89 | 0.05 | 7.9 | Carey et al. 1979b
Other
Cape Cod golf courses | 1986–1987 | 12^b^ | Soil core | GC/ECD | ND–4.310 | 2.278^c^ | 58 | Cohen et al. 1990
NPL sites
Holbrook, Massachusetts | NS | NS | NS | NS | NS | NS | NS | VIEW 1988
Sorreto, Louisiana | NS | NS | NS | NS | NS | NS | NS | VIEW 1988
Cape Girardeau, Missouri | NS | NS | NS | NS | 30^d^ | NS | NS | VIEW 1988
Lewisburg, Tennessee | NS | NS | NS | NS | 0.1^e^ | NS | NS | VIEW 1988
Memphis, Tennessee | NS | NS | NS | NS | 57^e^ | NS | NS | VIEW 1988
West Chester, Ohio | NS | NS | NS | NS | NS | NS | NS | VIEW 1988
Toome, Tennessee | NS | NS | NS | NS | NS | NS | NS | VIEW 1988
Marshall, Illinois | NS | NS | NS | NS | 48.3^e^ | NS | NS | VIEW 1988
Jacksonville, Arkansas | NS | NS | NS | NS | NS | NS | NS | VIEW 1988
Marshall, Illinois | NS | NS | NS | NS | ND–69^d^ | NS | NS | ATSDR 1989b
Marshall, Illinois | NS | NS | NS | NS | ND–0.760^e^ | NS | NS | ATSDR 1989b
Holbrook, Massachusetts | NS | 36^f^ | Grab | GC/ECD | ND–334 | NS | 86 | Callahan et al. 1991

a No distinction is made between the isomers of chlordane. In cases where the original papers made a distinction, the data were combined.

b Three sites and four depths.

c Average of three surface cores; not detected at and below 2.0, 24, and 5.8 feet at three sites.

d On-site.

e Off-site.

f Locations.

ECD = electron capture detector; GC = gas chromatography; ND = not detected; NPL = National Priorities List; NS = not specified

More recently, Martinez et al. (2012) conducted an urban soil study analyzing chlordane in 66 soil samples taken on August 25th, 2008, in Cedar Rapids, Iowa, where major flooding occurred 70 days prior to the samples being taken. The samples were primarily taken from residential land use areas in the flooding zone downstream and west of the main urban river (Cedar River) that flooded. Chlordane levels in Cedar River had not been previously identified, though chlordane was detected at high levels in an urban lake that also flooded. Chlordane samples were analyzed using a gas chromatography/mass selective detector mode (GC/MSD) in selected ion monitoring mode. Chlordane concentrations in soil ranged from 0 to 7,500 ng/g dry weight, though the distribution was highly skewed (median 4 ng/g dry weight; mean 130 ng/g dry weight). Generally, trans-nonachlor (median 1.8 ng/g dry weight; mean 24.0 ng/g dry weight) was found at higher concentrations than cis-chlordane (median 1.0 ng/g dry weight; mean 64.0 ng/g dry weight) and trans-chlordane (median 0.86 ng/g dry weight; mean 40 ng/g dry weight). No spatial correlation between the samples was found. Additionally, no significant difference was found between samples collected inside or outside the flooding area. The mean ratios for the soil samples in this study are: cis-chlordane:trans-chlordane 1.40±0.48; trans-chlordane:trans-nonachlor 40±1.50; and cis-chlordane:trans-nonachlor 0.96±1.50. Given these ratios, it is likely that significant weathering of technical chlordane occurred if direct soil application was the source of the observed concentrations.

### 5.5.4 Other Media

Chlordane has been detected in many other media. Tables 5-9, 5-10, 5-11, and 5-12 summarize results from studies that evaluated chlordane in food, aquatic organisms, terrestrial organisms, and human samples, respectively, prior to 1992.

Based on average chlordane concentrations in EPA’s STORET database for 1978–1987, the western south-central section of the United States had the highest concentrations of chlordane in fish tissue, and New England had the lowest (Phillips and Birchard 1991). Total chlordane concentrations in bluefish fillet were reduced an average 29% by trimming those portions of fillet with the highest concentrations of lipid, such as the skin, dorsal fat, and bellyflap (Sanders and Haynes 1988). Cooking did not significantly change the chlordane concentration in bluefish (Trotter et al. 1989).

Table 5-9 Detection of Chlordane in Food^a^

Media type/location | Sampling dates | Number of samples | Sample type | Analytical method | Concentration (ppm) | | Percent occurrence | Reference
Media type/location | Sampling dates | Number of samples | Sample type | Analytical method | Range | Mean | Percent occurrence | Reference
Total adult food groups
United States^b^ | 1990–1991 | 936 | Composite | NS | NS | NS | 1 | FDA 1991
United States^b^ | 1989–1990 | 936 | Composite | NS | NS | NS | <1 | FDA 1990
United States^b^ | 1987–1988 | 1,170 | Composite | NS | NS | NS | 4 | FDA 1989a
United States^b^ | 1982–1984 | 1,872 | Composite | NS | NS | NS | <1 | Gunderson 1988
10 State survey | 1988–1989 | 13,085 | Composite | NS | NS | NS | 0.09 | Minyard and Roberts 1991
10 State survey | 1987–1988 | 13,980 | Composite | NS | NS | NS | 0.05 | Minyard and Roberts 1991
United States^b^ | 1978–1985 | 1,044 | Composite | NS | NS | NS | 7 | Yess et al. 1991
United States | 1980–1982 | 324 | Composite | GC/MS | ND–0.0021 | 0.0004 | 1.2 | Gartrell et al. 1986a
United States | 1979–1980 | 240 | Composite | GC/MS | ND–0.0107 | 0.003 | 0.42 | Gartrell et al. 1985a
United States | 1977–1978 | 240 | Composite | NS | ND–0.001 | NS | 1.25 | Podrebarac 1984a
United States | 1976–1977 | 300 | Composite | GC/MS | ND–trace | NS | 0.67 | Johnson et al. 1984b
United States | 1975–1976 | 240 | Composite | GC/MS | ND–trace | NS | 0.83 | Johnson et al. 1981a
United States | 1973–1974 | 360 | Composite | GC+TLC | ND–trace | NS | 0.28 | Manske and Johnson 1977
United States | 1972–1973 | 360 | Composite | NS | ND–trace | NS | 0.28 | Johnson and Manske 1976
United States | 1971–1972 | 420 | Composite | NS | ND–0.59 | NS | 0.24 | Manske and Johnson 1975
United States | 1969–1970 | 360 | Composite | GC/ECD+TLC | ND | ND | 0 | Corneliussen 1972
United States | 1968–1969 | 360 | Composite | GC/ECD+TLC | 0.026–0.043^c^ | 0.035^c^ | 0.56 | Corneliussen 1970
United States | 1966–1967 | 360 | Composite | GC/ECD+TLC | 0.005–0.02^c^ | 0.013^c^ | 0.56 | Martin and Duggan 1968
United States | 1965–1966 | 432 | Composite | GC+TLC | ND–0.37 | NS | 0.23 | Duggan et al. 1967
United States | 1964–1965 | 216 | Composite | GC/ECD+TLC | ND–0.033 | NS | 0.46 | Duggan et al. 1966
Total toddler food groups
United States | 1980–1982 | 143 | Composite | GC/MS | ND–0.005 | NS | 0.7 | Gartrell et al. 1986b
United States | 1979–1980 | 110 | Composite | GC/MS | ND–0.0008 | NS | 0.91 | Gartrell et al. 1985b
United States | 1977–1978 | 606 | Composite | GC/MS | 0.010–0.028^c^ | 0.019^c^ | 0.33 | Podrebarac 1984b
United States | 1976–1977 | 687 | Composite | GC/MS | ND–trace | NS | 0.15 | Johnson et al. 1984a
United States | 1975–1976 | NS | Composite | GC/MS | ND–0.137 | NS | NS | Johnson et al. 1981b
Total infant food groups
United States | 1977–1978 | 417 | Composite | GC/MS | ND–0.020 | NS | 0.24 | Podrebarac 1984b
United States | 1976–1977 | 445 | Composite | GC/MS | ND–trace | NS | 0.22 | Johnson et al. 1984a
United States | 1975–1976 | NS | Composite | GC/MS | ND–trace | NS | NS | Johnson et al. 1981b
Dairy products
Illinois | 1972–1981 | 3,618 | Individual | GC, bovine milk | ND–>0.3 | NS | 53.4 | Steffey et al. 1984
United States | NS | NS | Cow milk, cheese | GC/MS | NS | Detected^d^ | NS | Lawrence et al. 1970
Animal products
Ontario, Canada | 1986–1988 | 539 | Abdominal fat | GC/ECD | <0.001 | NS | NS | Frank et al. 1990
Domestic animals
Ontario, Canada | 1986–1988 | 63 | Hen’s eggs | GC/ECD | <0.001 | NS | NS | Frank et al. 1990
Seafood
United States aquaculture areas | 1990 | 172 | Fish/shellfish | NS | <0.01–0.13 | NS | 5 | FDA 1991
Produce
United States | 1989–1991 | 6,970 | Fruits/vegetables | GC/ECD | ND^e^ | ND | 0 | Schattenberg and Hsu 1992

a No distinction is made between the isomers of chlordane. In cases where the original papers made a distinction, the data were combined.

b FDA’s Total Diet Study.

c Range of positive detection.

d Chlordane and a metabolite of chlordane (1-exo-2-endo-4,5,6,7,8,8-octachloro-2,3-exo-epoxy-2,3,3a,4,7,7a-hexahydro-4,7-methanoindene) were detected.

e Detection limit is 0.625 ppm.

ECD = electron capture detector; FDA = U.S. Food and Drug Administration; GC = gas chromatography; MS = mass spectroscopy; ND = not detected; NS = not specified; TLC = thin-layer chromatography

Table 5-10 Detection of Chlordane in Aquatic Organisms

Isomer | Sampling location | Dates | Number of samples | Sample type | Analytical method (detection limit) | Concentration (ppm) | | Percent occurrence | Reference
Isomer | Sampling location | Dates | Number of samples | Sample type | Analytical method (detection limit) | Range | Mean | Percent occurrence | Reference
Fish
cis, trans | Major United States watersheds^a^ | 1980–1981 | 315 | Whole fish, composite | GC (0.01 ppm wet weight) | ND–0.36 | 0.03 | 73.8 | Schmitt et al. 1985
cis, trans | Major United States watersheds^a^ | 1980–1981 | 315 | Whole fish, composite | GC (0.01 ppm wet weight) | ND–0.22 | 0.02 | 72.0 | Schmitt et al. 1985
cis, trans | Major United States watersheds^a^ | 1978–1979 | NS | Whole fish, composite | GC (0.01 ppm wet weight) | ND–2.53 | 0.07 | 94.4 | Schmitt et al. 1985
cis, trans | Major United States watersheds^a^ | 1978–1979 | NS | Whole fish, composite | GC (0.01 ppm wet weight) | ND–0.54 | 0.02 | 70.4 | Schmitt et al. 1985
cis, trans | Major United States watersheds^a^ | 1976–1977 | NS | Whole fish, composite | GC (0.01 ppm wet weight) | ND–0.93 | 0.06 | 92.5 | Schmitt et al. 1985
cis, trans | Major United States watersheds^a^ | 1976–1977 | NS | Whole fish, composite | GC (0.01 ppm wet weight) | ND–0.32 | 0.03 | 84.0 | Schmitt et al. 1985
cis, trans | 13 Lake Michigan tributaries | Fall 1983 | 26 | Whole fish, composite | GC/ECD (0.005 ppm wet weight) | ND–0.211 | NS | NS | Camanzo et al. 1987
cis, trans | 13 Lake Michigan tributaries | Fall 1983 | 26 | Whole fish, composite | GC/ECD (0.005 ppm wet weight) | ND–0.025 | NS | NS | Camanzo et al. 1987
cis, trans | Grand Traverse Bay (Lake Michigan) | Fall 1983 | 2 | Whole fish^b,c^ composite | GC/ECD (0.005 ppm wet weight) | 0.015–0.037 | NS | NS | Camanzo et al. 1987
cis, trans | Grand Traverse Bay (Lake Michigan) | Fall 1983 | 2 | Whole fish^b,c^ composite | GC/ECD (0.005 ppm wet weight) | 0.003–0.005 | NS | NS | Camanzo et al. 1987
cis, trans | Wabash River (Indiana) | NS | 1 | Whole fish, composite | MID GC/MS (0.0005 ppm wet weight) | – | 0.00854 | 100 | Kuehl et al. 1980
cis, trans | Wabash River (Indiana) | NS | 1 | Whole fish, composite | MID GC/MS (0.0005 ppm wet weight) | – | 0.01298 | 100 | Kuehl et al. 1980
cis and trans | Ashtabula River (Oklahoma) | NS | 1 | Whole fish, composite | MID GC/MS (0.0005 ppm wet weight) | – | ND | 0 | Kuehl et al. 1980
cis, trans | Great Lakes and major watersheds of the Great Lakes weight) | 1979 | 48 | Whole fish, composite | MID GC/MS (0.020 ppm wet weight) | ND–0.61 | 0.090 | 79.2 | Kuehl et al. 1983
cis, trans | Great Lakes and major watersheds of the Great Lakes weight) | 1979 | 48 | Whole fish, composite | MID GC/MS (0.020 ppm wet weight) | ND–0.52 | 0.098 | 87.5 | Kuehl et al. 1983
cis and trans | Major United States watersheds | 1976 | 58 | Whole fish, composite | GC/MS | NS | NS | 36.2 | Veith et al. 1979
cis and trans | 13 sites located along a 125-mile stretch of the Kansas River | 1986 | 25 | Whole fish, composite | GC/ECD (0.03 ppm wet weight) | ND–2.1 | 0.25 | 68.0 | Arruda et al. 1987
cis and trans | Siskiwit Lake on Isle Royal in Lake Superior | 1983 | 4 | Whole fish, composite^c^ | GC/MS (0.001 ppm)^d^ | 0.23–0.77^d^ | 0.42^d^ | NS | Swackhamer and Hites 1988
cis and trans | Siskiwit Lake on Isle Royal in Lake Superior | 1983 | 4 | Whole fish, composite^c^ | GC/MS (0.001 ppm)^d^ | 0.23–0.77^d^ | 0.42^d^ | NS | Swackhamer and Hites 1988
cis and trans | Siskiwit Lake on Isle Royal in Lake Superior | 1983 | 3 | Whole fish, composite^e^ | GC/MS (0.001 ppm)^d^ | 0.14–0.33^d^ | 0.26^d^ | NS | Swackhamer and Hites 1988
cis and trans | Siskiwit Lake on Isle Royal in Lake Superior | 1983 | 3 | Whole fish, composite^e^ | GC/MS (0.001 ppm)^d^ | 0.14–0.33^d^ | 0.26^d^ | NS | Swackhamer and Hites 1988
cis and trans | Lake Texoma (Texas and Oklahoma) | October 1979 | 14^f^ | Fillets | GC/ECD (0.001 ppm) | 0.002 (maximum)^f^ | 0.017 (median)^f^ | NS | Hunter et al. 1980
cis and trans | Lake Texoma (Texas and Oklahoma) | October 1979 | 47^g^ | Fillets | GC/ECD (0.001 ppm) | 0.008 (maximum)^g^ | NS | NS | Hunter et al. 1980
cis and trans | Lake Texoma (Texas and Oklahoma) | October 1979 | 38^h^ | Fillets | GC/ECD (0.001 ppm) | 0.024 (maximum)^h^ | NS | NS | Hunter et al. 1980
cis and trans | Tuttle Creek Lake (Kansas) | 1985 | 20 | Fillets | EPA method 608 (0.0008 ppm) | ND–0.113 | NS | 90 | KDHE 1988
trans | Atchafalaya River basin (Louisiana) | June 1981 | NS | Whole fish, composite | GC/ECD (NS) | ND–0.1 | NS | NS | Winger and Andreasen 1985
cis and trans | Chesapeake Bay and tributaries (Maryland) | 1980 | 24 | Fillets^i^ | GC/ECD (0.001 ppm wet weight) | 0.004–0.31 | 0.12 | NS | Eisenberg and Topping 1985
cis and trans | Chesapeake Bay and tributaries (Maryland) | 1979 | 98 | Fillets^i^ | GC/ECD (0.001 ppm wet weight) | ND–0.70 | 0.08 | NS | Eisenberg and Topping 1985
cis and trans | Chesapeake Bay and tributaries (Maryland) | 1978 | 15 | Fillets^i^ | GC/ECD (0.001 ppm wet weight) | ND–0.50 | 0.013 | NS | Eisenberg and Topping 1985
cis and trans | San Joaquin River and tributaries (California) | July 1981 | 8 | Whole fish, composite^j^ | GC/ECD (0.004 ppm wet weight) | ND–0.021 | 0.011 | 50 | Saiki and Schmitt 1986
cis and trans | San Joaquin River and tributaries (California) | July 1981 | 8 | Whole fish, composite^b^ | GC/ECD (0.004 ppm wet weight) | 0.012–0.273 | 0.077 | 100 | Saiki and Schmitt 1986
cis and trans | Lake Ontario (4 sites) | 1977–1978 | 1,718 | Whole fish | GC/ECD | 0.04–0.14^c,k^ | NS | NS | Borgmann and Whittle 1991
cis and trans | Major United States watersheds (112 sites)^l^ | 1984 | 321 | Fish tissue, composite | GC/ECD | <1.01^m^ | 0.06 | 85^n^ | Schmitt et al. 1990
Chlordanes^o^ | Major United States watersheds (112 sites)^l^ | 1984 | 321 | Fish tissue, composite | GC/ECD | <2.75^p^ | 0.11^q^ | 89^n^ | Schmitt et al. 1990
trans | Lower Mississippi basin | 7/87–8/87 | 17^u^ | Whole catfish | GC/MS | 0.011–0.170 | 0.062 | 100 | Leiker et al. 1991
Oysters
cis | Gulf of Mexico (49 site)^r^ | 1986 | 147 | Composite | GC/ECD | 0.91–96.3^s^ | 10.9 | 100 | Sericano et al. 1990
cis | Gulf of Mexico (48 site)^r^ | 1987 | 143 | Composite | GC/ECD | 0.65–292^t^ | 14.1 | 100 | Sericano et al. 1990
Clams
cis and trans | Portland (Maine) | November 1980 | 2 | Whole body, composite | GC/FID (0.00003 ppm) | ND–0.0018 | NS | 50 | Ray et al. 1983

a 107 stations located at key locations in major rivers throughout the United States and Great Lakes.

b Carp.

c Lake trout.

d Expressed on a lipid basis.

e Whitefish.

f Herbivores (gizzard shad).

g Detrivores (carp, channel catfish, smallmouth buffalo, river carpsucker).

h Carnivores (striped bass, white crappie, largemouth bass, blue catfish, flathead catfish).

i Finfish.

j Bluegill sunfish.

k Range of annual logarithmic means.

l National Contaminant Biomonitoring Program.

m Highest station mean Honolulu, Hawaii (0.6 ppm), next highest station (0.3 ppm), Saugatuck, Michigan.

n Positive sites (for isomer with highest number of positive sites).

o cis- and trans-chlordane, oxychlordane, and cis- and trans-nonachlor.

p Highest station mean in Honolulu, Hawaii (1.8 ppm), next highest station (0.8 ppm), Saugatuck, Michigan. Component composition is 1.00 ppm trans-nonachlor, 0.66 ppm cis-chlordane, 0.45 ppm cis-nonachlor, 0.35 ppm trans-chlordane, and 0.29 oxychlordane.

q Component composition is 0.03 trans-nonachlor, 0.03 ppm cis-chlordane, 0.02 ppm cis-nonachlor, 0.02 ppm trans-chlordane, and 0.01 ppm oxychlordane.

r NOAA’s Status and Trends Mussel Watch Program.

s The range, mean, and frequency for trans-nonachlor are 0.60–71.9 ppb, 10.0 ppb, and 100%, respectively.

t The range, mean, and frequency for trans-nonachlor are <0.25–289 ppb, 11.6 ppb, and 99%, respectively.

u Sites; number of fish per site varied from 1 to 4.

EPA = U.S. Environmental Protection Agency; GC = gas chromatography; ECD = electron capture detector; FID = flame ionization detector; MS = mass spectroscopy; MID = multiple ion detector; ND = not detected; NS = not stated

Table 5-11 Detection of Chlordane in Terrestrial Organisms^a^

Species/location | Sampling dates | Number of samples | Sample type | Analytical method | Concentration (ppm) | | Percent occurrence | Reference
Species/location | Sampling dates | Number of samples | Sample type | Analytical method | Range | Mean | Percent occurrence | Reference
Birds
Herons, egrets, kingfishers, sandpipers
Corpus Christi, Texas | 1983 | 10 | Eggs | GC/ECD | ND–0.88 | 0.14^b^ | NS | White and Krynitsky 1986
Loving, New Mexico | 1983 | 10 | Eggs | GC/ECD | ND | ND | NS | White and Krynitsky 1986
Artesia, New Mexico | 1983 | 10 | Eggs | GC/ECD | ND–0.36 | 0.07^b^ | NS | White and Krynitsky 1986
Louisiana | 1978–1979 | <10 | Whole body | GC/ECD | <0.05 | ND | NS | Dowd et al. 1985
Colorado Wyoming | 1979 | 147 | Eggs | GC/ECD+MS | 0.08–0.23^c^ | 0.14 | 5.4 | McEwen et al. 1984
United States | 1966–NS | 105 | Carcass | GC/ECD+MS | ND–1.8^d^ | NS | 23.8 | Ohlendorf et al. 1981
United States | 1966–NS | 48 | Brains | GC/ECD+MS | ND–1.4 | NS | 42.2 | Ohlendorf et al. 1981
Sheboygan River, Wisconsin | 1976–1980 | 11 | Carcass, brains | GC/ECD+MS | ND–0.22 | NS | NS | Heinz et al. 1984
Re-footed booby, sooty tern and shearwater
Hawaii | 1980 | 143 | Eggs, stomach | GC/ECD+MS | ND | ND | 0 | Ohlendorf and Harrison 1986
Brown or white pelicans
Louisiana | 1971–1976 | 117 | Eggs | GC/ECD | ND–1.31 | 0.36 | NS | Blus et al. 1979
Klamath Basin, California | 1969–1981 | 45 | Eggs | GC/MS | <0.1–0.12 | NS | 6.7 | Boellstorff et al. 1985
Comorant, black skimmer, western grebe
Galviston Bay, Texas | 1980–1981 | 6 | Eggs | GC/ECD+MS | ND–0.6 | NS | <50 | King and Krynitsky 1986
Galviston Bay, Texas | 1980–1982 | 13 | Eggs | GC/ECD+MS | ND–0.7 | NS | <50 | King and Krynitsky 1986
South Texas and Mexico | 1983 | 30 | Carcass | NS | <0.1–<0.3 | NS | 20 | White et al. 1985
Klamath Basin, California | 1981 | 12 | Eggs | GC/MS | <0.1–0.25^e^ | NS | >16.7 | Boellstorff et al. 1985
Clapper rails, gallinules and limpkins, dunlins
Avalon, New Jersey | 1973 | NS | Carcass | GC/ECD+MS | ND–0.12^f^ | NS | NS | Klaas and Belisle 1977
Virginia, South Carolina, New Jersey | 1972–1973 | 49 | Eggs | GC/ECD+MS | ND–<0.10^c^ | NS | 20^c^ | Klaas et al. 1980
Florida, South Carolina, Louisiana | 1973–1974 | NS | Eggs | GC/ECD+MS | ND | ND | 0 | Klaas et al. 1980
Sarnish Bay, Washington | 1980 | 8 | Whole body | GC/MS | 0.008–0.06 | 0.02 | 100 | Schick et al. 1987
Bowerman Basin, Washington | 1980 | 5 | Whole body | GC/MS | 0.003–0.005 | 0.004 | 100 | Schick et al. 1987
Gulls, common eider
Virginia, Maine | 1977 | 116 | Eggs | GC | 0.00–0.50^f^ | 0.09^c^ | >26.7 | Szaro et al. 1979
Appledore Island, Massachusetts | 1977 | 30 | Eggs | GC | ND | ND | 0 | Szaro et al. 1979
Appledore Island, Massachusetts | 1977 | 28 | Eggs | GC | 0.0–0.50 | 0.04 | 21.4 | Szaro et al. 1979
Appledore Island, Massachusetts | 1977 | 28 | Eggs | GC | 0.0–0.43^f^ | 0.22 | 96.4 | Szaro et al. 1979
Galviston, Texas | 1980–1981 | 10 | Eggs | GC/ECD+MS | 0.1–1.2^c^ | 0.29 | >50 | King and Krynitsky 1986
Bangs Island, Massachusetts | 1977 | 30 | Eggs | GC | ND | ND | 0 | Szaro et al. 1979
Ducks
Atlantic flyway | 1976–1977 | NS | Wings | GC/ECD | 0.01–0.06 | NS | 57 | White 1979
Mississippi flyway | 1976–1977 | NS | Wings | GC/ECD | 0.01–0.02 | NS | 22 | White 1979
Central flyway | 1976–1977 | NS | Wings | GC/ECD | 0.01–0.02 | NS | 14 | White 1979
Pacific flyway | 1976–1977 | NS | Wings | GC/ECD | 0.01–0.02 | NS | 14 | White 1979
United States | 1981–1982 | NS | Wings | GC/MS | <0.01–0.05 | NS | 10^g^ | Prouty and Bunck 1986
Chesapeake Bay, Maryland | 1973, 1975 | 142 | Carcass | GC/MS | ND–NS | 0.19 | 6.3 | White et al. 1979
Osprey, eagles, owls, hawks
Barnegat Bay, New Jersey | 1971, 1974 | 9 | Eggs | GC/ECD+MS | ND–0.55^e^ | 0.20^c^ | 78 | Wiemeyer et al. 1978
Avalon-Stone Harbor, New Jersey | 1979, 1972 | 8 | Eggs | GC/ECD+MS | ND–0.08^e^ | 0.03 | 50 | Wiemeyer et al. 1978
United States | 1964–1973 | 26 | Carcass, brains | GC/ECD+MS | <0.1–1.7^e,h^ | NS | >69.2 | Wiemeyer et al. 1980
United States | 1971–1974 | 38 | Carcass | GC/MS | NS | 27^e^ | NS | Barbehenn and Reichel 1981
United States | 1971–1974 | 38 | Brain | GC/MS | NS | 0.27^e^ | NS | Barbehenn and Reichel 1981
United States | 1971–1974 | 24 | Carcass | GC/MS | NS | 15^f^ | NS | Barbehenn and Reichel 1981
United States | 1971–1974 | 24 | Brain | GC/MS | NS | 0.15^f^ | NS | Barbehenn and Reichel 1981
United States | 1969–1979 | 6 | Eggs | GC/ECD+MS | ND–3.6 | 0.39^c^ | 63.5 | Wiemeyer et al. 1984
Maryland, Alabama | 1978–1981 | 2 | Carcass, brains | NS | 1.1–2.4 | 1.65 | 100 | Blus et al. 1983
Corvallis, Oregon | 1980 | 1 | Brains | NS | 0.1 | 1.1 | 100 | Blus et al. 1983
Starling
United States | 1979, 1982 | NS | Carcass | GC/MS | <0.01–0.04 | 0.02^c^ | 3.3^i^ | Bunck et al. 1987
Pheasants
Kansas | 1982–1983 | NS | Carcass | NS | ND | ND | 0 | Layher et al. 1985
Other vertebrates
Turtles
Merritt Island National Wildlife Refuge, Laurel Maryland | 1979 | 56 | Eggs | GC/ECD+MS | ND–<0.008^f^ | ND | 28.6^f^ | Clark and Krynitsky 1985
New Jersey, Maryland | 1981–1982 | 32 | Visceral fat | GC/ECD+MS | ND–>9.33^f^ | 3.9^c^ | >88^f^ | Albers et al. 1986
Crocodiles
Patuxent Wildlife Research Center, Laurel, Maryland | 1977–1978 | 23 | Eggs | GC/ECD | <0.01–0.07 | 0.02^f,c^ | 87.5^j^ | Hall et al. 1979
Raccoons
Lake Verret, Louisiana | 1978–1979 | <10 | Leg muscles | GC/ECD | <0.05 | ND | NS | Dowd et al. 1985
Plaquemine-Brule, Louisiana | 1978–1979 | <10 | Leg muscles | GC/ECD | <0.05 | ND | NS | Dowd et al. 1985
East Franklin, Louisiana | 1978–1979 | <10 | Leg muscles | GC/ECD | <0.05–NS | 0.017^k^ | NS | Dowd et al. 1985
Big brown bats
Gaithersburg, Maryland | 1973 | 18 | Carcass, brains | GC/ECD | ND–<0.40^f^ | NS | 50 | Clark and Lamont 1976
Earthworms
Holbrook, Massachusetts | NS | 29^l^ | Whole body | GC/ECD | 0.8–12.9 | NS | 45 | Callahan et al. 1991
Insects
Moths
Washington, DC–Baltimore, Maryland | 1977–1979 | NS | Whole body | GLC/MS | <0.05–0.75 | 0.22 | NS | Beyer and Kaiser 1984
Meadow grasshopper
Palermo, New Jersey | 1973 | NS | NS | GC/ECD+MS | ND–0.02^e^ | NS | NS | Klaas and Belisle 1977
Honey bees
Connecticut | 1983–1985 | NS | Whole body, 20 brood combs | GC/ECD | 0.06–0.69^c^ | NS | 7.5^m^ | Anderson and Wojtas 1986

a No distinction is made between the isomers of chlordane. In cases where the original papers made a distinction, the data were combined.

b Geometric mean.

c Range of positive detections.

d Oxychlordane and trans-nonachlor were reported in paper at ranges of ND–0.87 and ND–3.0, respectively.

e cis-Chlordane and/or trans-nonachlor.

f Oxychlordane included in mixture.

g Value describes number of detections divided by the number of pools.

h Oxychlordane was also detected, range ND–0.15, frequency >12%.

i Percent of pools with detectable residues of organochlorine compounds.

j cis-Chlordane, trans-nonachlor or oxychordane was detected in 7 out of 8 clutches.

k Mean was exceeded by the standard error.

l Earthworms were exposed on-site for 7 days.

m Chlordane was detected in 4 out of 57 apiaries.

ECD = electron capture detector; GC = gas chromatography; GLC = gas-liquid chromatography; MS = mass spectroscopy; ND = not detected; NS = not specified

Table 5-12 Detection of Chlordane in Human Samples^a^

Media type/location | Sampling dates | Number of samples | Sample type | Analytical method | Concentration (ppb) | | Percent occurrence | Reference
Media type/location | Sampling dates | Number of samples | Sample type | Analytical method | Range | Mean | Percent occurrence | Reference
Human adipose tissue
United States | 1976–1980 | 785 | General | GC/ECD+MS | ND–>10^b^ | NS | 95 | Murphy et al. 1983
United States | NS | 8 | General | NCI/MS | ND–>1 | NS | 87.5 | Dougherty et al. 1980
Florida | 1978 | 10 | General | GC/ECD | ND | ND | 0 | Barquet et al. 1981
Florida | 1978 | 10 | General | GC/ECD | 70–490^b^ | 193 | 100 | Barquet et al. 1981
United States | 1972–1975 | NS | General | GC/ECD+MS | ND–>100^b^ | 100^c^ | >90 | Kutz et al. 1979
Bloomington, Indiana | 1987–1988 | 23 | Breast | GC/ECD+MS | 0.6–10.2; 42–260^b^ | 2.0^d^; 88^d^ | 100; 100 | Dearth and Hites 1991a
North Texas | 1987–1988 | 35 | Abdominal | GC/ECD | 12–261^b,e^ | 95^d,f^ | 100 | Adeshina and Todd 1990
Canada | 1985 | 108 | General | GC/ECD+MS | <11; <103^b^ | 4; 33 | 100; 100 | Mes et al. 1990
British Columbia, Canada | NS | 25 | Most abdominal^g^ | GC/ECD | <134.20^h^ | 42.5^i^ | 100 | Mes 1992
Japan^j^ | 1986–1988 | 23 | NS | GC/ECD | 130–2,160 | 670 | 100 | Sasaki et al. 1991a
Human blood sera
United States | 1976–1980 | 4,200 | General | GC/ECD+MS | ND–>1^b^ | NS | 4 | Murphy et al. 1983
Welds County, Colorado | 1968 | 358 | Nonoccupational | GC/ECD | ND | ND | | Starr et al. 1974
Welds County, Colorado | 1968 | 93 | Farm | GC/ECD | ND | ND | 0 | Starr et al. 1974
Welds County, Colorado | 1968 | 175 | Occupational | GC/ECD | 60–233^k^ | 151 | 3.4 | Starr et al. 1974
British Columbia, Canada | NS | 25 | Whole blood^g^ | GC/ECD | <0.30^l^ | 0.10^m^ | 100 | Mes 1992
Japan^j^ | 1986–1988 | 23 | General | GC/ECD | ND–280 | 0.58 | 100 | Sasaki et al. 1991a
Japan | 1989–1990 | 240 | General | GC-MS | 0.06–3.85^n^ | 0.34^o^ | 100 | Hirai and Tomokuni 1991b
Human milk
United States | NS | 1,436 | General | GC/ECD | ND–>500^b^ | 95.8 | 74 | Savage et al. 1981
United States | NS | 1,436 | General | GC/ECD | ND | ND | 0 | Savage et al. 1981
Hawaii and U.S. mainland | 1979–1980 | 156 | General | GC/ECD | ND | ND | 0 | Takei et al. 1983
U.S. mainland | 1979–1980 | 102 | General | GC/ECD | ND–440 | 54 | 99 | Takei et al. 1983
Hawaii | 1979–1980 | 54 | General | GC/ECD | 11–550 | 68 | 100 | Takei et al. 1983
France | 1991 | 20 | General | GC/ECD | ND–294^p^ | 70^p^ | 90 | Bordet et al. 1993
Human seminal fluid
United States | NS | NS | General | GC/ECD | ND–detected | NS | NS | Dougherty et al. 1980

a No distinction is made between the isomers of chlordane. In cases where the original papers made a distinction, the data were combined.

b Oxychlordane.

c Approximate number.

d Geometric mean.

e Occupational unexposed people.

f Geometric mean (age group): 38 ppb (21–40 years), 88 ppb (41–60 years), and 154 ppb (61+ years).

g Paired blood and biopsy fat samples from selected patients. Relationship established for oxychlordane at 99% confidence level.

h Sum of oxychlordane (44.9), α-chlordane (2.1), γ-chlordane (2.2), trans-nonachlor (74.0), and cis-nonachlor (11.0).

i Median. Sum of oxychlordane (16.5), α-chlordane (0.3), γ-chlordane (0.5), trans-nonachlor (22.6), and cis-nonachlor (2.6).

j Total chlordane; same individuals sampled for adipose tissue and serum.

k All positive samples were obtained from one individual.

l Median. Sum of oxychlordane (0.07), α-chlordane (0.02), and γ-chlordane (0.01).

m Sum oxychlordane (0.16), α-chlordane (0.05), γ-chlordane (0.05), and trans-nonachlor (0.04).

n Nonachlor. Ranges for chlordane and oxychlordane are ND–0.60 ppb and ND–0.62, respectively.

o Median.

p ng of α-chlordane plus γ-chlordane/g of milk fat.

ECD = electron capture detector; GC = gas chromatography; MS = mass spectroscopy; NCI = negative chemical ionization; ND = not detected; NS = not specified

## 5.6 GENERAL POPULATION EXPOSURE

A major route of exposure to chlordane in the United States is from living in chlordane-treated houses. Many of these houses are in the deep south and far southwest where termites are a significant problem, but moderate to heavy use of chlordane extended from Pennsylvania and the lower New England states south and west to the lower portion of Colorado and up to northern California. Chlordane vaporizes gradually in treated homes for over 10 years. It accumulates in residents’ bodies by inhalation of the vapor, by eating food that has adsorbed the vapor, or dermal contact with the chemical. Prior to 1992, indoor air concentrations often exceed 1 μg/m^3^ (see Table 5-6) and persisted for many years (Livingston and Jones 1981). A study of chlordane concentrations in 19 houses treated for subterranean termite control indicated that the chlordane concentration in the indoor air occurred during treatment and declined significantly after 24 hours (Kamble et al. 1992). While there was a slight reduction in chlordane concentration from the 24-hour levels 7 days posttreatment, these changes were not significant. Concentrations of chlordane remained essentially the same from 30 to 180 days after treatment, and these concentrations were similar to pretreatment levels. The EPA (1987g) estimated that, up until 1988, 1.3–1.8 million people per year were exposed to cyclodiene termiticides, as occupants of newly treated structures. They further estimated that ≈30 million structures had been treated for termites with these chemicals, resulting in the exposure of over 80 million people. Of these structures, ≈65% were treated with chlordane, or 19.5 million structures, resulting in the exposure of 52 million people. The exact concentrations to which they were exposed are difficult to estimate from the available data. A Japanese study showed that the concentration of chlordane and oxychlordane in the milk fat of lactating women living in chlordane-treated houses was 13.8 and 33.6 ppb, respectively, versus 3.6 and 19.3 ppb for unexposed controls (Taguchi and Yakushiji 1988). Chlordane and oxychlordane levels in milk increased with years since treatment.

A major study of general population exposure to pesticides, including chlordane, was included in the Nonoccupational Pesticide Exposure Study (NOPES) (EPA 1990b). This study applied probabilistic population sampling techniques, indoor, outdoor, and personal breathing zone air monitoring, and human activity pattern data for multiple routes of exposure to assess total human exposure. These techniques were applied to the communities of Jacksonville, Florida, and Springfield/Chicopee, Massachusetts, over three and two seasons, respectively. For Jacksonville, the personal breathing zone air concentration was relatively stable, and the yearly means for 1986–1988 ranged from 191 to 212 ng/m^3^ over all three seasons, with 50–93% of samples containing detectable levels of chlordane. The corresponding results for Springfield/Chicopee were 36 ng/m^3^ in winter and 253 ng/m^3^ in the spring; 50–87% of the samples had detectable levels of chlordane. Several observations were made from the study. Indoor levels of chlordane were highest in summer and lowest in winter. They were higher in older housing units and households with reported termiticide use. For chlordane, mean air exposure in homes with detectable levels of chlordane was always much higher (~25 times) than exposure from food. Routine sampling of the public water supplies prior to NOPES and tap water in Jacksonville, Florida, and Springfield/Chicopee, Massachusetts, revealed no detectable levels of chlordane in drinking water.

In addition to living in chlordane-treated structures, ingestion of contaminated food is another major route of exposure. Duggan et al. (1983) and Gartrell et al. (1985a, 1985b, 1985c, 1985d, 1986a, 1986b) estimated yearly dietary intake of chlordane since 1965 for 16–19-year-old males. In more recent years, toddlers and infants were included in these estimates (Gunderson 1988). FDA (1989a, 1990, 1991) estimated dietary chlordane intake for various age/sex groups for 1982–1984, 1989, 1990, and 1991. Their results are listed in Table 5-13. The data show a relatively steady intake over the years from 1977 to 1982, indicating that chlordane residues had not decreased significantly in agricultural soils (if that is where the chlordane originated). In addition, infants and toddlers would generally have higher intakes of chlordane than adults because of the high fat content of the foods they eat. The results for the 1991 FDA Total Diet Study were 0.0013 μg/kg/day for infants and 0.0005–0.0015 μg/kg/day for teenagers and adults (FDA 1991). The total daily dietary intake of chlordane per unit body weight, according to results of the 1982–1984 FDA’s Total Diet Study was 0.0051 μg/kg/day for infants, 0.0065 μg/kg/day for toddlers, and 0.002–0.0027 μg/kg/day for teenagers and adults (Gunderson 1988). The Total Diet Study analyzes foods prepared for consumption. After 1982, 234 foods were selected to represent 5,000 different food items identified in dietary surveys.

Table 5-13 Chlordane Intake from Food^a^

Year | Chlordane intake (µg/kg body weight/day)
Year | 14–19-Year-old males^b^ | 60–65-Year-old females | Toddlers | Infants
1965–1970 | Not detected | Not reported | Not performed | Not performed
1971 | Not detected | Not reported | Not performed | Not performed
1972 | 0.01 | Not reported | Not performed | Not performed
1973 | Trace | Not reported | Not performed | Not performed
1974 | Trace | Not reported | Not performed | Not performed
1975 | Trace | Not reported | Not performed | Not performed
1976 | Trace | Not reported | Not performed | Not performed
1977 | 0.004 | Not reported | 0.005 | 0.001
1978 | 0.004 | Not reported | 0.032 | 0.010
1979 | 0.004 | Not reported | 0.003 | <0.001
1980 | 0.003 | Not reported | 0.005 | 0.003
1981–1982 | 0.004 | Not reported | 0.003 | 0.002
1984^c^ | 0.0025 | 0.0026 | 0.0065 | 0.0051
1989^d^ | 0.0007 | 0.0010 | Not reported | 0.0007
1990^d^ | 0.0001 | 0.0001 | Not reported | 0.001
1991^d^ | 0.0005 | 0.0015 | Not reported | 0.0013

a Data from Duggan et al. (1983) and Gartell et al. (1985a, 1985b, 1985c, 1985d, 1986a, 1986b) unless otherwise noted.

b 16–19-Year-old males for studies in years 1965–1982, 14–16-year-old males for studies 1984–1991.

c Gunderson 1988.

d FDA 1989, 1990, 1991.

Dermal exposures may result from children or adults coming into contact with contaminated soils or house dust near treated houses, lawns, or gardens. Dermal exposures cannot be quantified with the available information.

Previous exposure to chlordane is often gauged by the concentration of chlordane compounds (usually oxychlordane or trans-nonachlor) in human adipose tissue. According to EPA’s National Human Monitoring Program and other broad based U.S. surveys, the geometric mean concentration of oxychlordane in human adipose tissue ranged from 90 to 120 ppb between 1971 and 1983 with no clear temporal trend (Adeshina and Todd 1990; Kutz et al. 1991). North Texas and Canadian studies showed increasing oxychlordane levels with age in selected age groups, but no difference in levels according to sex (Adeshina and Todd 1990; Mes et al. 1990).

The Fourth National Report on Human Exposures to Environmental Chemicals (CDC 2009) includes information regarding serum levels of chlordane metabolites oxychlordane and trans-nonachlor according to various age groups, sex, and race/ethnicity for the years 1999–2004. Tables 5-14 and 5-15 depict lipid adjusted and whole weight oxychlordane levels, respectively. Tables 5-16 and 5-17 depict lipid adjusted and whole weight trans-nonachlor levels, respectively. Lipid adjusted and whole weight oxychlordane levels for the years 2005–2009 (CDC 2017) are depicted in Tables 5-18 and 5-19, respectively. Lipid adjusted and whole weight trans-nonachlor levels for the years 2005–2009 (CDC 2017) are depicted in Tables 5-20 and 5-21, respectively. These data demonstrate that the U.S. population continues to exhibit measurable amounts of chlordane metabolites in serum; concentrations are higher in older age groups than younger age groups without significant male-female or race/ethnicity differences.

Table 5-14 Geometric Mean and Selected Percentiles of Serum Oxychlordane (Lipid Adjusted) Serum Concentrations (in ng/g of Lipid or Parts per Billion on a Lipid-Weight Basis) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES) 1999–2004

| Survey years^a^ | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years^a^ | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 1999–2000 | *^b^ | <LOD^c^ | 20.8 (17.8–23.0) | 34.4 (30.5–38.6) | 44.8 (40.2–49.6) | 1,661
Total | 2001–2002 | 11.4 (<LOD–12.5) | 11.1 (<LOD–12.5) | 21.7 (19.3–24.4) | 36.4 (31.5–41.4) | 49.7 (42.0–61.2) | 2,249
Total | 2003–2004 | 9.37 (8.69–10.1) | 10.3 (9.20–11.0) | 18.0 (16.8–20.1) | 29.0 (26.8–32.1) | 37.7 (34.8–43.8) | 1,978
Age group
12–19 years | 1999–2000 | * | <LOD | <LOD | <LOD | <LOD | 663
12–19 years | 2001–2002 | * | <LOD | <LOD | <LOD | 11.5 (<LOD–12.6) | 752
12–19 years | 2003–2004 | * | <LOD | <LOD | 9.20 (<LOD–11.5) | 11.5 (8.10–18.9) | 595
≥20 years | 1999–2000 | * | <LOD | 23.3 (21.0–25.9) | 37.7 (32.3–43.5) | 47.7 (43.1–50.8) | 998
≥20 years | 2001–2002 | 12.9 (11.7–14.3) | 13.3 (11.4–14.9) | 23.9 (21.2–26.7) | 38.5 (33.4–45.9) | 53.1 (44.1–65.9) | 1,497
≥20 years | 2003–2004 | 10.6 (9.82–11.5) | 11.4 (10.6–12.4) | 19.9 (17.9–21.5) | 31.3 (28.8–33.2) | 39.2 (36.5–44.8) | 1,383
Gender
Males | 1999–2000 | * | <LOD | 18.1 (16.1–19.6) | 31.3 (25.9–38.2) | 42.4 (35.3–49.6) | 793
Males | 2001–2002 | 11.1 (<LOD–12.6) | 11.1 (<LOD–12.6) | 20.6 (16.6–24.9) | 33.1 (27.5–43.8) | 48.1 (40.2–56.9) | 1,049
Males | 2003–2004 | 9.10 (8.20–10.1) | 9.90 (8.30–11.2) | 17.1 (15.6–18.4) | 27.6 (25.3–32.2) | 36.0 (32.7–39.2) | 963
Females | 1999–2000 | * | <LOD | 22.3 (20.1–25.9) | 36.9 (31.5–40.3) | 46.2 (39.1–51.8) | 868
Females | 2001–2002 | 11.7 (10.7–12.7) | 11.0 (<LOD–12.9) | 23.1 (20.7–25.0) | 37.5 (34.5–42.1) | 52.8 (42.7–70.0) | 1,200
Females | 2003–2004 | 9.63 (8.89–10.4) | 10.6 (9.10–11.3) | 20.1 (17.4–21.7) | 30.3 (27.5–32.7) | 41.9 (36.3–45.5) | 1,015
Race/ethnicity
Mexican Americans | 1999–2000 | * | <LOD | 16.3 (<LOD–19.9) | 28.9 (18.8–42.0) | 39.9 (26.8–61.0) | 628
Mexican Americans | 2001–2002 | * | <LOD | 13.9 (11.0–18.4) | 27.2 (21.0–33.1) | 37.9 (29.9–42.0) | 557
Mexican Americans | 2003–2004 | * | <LOD | 12.8 (10.1–15.8) | 22.9 (15.8–31.4) | 31.4 (22.4–51.6) | 462
Non-Hispanic blacks | 1999–2000 | * | <LOD | 18.7 (<LOD–32.2) | 39.9 (26.5–47.3) | 48.6 (43.5–65.5) | 350
Non-Hispanic blacks | 2001–2002 | 11.7 (<LOD–13.6) | <LOD | 22.8 (17.2–28.3) | 41.4 (30.6–53.7) | 56.5 (41.8–73.5) | 501
Non-Hispanic blacks | 2003–2004 | 8.74 (<LOD–10.2) | 8.70 (<LOD–10.6) | 18.9 (15.9–21.5) | 35.1 (25.4–40.2) | 44.2 (37.7–56.8) | 493
Non-Hispanic whites | 1999–2000 | * | <LOD | 21.8 (18.6–24.6) | 34.2 (28.9–40.9) | 44.0 (37.2–49.8) | 559
Non-Hispanic whites | 2001–2002 | 12.1 (11.0–13.3) | 11.8 (10.5–13.9) | 23.0 (20.1–25.7) | 37.5 (31.6–45.1) | 52.2 (41.0–67.4) | 1,031
Non-Hispanic whites | 2003–2004 | 10.2 (9.36–11.1) | 11.2 (10.0–12.1) | 19.7 (17.2–21.7) | 30.3 (26.8–33.6) | 37.7 (34.3–45.5) | 898

a The limit of detection for survey years 1999–2000, 2001–2002, and 2003–2004 were 14.5, 10.5, and 7.8 ng/g, respectively.

b Not calculated: proportion of results below limit of detection was too high to provide a valid result.

c Less than the limit of detection.

CI = confidence interval; LOD = limit of detection

Source: CDC 2009, 2017

Table 5-15 Geometric Mean and Selected Percentiles of Serum Oxychlordane (Whole Weight) Serum Concentrations (in ng/g of Serum or Parts per Billion) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES) 1999–2004

| Survey years^a^ | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years^a^ | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 1999–2000 | *^b^ | <LOD^c^ | 0.140 (0.120–0.150) | 0.260 (0.200–0.290) | 0.310 (0.290–0.340) | 1,661
Total | 2001–2002 | 0.070 (<LOD–0.077) | 0.070 (<LOD–0.080) | 0.140 (0.130–0.160) | 0.250 (0.220–0.300) | 0.350 (0.290–0.440) | 2,249
Total | 2003–2004 | 0.057 (0.053–0.062) | 0.063 (0.058–0.068) | 0.119 (0.106–0.133) | 0.204 (0.189–0.213) | 0.269 (0.246–0.291) | 1,978
Age group
12–19 years | 1999–2000 | * | <LOD | <LOD | <LOD | <LOD | 663
12–19 years | 2001–2002 | * | <LOD | <LOD | <LOD | 0.060 (<LOD–0.070) | 752
12–19 years | 2003–2004 | * | <LOD | <LOD | 0.047 (<LOD–0.063) | 0.066 (0.048–0.092) | 595
≥20 years | 1999–2000 | * | <LOD | 0.150 (0.140–0.180) | 0.280 (0.230–0.300) | 0.330 (0.300–0.400) | 998
≥20 years | 2001–2002 | 0.082 (0.074–0.091) | 0.080 (0.070–0.090) | 0.160 (0.140–0.180) | 0.270 (0.230–0.320) | 0.370 (0.310–0.450) | 1,497
≥20 years | 2003–2004 | 0.067 (0.061–0.073) | 0.073 (0.066–0.079) | 0.130 (0.115–0.146) | 0.210 (0.203–0.227) | 0.286 (0.258–0.320) | 1,383
Gender
Males | 1999–2000 | * | <LOD | 0.120 (0.100–0.140) | 0.220 (0.180–0.280) | 0.300 (0.260–0.340) | 793
Males | 2001–2002 | 0.069 (<LOD–0.079) | 0.070 (<LOD–0.080) | 0.130 (0.120–0.160) | 0.230 (0.190–0.300) | 0.320 (0.250–0.430) | 1,049
Males | 2003–2004 | 0.056 (0.050–0.063) | 0.063 (0.055–0.076) | 0.115 (0.100–0.126) | 0.189 (0.168–0.207) | 0.258 (0.216–0.302) | 963
Females | 1999–2000 | * | <LOD | 0.140 (0.130–0.170) | 0.270 (0.200–0.310) | 0.320 (0.290–0.400) | 868
Females | 2001–2002 | 0.071 (0.065–0.077) | 0.070 (<LOD–0.080) | 0.150 (0.130–0.160) | 0.260 (0.230–0.310) | 0.370 (0.280–0.510) | 1,200
Females | 2003–2004 | 0.058 (0.053–0.064) | 0.063 (0.057–0.068) | 0.126 (0.104–0.146) | 0.208 (0.199–0.231) | 0.286 (0.245–0.331) | 1,015
Race/ethnicity
Mexican Americans | 1999–2000 | * | <LOD | 0.100 (<LOD–0.130) | 0.210 (0.130–0.320) | 0.290 (0.190–0.410) | 628
Mexican Americans | 2001–2002 | * | <LOD | 0.100 (0.070–0.130) | 0.200 (0.150–0.240) | 0.280 (0.210–0.360) | 557
Mexican Americans | 2003–2004 | * | <LOD | 0.083 (0.066–0.104) | 0.149 (0.108–0.230) | 0.230 (0.148–0.373) | 462
Non-Hispanic blacks | 1999–2000 | * | <LOD | 0.110 (<LOD–0.170) | 0.240 (0.170–0.290) | 0.320 (0.240–0.430) | 350
Non-Hispanic blacks | 2001–2002 | 0.066 (<LOD–0.077) | <LOD | 0.130 (0.090–0.170) | 0.260 (0.180–0.350) | 0.350 (0.240–0.560) | 501
Non-Hispanic blacks | 2003–2004 | 0.049 (<LOD–0.057) | 0.050 (<LOD–0.062) | 0.112 (0.087–0.136) | 0.225 (0.165–0.287) | 0.315 (0.253–0.348) | 493
Non-Hispanic whites | 1999–2000 | * | <LOD | 0.140 (0.120–0.170) | 0.270 (0.200–0.300) | 0.320 (0.280–0.380) | 559
Non-Hispanic whites | 2001–2002 | 0.075 (0.068–0.083) | 0.080 (0.070–0.090) | 0.150 (0.130–0.170) | 0.250 (0.220–0.310) | 0.370 (0.280–0.450) | 1,031
Non-Hispanic whites | 2003–2004 | 0.063 (0.058–0.070) | 0.070 (0.063–0.077) | 0.128 (0.110–0.148) | 0.207 (0.190–0.223) | 0.271 (0.242–0.315) | 898

a The limit of detection for survey years 1999–2000, 2001–2002, and 2003–2004 were 14.5, 10.5, and 7.8 ng/g, respectively.

b Not calculated: proportion of results below limit of detection was too high to provide a valid result.

c Less than the limit of detection.

CI = confidence interval; LOD = limit of detection

Source: CDC 2017

Table 5-16 Geometric Mean and Selected Percentiles of Serum trans-Nonachlor (Lipid Adjusted) Serum Concentrations (in ng/g of Lipid or Parts per Billion on a Lipid-Weight Basis) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES) 1999–2004

| Survey years^a^ | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years^a^ | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 1999–2000 | 18.3 (16.7–20.0) | 17.9 (16.1–20.1) | 31.9 (28.9–36.0) | 55.1 (48.4–62.6) | 79.4 (67.6–88.1) | 1,933
Total | 2001–2002 | 17.0 (15.2–18.9) | 17.9 (15.5–20.5) | 33.7 (30.2–37.2) | 56.3 (49.6–66.0) | 78.2 (64.0–113) | 2,286
Total | 2003–2004 | 14.7 (13.1–16.5) | 14.8 (13.5–17.0) | 30.2 (26.7–32.5) | 49.0 (42.6–54.7) | 68.3 (58.6–82.3) | 1,955
Age group
12–19 years | 1999–2000 | *^b^ | <LOD^c^ | <LOD | 18.8 (<LOD–20.6) | 25.2 (19.1–28.4) | 664
12–19 years | 2001–2002 | * | <LOD | <LOD | 13.4 (11.8–16.4) | 19.2 (15.2–23.5) | 758
12–19 years | 2003–2004 | * | <LOD | 8.70 (<LOD–12.5) | 16.1 (10.7–23.7) | 22.6 (16.1–34.6) | 589
≥20 years | 1999–2000 | 20.8 (19.0–22.8) | 20.7 (18.0–23.5) | 35.4 (30.9–40.3) | 59.9 (51.8–67.6) | 82.7 (74.9–89.6) | 1,269
≥20 years | 2001–2002 | 19.8 (17.6–22.3) | 20.9 (19.0–23.1) | 36.6 (32.8–41.1) | 60.6 (52.5–69.9) | 84.9 (66.0–123) | 1,528
≥20 years | 2003–2004 | 16.9 (15.1–18.9) | 17.3 (14.6–20.0) | 31.8 (28.9–35.3) | 51.4 (45.9–58.6) | 74.7 (59.8–90.0) | 1,366
Gender
Males | 1999–2000 | 17.7 (16.5–19.1) | 17.2 (14.9–20.1) | 30.2 (27.7–34.2) | 51.1 (47.3–58.6) | 78.2 (60.2–88.1) | 922
Males | 2001–2002 | 17.0 (14.8–19.5) | 18.3 (14.8–21.1) | 34.4 (28.3–39.3) | 54.8 (45.0–68.9) | 78.2 (59.7–113) | 1,062
Males | 2003–2004 | 14.8 (12.7–17.3) | 14.6 (12.2–18.0) | 30.8 (26.7–35.3) | 51.0 (42.0–59.4) | 68.6 (56.0–93.8) | 955
Females | 1999–2000 | 18.8 (16.7–21.1) | 18.4 (16.1–22.2) | 32.9 (29.0–38.3) | 59.0 (48.4–67.6) | 80.8 (71.5–95.5) | 1,011
Females | 2001–2002 | 17.0 (15.4–18.7) | 17.6 (15.0–20.3) | 32.8 (30.4–36.7) | 56.9 (51.9–65.5) | 78.1 (65.5–111) | 1,224
Females | 2003–2004 | 14.5 (13.1–16.1) | 15.0 (13.8–16.3) | 28.2 (25.3–32.8) | 48.1 (41.4–52.7) | 68.3 (56.8–79.9) | 1,000
Race/ethnicity
Mexican Americans | 1999–2000 | * | <LOD | 25.1 (22.7–29.5) | 40.7 (35.1–51.8) | 56.3 (45.8–77.2) | 650
Mexican Americans | 2001–2002 | 11.9 (<LOD–14.6) | 10.6 (<LOD–14.5) | 26.0 (19.3–30.4) | 47.9 (36.3–57.2) | 59.8 (49.3–74.1) | 558
Mexican Americans | 2003–2004 | 10.2 (7.86–13.2) | 9.10 (<LOD–11.1) | 20.7 (11.1–34.7) | 39.5 (25.9–65.5) | 62.2 (36.0–93.4) | 457
Non-Hispanic blacks | 1999–2000 | 20.3 (17.0–24.1) | 17.5 (15.4–23.5) | 35.7 (28.9–45.5) | 77.0 (60.8–90.7) | 107 (84.0–143) | 404
Non-Hispanic blacks | 2001–2002 | 18.8 (15.4–22.9) | 19.2 (14.7–22.0) | 36.8 (28.3–50.5) | 73.6 (50.8–110) | 112 (68.7–160) | 514
Non-Hispanic blacks | 2003–2004 | 14.4 (12.2–17.0) | 13.8 (11.2–16.3) | 30.8 (26.5–36.1) | 59.9 (47.7–77.7) | 86.6 (56.8–129) | 486
Non-Hispanic whites | 1999–2000 | 19.1 (17.2–21.1) | 19.0 (16.9–22.2) | 32.8 (28.0–37.6) | 52.5 (44.9–64.4) | 74.0 (62.3–86.7) | 722
Non-Hispanic whites | 2001–2002 | 17.5 (15.6–19.7) | 19.0 (16.3–21.1) | 34.0 (29.7–38.1) | 55.5 (45.9–69.4) | 78.7 (59.1–126) | 1,052
Non-Hispanic whites | 2003–2004 | 15.8 (13.7–18.2) | 16.0 (13.8–19.3) | 30.8 (26.4–35.0) | 48.8 (42.1–55.7) | 67.6 (57.5–87.3) | 889

a The limit of detection for survey years 1999–2000, 2001–2002, and 2003–2004 were 14.5, 10.5, and 7.8 ng/g, respectively.

b Not calculated: proportion of results below limit of detection was too high to provide a valid result.

c Less than the limit of detection.

CI = confidence interval; LOD = limit of detection

Source: CDC 2009, 2017

Table 5-17 Geometric Mean and Selected Percentiles of Serum trans-Nonachlor (Whole Weight) Serum Concentrations (in ng/g of Serum or Parts per Billion) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES) 1999–2004

| Survey years^a^ | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years^a^ | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 1999–2000 | 0.109 (0.099–0.119) | 0.110 (0.090–0.120) | 0.210 (0.190–0.240) | 0.370 (0.330–0.420) | 0.550 (0.470–0.630) | 1,933
Total | 2001–2002 | 0.104 (0.093–0.116) | 0.110 (0.100–0.120) | 0.220 (0.190–0.250) | 0.390 (0.330–0.480) | 0.590 (0.430–0.800) | 2,286
Total | 2003–2004 | 0.089 (0.080–0.100) | 0.094 (0.084–0.108) | 0.191 (0.171–0.211) | 0.324 (0.290–0.371) | 0.470 (0.410–0.558) | 1,955
Age group
12–19 years | 1999–2000 | *^b^ | <LOD^c^ | <LOD | 0.090 (<LOD 0.110) | 0.120 (0.100–0.130) | 664
12–19 years | 2001–2002 | * | <LOD | <LOD | 0.070 (0.060–0.080) | 0.090 (0.080–0.130) | 758
12–19 years | 2003–2004 | * | <LOD | 0.041 (<LOD 0.060) | 0.081 (0.054–0.117) | 0.109 (0.081–0.161) | 589
≥20 years | 1999–2000 | 0.128 (0.116–0.141) | 0.130 (0.110–0.150) | 0.230 (0.210–0.260) | 0.400 (0.360–0.460) | 0.580 (0.490–0.690) | 1,269
≥20 years | 2001–2002 | 0.125 (0.111–0.141) | 0.130 (0.120–0.150) | 0.240 (0.210–0.280) | 0.420 (0.350–0.540) | 0.640 (0.470–0.840) | 1,528
≥20 years | 2003–2004 | 0.106 (0.095–0.119) | 0.112 (0.096–0.127) | 0.210 (0.186–0.237) | 0.355 (0.301–0.405) | 0.520 (0.430–0.594) | 1,366
Gender
Males | 1999–2000 | 0.106 (0.098–0.114) | 0.100 (0.090–0.120) | 0.210 (0.180–0.220) | 0.350 (0.310–0.400) | 0.520 (0.400–0.630) | 922
Males | 2001–2002 | 0.105 (0.091–0.122) | 0.110 (0.090–0.130) | 0.220 (0.190–0.260) | 0.380 (0.310–0.500) | 0.580 (0.390–0.830) | 1,062
Males | 2003–2004 | 0.092 (0.079–0.108) | 0.098 (0.085–0.126) | 0.202 (0.177–0.232) | 0.343 (0.285–0.395) | 0.458 (0.395–0.594) | 955
Females | 1999–2000 | 0.111 (0.099–0.125) | 0.110 (0.090–0.130) | 0.220 (0.190–0.250) | 0.390 (0.310–0.460) | 0.580 (0.460–0.690) | 1,011
Females | 2001–2002 | 0.103 (0.093–0.113) | 0.110 (0.090–0.120) | 0.220 (0.180–0.240) | 0.400 (0.340–0.450) | 0.590 (0.430–0.830) | 1,224
Females | 2003–2004 | 0.087 (0.078–0.097) | 0.092 (0.079–0.098) | 0.183 (0.161–0.210) | 0.317 (0.286–0.367) | 0.470 (0.409–0.565) | 1,000
Race/ethnicity
Mexican Americans | 1999–2000 | * | <LOD | 0.170 (0.120–0.210) | 0.310 (0.240–0.340) | 0.390 (0.320–0.520) | 650
Mexican Americans | 2001–2002 | 0.071 (<LOD–0.091) | 0.060 (<LOD–0.090) | 0.160 (0.120–0.210) | 0.330 (0.270–0.390) | 0.470 (0.360–0.590) | 558
Mexican Americans | 2003–2004 | 0.062 (0.047–0.082) | 0.055 (<LOD–0.069) | 0.135 (0.069–0.237) | 0.288 (0.158–0.559) | 0.414 (0.279–0.651) | 457
Non-Hispanic blacks | 1999–2000 | 0.112 (0.093–0.134) | 0.100 (0.080–0.130) | 0.220 (0.180–0.300) | 0.490 (0.340–0.600) | 0.760 (0.510–0.960) | 404
Non-Hispanic blacks | 2001–2002 | 0.106 (0.085–0.131) | 0.110 (0.080–0.130) | 0.220 (0.160–0.310) | 0.490 (0.320–0.680) | 0.680 (0.410–1.20) | 514
Non-Hispanic blacks | 2003–2004 | 0.080 (0.068–0.096) | 0.078 (0.061–0.093) | 0.186 (0.145–0.242) | 0.417 (0.272–0.565) | 0.573 (0.497–0.684) | 486
Non-Hispanic whites | 1999–2000 | 0.116 (0.104–0.129) | 0.120 (0.100–0.140) | 0.220 (0.190–0.240) | 0.370 (0.300–0.440) | 0.510 (0.440–0.630) | 722
Non-Hispanic whites | 2001–2002 | 0.108 (0.096–0.122) | 0.120 (0.100–0.130) | 0.220 (0.190–0.250) | 0.390 (0.310–0.490) | 0.600 (0.400–0.930) | 1,052
Non-Hispanic whites | 2003–2004 | 0.098 (0.085–0.113) | 0.103 (0.090–0.124) | 0.205 (0.173–0.234) | 0.327 (0.288–0.390) | 0.461 (0.397–0.576) | 889

a The limit of detection for survey years 1999–2000, 2001–2002, and 2003–2004 were 14.5, 10.5, and 7.8 ng/g, respectively.

b Not calculated: proportion of results below limit of detection was too high to provide a valid result.

c Less than the limit of detection.

CI = confidence interval; LOD = limit of detection

Source: CDC 2009, 2017

Table 5-18 Weighted Arithmetic Mean and Unadjusted Standard Error of Pooled Serum Concentrations of Serum Oxychlordane (Lipid Adjusted) (in ng/g of Lipid or Parts per Billion on a Lipid-Weight Basis) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES) 2005–2008

Category | Age (years) | Survey years^a^ | Weighted arithmetic mean^b^ | Unadjusted standard error^c^ | Number of pools^d^
Non-Hispanic white male | 12–19 | 2005–2006 | 4.80 | 1.1 | 9
Non-Hispanic white male | 12–19 | 2007–2008 | 3.52 | 0.52 | 6
Non-Hispanic white male | 20–39 | 2005–2006 | 6.50 | 1.06 | 12
Non-Hispanic white male | 20–39 | 2007–2008 | 6.93 | 0.75 | 15
Non-Hispanic white male | 40–59 | 2005–2006 | 14.9 | 1.4 | 12
Non-Hispanic white male | 40–59 | 2007–2008 | 12.1 | 0.5 | 16
Non-Hispanic white male | 60+ | 2005–2006 | 25.4 | 2.5 | 15
Non-Hispanic white male | 60+ | 2007–2008 | 26.1 | 1.4 | 23
Non-Hispanic white female | 12–19 | 2005–2006 | 2.98 | 0.3 | 10
Non-Hispanic white female | 12–19 | 2007–2008 | 3.66 | 0.74 | 7
Non-Hispanic white female | 20–39 | 2005–2006 | 5.64 | 0.56 | 16
Non-Hispanic white female | 20–39 | 2007–2008 | 5.79 | 0.51 | 13
Non-Hispanic white female | 40–59 | 2005–2006 | 13.7 | 1 | 13
Non-Hispanic white female | 40–59 | 2007–2008 | 11.8 | 0.8 | 17
Non-Hispanic white female | 60+ | 2005–2006 | 28.9 | 2.6 | 17
Non-Hispanic white female | 60+ | 2007–2008 | 31.8 | 2.3 | 21
Non-Hispanic black male | 12–19 | 2005–2006 | 4.08 | 0.49 | 13
Non-Hispanic black male | 12–19 | 2007–2008 | 2.80 | 0.75 | 6
Non-Hispanic black male | 20–39 | 2005–2006 | 4.53 | 0.9 | 6
Non-Hispanic black male | 20–39 | 2007–2008 | 5.72 | 0.28 | 6
Non-Hispanic black male | 40–59 | 2005–2006 | 12.0 | 1 | 5
Non-Hispanic black male | 40–59 | 2007–2008 | 12.1 | 1.1 | 6
Non-Hispanic black male | 60+ | 2005–2006 | 32.7 | 5.3 | 5
Non-Hispanic black male | 60+ | 2007–2008 | 26.6 | 2.5 | 8
Non-Hispanic black female | 12–19 | 2005–2006 | 2.92 | 0.31 | 14
Non-Hispanic black female | 12–19 | 2007–2008 | *^e^ | * | 5
Non-Hispanic black female | 20–39 | 2005–2006 | 5.56 | 0.68 | 7
Non-Hispanic black female | 20–39 | 2007–2008 | 4.45 | 0.79 | 8
Non-Hispanic black female | 40–59 | 2005–2006 | 14.5 | 0.8 | 7
Non-Hispanic black female | 40–59 | 2007–2008 | 14.3 | 1 | 8
Non-Hispanic black female | 60+ | 2005–2006 | 52.9 | 11.7 | 5
Non-Hispanic black female | 60+ | 2007–2008 | 38.1 | 1.7 | 7
Mexican American male | 12–19 | 2005–2006 | 2.54 | 0.33 | 11
Mexican American male | 12–19 | 2007–2008 | 2.76 | 0.45 | 6
Mexican American male | 20–39 | 2005–2006 | 5.84 | 1.22 | 9
Mexican American male | 20–39 | 2007–2008 | 4.93 | 0.38 | 9
Mexican American male | 40–59 | 2005–2006 | 11.0 | 1.4 | 4
Mexican American male | 40–59 | 2007–2008 | 12.0 | 0.7 | 6
Mexican American male | 60+ | 2005–2006 | 18.6 | 2.4 | 4
Mexican American male | 60+ | 2007–2008 | 21.9 | 2.2 | 5
Mexican American female | 12–19 | 2005–2006 | 2.39 | 0.25 | 16
Mexican American female | 12–19 | 2007–2008 | * | * | 5
Mexican American female | 20–39 | 2005–2006 | 4.39 | 0.5 | 9
Mexican American female | 20–39 | 2007–2008 | 4.17 | 0.55 | 8
Mexican American female | 40–59 | 2005–2006 | 13.7 | 1.8 | 6
Mexican American female | 40–59 | 2007–2008 | 13.4 | 2.2 | 6
Mexican American female | 60+ | 2005–2006 | 27.4 | 3.8 | 3
Mexican American female | 60+ | 2007–2008 | 28.2 | 4.3 | 5

a The limit of detection for survey years 2005–2006 and 2007–2008 were 1.46 and 1.4 ng/g, respectively.

b Weighted arithmetic means are not comparable to weighted geometric means.

c Unadjusted standard errors do not incorporate survey design effects.

d Each pool was composed of serum from 8 persons.

e Not calculated: proportion of results below limit of detection was too high to provide a valid result.

Source: CDC 2017

Table 5-19 Weighted Arithmetic Mean and Unadjusted Standard Error of Pooled Serum Concentrations of Serum Oxychlordane (Whole Weight) (in ng/g of Serum or Parts per Billion) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES) 2005–2008

Category | Age (years) | Survey years^a^ | Weighted arithmetic mean^b^ | Unadjusted standard error^c^ | Number of pools^d^
Non-Hispanic white male | 12–19 | 2005–2006 | 0.026 | 0.006 | 9
Non-Hispanic white male | 12–19 | 2007–2008 | 0.018 | 0.003 | 6
Non-Hispanic white male | 20–39 | 2005–2006 | 0.049 | 0.01 | 12
Non-Hispanic white male | 20–39 | 2007–2008 | 0.047 | 0.006 | 15
Non-Hispanic white male | 40–59 | 2005–2006 | 0.113 | 0.013 | 12
Non-Hispanic white male | 40–59 | 2007–2008 | 0.089 | 0.005 | 16
Non-Hispanic white male | 60+ | 2005–2006 | 0.171 | 0.015 | 15
Non-Hispanic white male | 60+ | 2007–2008 | 0.167 | 0.009 | 23
Non-Hispanic white female | 12–19 | 2005–2006 | 0.016 | 0.002 | 10
Non-Hispanic white female | 12–19 | 2007–2008 | 0.017 | 0.004 | 7
Non-Hispanic white female | 20–39 | 2005–2006 | 0.037 | 0.004 | 16
Non-Hispanic white female | 20–39 | 2007–2008 | 0.035 | 0.003 | 13
Non-Hispanic white female | 40–59 | 2005–2006 | 0.101 | 0.01 | 13
Non-Hispanic white female | 40–59 | 2007–2008 | 0.079 | 0.006 | 17
Non-Hispanic white female | 60+ | 2005–2006 | 0.210 | 0.017 | 17
Non-Hispanic white female | 60+ | 2007–2008 | 0.214 | 0.017 | 21
Non-Hispanic black male | 12–19 | 2005–2006 | 0.020 | 0.002 | 13
Non-Hispanic black male | 12–19 | 2007–2008 | 0.013 | 0.003 | 6
Non-Hispanic black male | 20–39 | 2005–2006 | 0.027 | 0.005 | 6
Non-Hispanic black male | 20–39 | 2007–2008 | 0.032 | 0.002 | 6
Non-Hispanic black male | 40–59 | 2005–2006 | 0.076 | 0.006 | 5
Non-Hispanic black male | 40–59 | 2007–2008 | 0.077 | 0.007 | 6
Non-Hispanic black male | 60+ | 2005–2006 | 0.193 | 0.028 | 5
Non-Hispanic black male | 60+ | 2007–2008 | 0.162 | 0.017 | 8
Non-Hispanic black female | 12–19 | 2005–2006 | 0.014 | 0.001 | 14
Non-Hispanic black female | 12–19 | 2007–2008 | *^e^ | * | 5
Non-Hispanic black female | 20–39 | 2005–2006 | 0.032 | 0.004 | 7
Non-Hispanic black female | 20–39 | 2007–2008 | 0.022 | 0.004 | 8
Non-Hispanic black female | 40–59 | 2005–2006 | 0.093 | 0.006 | 7
Non-Hispanic black female | 40–59 | 2007–2008 | 0.086 | 0.008 | 8
Non-Hispanic black female | 60+ | 2005–2006 | 0.347 | 0.067 | 5
Non-Hispanic black female | 60+ | 2007–2008 | 0.229 | 0.012 | 7
Mexican American male | 12–19 | 2005–2006 | 0.014 | 0.002 | 11
Mexican American male | 12–19 | 2007–2008 | 0.014 | 0.002 | 6
Mexican American male | 20–39 | 2005–2006 | 0.041 | 0.007 | 9
Mexican American male | 20–39 | 2007–2008 | 0.034 | 0.004 | 9
Mexican American male | 40–59 | 2005–2006 | 0.089 | 0.014 | 4
Mexican American male | 40–59 | 2007–2008 | 0.087 | 0.009 | 6
Mexican American male | 60+ | 2005–2006 | 0.137 | 0.025 | 4
Mexican American male | 60+ | 2007–2008 | 0.156 | 0.011 | 5
Mexican American female | 12–19 | 2005–2006 | 0.013 | 0.001 | 16
Mexican American female | 12–19 | 2007–2008 | * | * | 5
Mexican American female | 20–39 | 2005–2006 | 0.029 | 0.003 | 9
Mexican American female | 20–39 | 2007–2008 | 0.024 | 0.004 | 8
Mexican American female | 40–59 | 2005–2006 | 0.100 | 0.011 | 6
Mexican American female | 40–59 | 2007–2008 | 0.090 | 0.014 | 6
Mexican American female | 60+ | 2005–2006 | 0.208 | 0.035 | 3
Mexican American female | 60+ | 2007–2008 | 0.193 | 0.03 | 5

a The limit of detection for survey years 2005–2006 and 2007–2008 were 1.46 and 1.4 ng/g, respectively.

b Weighted arithmetic means are not comparable to weighted geometric means.

c Unadjusted standard errors do not incorporate survey design effects.

d Each pool was composed of serum from 8 persons.

e Not calculated: proportion of results below limit of detection was too high to provide a valid result.

Source: CDC 2017

Table 5-20 Weighted Arithmetic Mean and Unadjusted Standard Error of Pooled Serum Concentrations of Serum trans-Nonachlor (Lipid Adjusted) (in ng/g of Lipid or Parts per Billion on a Lipid-Weight Basis) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES) 2005–2008

Category | Age (years) | Survey years^a^ | Weighted arithmetic mean^b^ | Unadjusted standard error^c^ | Number of pools^d^
Non-Hispanic white male | 12–19 | 2005–2006 | 9.03^e^ | 2.84 | 9
Non-Hispanic white male | 12–19 | 2007–2008 | 6.06 | 1.08 | 6
Non-Hispanic white male | 20–39 | 2005–2006 | 11.3 | 2 | 12
Non-Hispanic white male | 20–39 | 2007–2008 | 11.1 | 1.5 | 15
Non-Hispanic white male | 40–59 | 2005–2006 | 26.9 | 3.9 | 12
Non-Hispanic white male | 40–59 | 2007–2008 | 21.5 | 1.2 | 16
Non-Hispanic white male | 60+ | 2005–2006 | 49.4 | 7.9 | 15
Non-Hispanic white male | 60+ | 2007–2008 | 50.6 | 4.2 | 23
Non-Hispanic white female | 12–19 | 2005–2006 | 4.94 | 0.52 | 10
Non-Hispanic white female | 12–19 | 2007–2008 | 6.70 | 0.89 | 7
Non-Hispanic white female | 20–39 | 2005–2006 | 9.70 | 1.44 | 16
Non-Hispanic white female | 20–39 | 2007–2008 | 8.95 | 0.97 | 13
Non-Hispanic white female | 40–59 | 2005–2006 | 21.8 | 2.3 | 13
Non-Hispanic white female | 40–59 | 2007–2008 | 16.4 | 1.5 | 17
Non-Hispanic white female | 60+ | 2005–2006 | 50.2 | 6.1 | 17
Non-Hispanic white female | 60+ | 2007–2008 | 51.7 | 6.1 | 21
Non-Hispanic black male | 12–19 | 2005–2006 | 6.50 | 0.67 | 13
Non-Hispanic black male | 12–19 | 2007–2008 | 4.71 | 0.65 | 6
Non-Hispanic black male | 20–39 | 2005–2006 | 8.24 | 0.86 | 6
Non-Hispanic black male | 20–39 | 2007–2008 | 8.87 | 0.97 | 6
Non-Hispanic black male | 40–59 | 2005–2006 | 22.0 | 2.6 | 5
Non-Hispanic black male | 40–59 | 2007–2008 | 21.7 | 2.1 | 6
Non-Hispanic black male | 60+ | 2005–2006 | 66.4 | 13.2 | 5
Non-Hispanic black male | 60+ | 2007–2008 | 54.4 | 4.9 | 8
Non-Hispanic black female | 12–19 | 2005–2006 | 4.44 | 0.54 | 14
Non-Hispanic black female | 12–19 | 2007–2008 | 3.39^e^ | 1.18 | 5
Non-Hispanic black female | 20–39 | 2005–2006 | 9.32 | 1.22 | 7
Non-Hispanic black female | 20–39 | 2007–2008 | 6.42 | 0.6 | 8
Non-Hispanic black female | 40–59 | 2005–2006 | 24.1 | 1.5 | 7
Non-Hispanic black female | 40–59 | 2007–2008 | 20.4 | 1.7 | 8
Non-Hispanic black female | 60+ | 2005–2006 | 89.0 | 15.4 | 5
Non-Hispanic black female | 60+ | 2007–2008 | 68.0 | 3.9 | 7
Mexican American male | 12–19 | 2005–2006 | 3.71 | 0.49 | 11
Mexican American male | 12–19 | 2007–2008 | 3.91 | 0.81 | 6
Mexican American male | 20–39 | 2005–2006 | 7.58 | 0.75 | 9
Mexican American male | 20–39 | 2007–2008 | 8.43 | 0.97 | 9
Mexican American male | 40–59 | 2005–2006 | 18.8 | 2.4 | 4
Mexican American male | 40–59 | 2007–2008 | 24.5 | 2.9 | 6
Mexican American male | 60+ | 2005–2006 | 30.7 | 6.3 | 4
Mexican American male | 60+ | 2007–2008 | 40.3 | 4.5 | 5
Mexican American female | 12–19 | 2005–2006 | 3.53 | 0.23 | 16
Mexican American female | 12–19 | 2007–2008 | *^f^ | * | 5
Mexican American female | 20–39 | 2005–2006 | 6.40 | 0.75 | 9
Mexican American female | 20–39 | 2007–2008 | 7.55 | 0.9 | 8
Mexican American female | 40–59 | 2005–2006 | 18.5 | 1.7 | 6
Mexican American female | 40–59 | 2007–2008 | 22.6 | 4.4 | 6
Mexican American female | 60+ | 2005–2006 | 46.4 | 9.8 | 3
Mexican American female | 60+ | 2007–2008 | 46.9 | 8 | 5

a The limit of detection for survey years 2005–2006 and 2007–2008 were 0.77 and 1.4 ng/g, respectively.

b Weighted arithmetic means are not comparable to weighted geometric means.

c Unadjusted standard errors do not incorporate survey design effects.

d Each pool was composed of serum from 8 persons.

e Standard error of the mean estimate is >30%.

f Not calculated: proportion of results below limit of detection was too high to provide a valid result.

Source: CDC 2017

Table 5-21 Weighted Arithmetic Mean and Unadjusted Standard Error of Pooled Serum Concentrations of Serum trans-Nonachlor (Whole Weight) (in ng/g of Serum or Parts per Billion) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES) 2005–2008

Category | Age (years) | Survey years^a^ | Weighted arithmetic mean^b^ | Unadjusted standard error^c^ | Number of pools^d^
Non-Hispanic white male | 12–19 | 2005–2006 | 0.048^e^ | 0.015 | 9
Non-Hispanic white male | 12–19 | 2007–2008 | 0.030 | 0.005 | 6
Non-Hispanic white male | 20–39 | 2005–2006 | 0.086 | 0.019 | 12
Non-Hispanic white male | 20–39 | 2007–2008 | 0.076 | 0.011 | 15
Non-Hispanic white male | 40–59 | 2005–2006 | 0.206 | 0.034 | 12
Non-Hispanic white male | 40–59 | 2007–2008 | 0.159 | 0.012 | 16
Non-Hispanic white male | 60+ | 2005–2006 | 0.331 | 0.049 | 15
Non-Hispanic white male | 60+ | 2007–2008 | 0.325 | 0.028 | 23
Non-Hispanic white female | 12–19 | 2005–2006 | 0.026 | 0.003 | 10
Non-Hispanic white female | 12–19 | 2007–2008 | 0.031 | 0.004 | 7
Non-Hispanic white female | 20–39 | 2005–2006 | 0.063 | 0.01 | 16
Non-Hispanic white female | 20–39 | 2007–2008 | 0.054 | 0.007 | 13
Non-Hispanic white female | 40–59 | 2005–2006 | 0.161 | 0.019 | 13
Non-Hispanic white female | 40–59 | 2007–2008 | 0.108 | 0.009 | 17
Non-Hispanic white female | 60+ | 2005–2006 | 0.362 | 0.04 | 17
Non-Hispanic white female | 60+ | 2007–2008 | 0.352 | 0.045 | 21
Non-Hispanic black male | 12–19 | 2005–2006 | 0.032 | 0.003 | 13
Non-Hispanic black male | 12–19 | 2007–2008 | 0.022 | 0.003 | 6
Non-Hispanic black male | 20–39 | 2005–2006 | 0.049 | 0.006 | 6
Non-Hispanic black male | 20–39 | 2007–2008 | 0.050 | 0.006 | 6
Non-Hispanic black male | 40–59 | 2005–2006 | 0.140 | 0.014 | 5
Non-Hispanic black male | 40–59 | 2007–2008 | 0.138 | 0.013 | 6
Non-Hispanic black male | 60+ | 2005–2006 | 0.390 | 0.071 | 5
Non-Hispanic black male | 60+ | 2007–2008 | 0.331 | 0.032 | 8
Non-Hispanic black female | 12–19 | 2005–2006 | 0.022 | 0.003 | 14
Non-Hispanic black female | 12–19 | 2007–2008 | 0.016^e^ | 0.005 | 5
Non-Hispanic black female | 20–39 | 2005–2006 | 0.054 | 0.007 | 7
Non-Hispanic black female | 20–39 | 2007–2008 | 0.032 | 0.003 | 8
Non-Hispanic black female | 40–59 | 2005–2006 | 0.154 | 0.009 | 7
Non-Hispanic black female | 40–59 | 2007–2008 | 0.124 | 0.012 | 8
Non-Hispanic black female | 60+ | 2005–2006 | 0.588 | 0.088 | 5
Non-Hispanic black female | 60+ | 2007–2008 | 0.409 | 0.027 | 7
Mexican American male | 12–19 | 2005–2006 | 0.020 | 0.002 | 11
Mexican American male | 12–19 | 2007–2008 | 0.020 | 0.004 | 6
Mexican American male | 20–39 | 2005–2006 | 0.054 | 0.005 | 9
Mexican American male | 20–39 | 2007–2008 | 0.058 | 0.008 | 9
Mexican American male | 40–59 | 2005–2006 | 0.153 | 0.022 | 4
Mexican American male | 40–59 | 2007–2008 | 0.176 | 0.024 | 6
Mexican American male | 60+ | 2005–2006 | 0.228 | 0.06 | 4
Mexican American male | 60+ | 2007–2008 | 0.289 | 0.028 | 5
Mexican American female | 12–19 | 2005–2006 | 0.019 | 0.001 | 16
Mexican American female | 12–19 | 2007–2008 | *^f^ | * | 5
Mexican American female | 20–39 | 2005–2006 | 0.042 | 0.005 | 9
Mexican American female | 20–39 | 2007–2008 | 0.044 | 0.006 | 8
Mexican American female | 40–59 | 2005–2006 | 0.135 | 0.011 | 6
Mexican American female | 40–59 | 2007–2008 | 0.151 | 0.029 | 6
Mexican American female | 60+ | 2005–2006 | 0.360 | 0.095 | 3
Mexican American female | 60+ | 2007–2008 | 0.323 | 0.058 | 5

a The limit of detection for survey years 2005–2006 and 2007–2008 were 0.77 and 1.4 ng/g, respectively.

b Weighted arithmetic means are not comparable to weighted geometric means.

c Unadjusted standard errors do not incorporate survey design effects.

d Each pool was composed of serum from 8 persons.

e Standard error of the mean estimate is >30%.

f Not calculated: proportion of results below limit of detection was too high to provide a valid result.

Source: CDC 2017

Workers may be exposed to chlordane during its manufacture, formulation, shipping, storage, application, and disposal. The National Occupational Exposure Survey (NOES) conducted by NIOSH from 1981 to 1983 estimated that 3,732 workers were potentially exposed to chlordane in the workplace in the United States (NIOSH 1989a). The NOES was based on field surveys of 4,490 businesses employing nearly 1.8 million workers and was designed as a nationwide survey based on a statistical sample of virtually all workplace environments in the United States in which eight or more persons are employed in all standard industrial codes except mining or agriculture.

Workplace monitoring data are available from two studies conducted simultaneously by Velsicol (Cahill et al. 1979) and the State of California (Maddy et al. 1979). In these studies, patches were attached to the inside and outside of the applicators’ coveralls, and breathing zone air was monitored while chlordane was applied to six houses (three with a crawl space and three on a concrete slab). Cahill et al. (1979) reported that 0.015–7.96 mg/cm^2^ (median 0.175 mg/cm^2^, 24 samples) was found on the 100 cm^2^ denim patches attached just above the knees and elbows of the applicators’ coveralls, whereas Maddy et al. (1979) found 0.005–2.9 mg/cm^2^ (median 0.12 mg/cm^2^, 23 samples) for 100 cm^2^ duck cotton cloth (similar to denim) patches attached below the knees and elbows. Concentrations inside the coveralls were determined by Cahill et al. (1979) by attaching a denim patch to the work pants (worn under the coveralls) at the knee and to the inside of the coveralls at the elbow (but not overlapping the outside elbow patch). Maddy et al. (1979) determined inside concentrations by attaching eight layers of cotton cheese cloth backed by aluminum foil to the inner surface of the duck cloth patches attached below the knees and elbows of the applicators. Cahill et al. (1979) found 0.0053–0.127 mg/cm^2^ (median 0.024 mg/cm^2^, 24 samples) on the inside patches, whereas Maddy et al. (1979) found 0.009–l.9 mg/cm^2^ (median 0.082 mg/cm^2^, 23 samples) on the cheese cloth backing.

Air impingers were worn by the applicators both on the lapel and on the chin inside the respirator. Air concentrations were reported for both inside and outside the respirator by Maddy et al. (1979), but only one value was reported by Cahill et al. (1979). Cahill et al. (1979) reported finding chlordane in all four samples analyzed (0.16–14.2 mg/m^3^), whereas Maddy et al. (1979) found 0.007, 0.008, and 0.110 mg/m^3^ in three of five samples taken outside the respirator and 0.011 and 0.27 mg/m^3^ in two of six samples taken inside the respirator. No detection limit was reported by Maddy et al. (1979); therefore, no information is available concerning the samples with concentrations too low to detect.

Kamble et al. (1992) studied the exposure of 29 commercial applicators exposed to Termide® EC (technical chlordane 39.22% plus heptachlor 19.6%), diluted to 0.75% (active ingredient) during subterranean termite treatment of homes. Dermal exposure was monitored using 14 gauze pads for each applicator attached to exterior and interior parts of clothing for an average duration of 138 minutes. Exposure to hands was monitored by hand rinses immediately after application. Respiratory exposure was assessed with personnel-type air samplers (see Table 5-6). Total dermal exposure of applicators to chlordane was 2.5 μg/kg/hour. The most exposed body regions in descending order were: hands, forearms, head, lower legs, thighs, back trunk, front trunk, upper arms, and back of the neck. Approximately 25% of the chlordane on the exterior surface of clothing was likely to penetrate through the fabric. Respiratory exposure was 0.04 μg/kg/hour.

Elia et al. (1983) reported that chlordane was detected in the water and air of a sewage treatment plant near Memphis, Tennessee, and suggested that occupational exposures to semi-volatile compounds such as chlordane could occur at these plants. No chlordane data, however, were presented. Former occupational exposures, in addition to termite control, included chlordane manufacturing, formulation, distribution, and agricultural and lawn care pesticide application. Since chlordane is no longer manufactured or used commercially in the United States (EPA 1988c), these occupational exposures no longer exist. No data are available that would allow the estimation of workplace levels during manufacture and use.

## 5.7 POPULATIONS WITH POTENTIALLY HIGH EXPOSURES

A segment of the general population with potentially high exposure to chlordane includes those people living in structures that were treated with chlordane for termite control or people digging in soil around these houses. The majority of these structures are located in the deep south and far southwest where termites are a significant problem, but moderate to heavy use of chlordane extended from Pennsylvania and the lower New England states south and west to the lower portion of Colorado and up to northern California. The available data indicate that these exposures would be much greater than exposures from other sources of chlordane. Persons involved in the manufacture of chlordane and persons involved in the application of chlordane before its use was banned on April 14, 1988, may have been exposed to relatively high levels. Similarly, lawn care workers and farmers that handled chlordane before above-ground uses were banned may have been exposed to high levels of the chemical. Populations living near waste disposal sites containing chlordane may have been exposed to elevated levels of chlordane.