# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of chlordane are listed in Table 4-1. Technical chlordane is a mixture of >140 related compounds, 120 of which have been identified by high resolution gas spectroscopy with electron capture, negative ionization mass spectroscopy (Dearth and Hites 1991c). Most of these compounds are minor or trace components. Sixty to 85% of technical chlordane consists of the stereoisomers cis- and trans-chlordane (Buchert et al. 1989; Worthing and Walker 1987). The ratio of the cis and trans isomers depends on the manufacturing process (Buchert et al. 1989). cis-Chlordane (1α,2α,3aα,4β,7β,7aα) is also known as α-chlordane. trans-Chlordane (1α,2 β,3aα,4β,7β,7aα) is commonly known as γ-chlordane, although it is occasionally referred to as ß-chlordane (CAS 1992; EPA 1984; Worthing and Walker 1987). This is particularly confusing because γ-chlordane is also the common name of the 2,2,4,5,6,7,8,8-octachloro isomer. This toxicological profile for chlordane uses the names cis- and trans-chlordane to avoid confusion.

Table 4-1 Chemical Identity of Chlordane

Characteristic | Information | | Reference
Chemical name | 1,2,4,5,6,7,8,8-Octachloro-2,3,3a,4,7,7a-hexahydro-4,7-methano-1H-indene | | CAS 1987
Synonym(s) and registered trade name(s) | 1,2,4,5,6,7,8,9-Octachloro-3a,4,7,7a-tetrahydro-4,7-methanoinden; Chlordan; Velsicol 1068®; Octachlor® | | Anonymous 1988; CAS 1987
Chemical formula | C_10_H_6_Cl_8_ | | CAS 1988
Chemical structure | trans; [image] | cis; [image] | CAS 1988
CAS Registry Number | 12789-03-6 (technical); 57-74-9 (nonstereospecific); 5103-71-9 (cis-chlordane or α-chlordane); 5103-74-2 (trans-chlordane or γ-chlordane) | | CAS 1988; Worthing and Walker 1987

CAS = Chemical Abstracts Service

Other major constituents of technical chlordane are chlordene; heptachlor; cis-, and trans-nonachlor; α-, ß-, and γ-chlordene; 3a,4,5,5a,6-exo-hexachloro-1a,2,3,3a,5a,5b-hexahydro-1,4-methano-1H-cyclobuta[cd]pentalene; and 2,4,4,5,6,6,7,8-octachloro-2,3,3a,4,5,7a-hexahydro-1,4-methano-1H-indene (Miyazaki et al. 1985; Parlar et al. 1979).

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of chlordane are presented in Table 4-2. The physical and chemical properties of technical chlordane are difficult to specify since there are many components in the technical mixture. For example, technical chlordane is a viscous liquid made of a mixture of many compounds that are solids when pure (a eutectic mixture). The state of the technical product alone will determine the specific properties of the product. For example, the vapor pressure of individual components of chlordane will be lower than that of the technical product because individual components are solids and have crystal lattice energies that reduce their vapor pressures relative to a liquid (Bidleman and Foreman 1987). The vapor pressure of the mixture will also change over time since the more volatile components will be removed faster, changing the composition of the mixture. Compositional changes with time may also result from different rates of degradation and transport among the constituents of the mixture. Additionally, physical properties are not always available for the technical product, which makes comparing properties difficult and increases the uncertainty of any calculated properties. Finally, the overall effect of these differences cannot be evaluated since a complete set of physical properties for the components and technical product is not available.

Table 4-2 Physical and Chemical Properties of Chlordane

Property | Information | Reference
Molecular weight | 409.76 (pure chlordane) | Windholz 1983
Color | Amber | Windholz 1983
Color | Colorless | Hawley 1981
Physical state | Viscous liquid (technical product) | Windholz 1983
Melting point
cis-chlordane | 106–107°C | Worthing and Walker 1987
trans-chlordane | 104–1-5°C | Worthing and Walker 1987
Boiling point | 175°C at 2 mmHg | Hawley 1981
Density at 25°C | 1.59–1.63 g/cm^3^ | Windholz 1983
Odor | Odorless | Hawley 1981
Odor | Mild pungent | NRCC 1974
Odor threshold: | 0.0084–0.0419 mg/m^3^ | Ruth 1986
Solubility:^a^
Water at 25°C | 0.056 mg/L for cis:trans (75:25) | Sanborn et al. 1976
Water at 25°C | 1.850 mg/L^b^ | Weil et al. 1974
Organic solvents | Miscible with hydrocarbon solvents | Whetstone 1964; Worthing and Walker 1987
Partition coefficients:
Log K_ow_ | 5.54 (estimated for pure chlordane) | EPA 1986b
Log K_oc_ | 3.49–4.64^c^ | Lyman 1982
Log K_oc_ | 6.3 (trans-) suspended solids | Lau et al. 1989
Vapor pressure:^d^ | | Foreman and Bidleman 1987
cis-chlordane
(supercooled liquid) | 2.2×10^−5^ mmHg
(crystal)^e^ | 3.0×10^−6^ mmHg
trans-chlordane
(supercooled liquid) | 2.9×10^−5^ mmHg
(crystal)^e^ | 3.9×10^−6^ mmHg
Henry’s law constant at 25°C | 4.85×10^−5^ atm-m^3^/mol^b^ | Suntio et al. 1988
Henry’s law constant at 25°C | 8.31×10^−5^ atm-m^3^/mol (trans-) | Fendinger et al. 1989
Henry’s law constant at 25°C | 4.8×10^−5^ atm-m^3^/mol | Cotham and Bidleman 1991
Autoignition temperature | No data
Flashpoint | 56°C (open cup) | OHM/TADS 1988
Flammability limits | No data
Conversion factors | 1 ppm (v/v) = 16.75 mg/m^3^ in air | HSDB 1988
Conversion factors | 1 mg/m^3^ = 0.0597 ppm (v/v) in air
Explosive limits | No data

a The solubility of the components of technical chlordane may differ from the solubility of the technical product.

b Study did not specify whether test substance was technical grade or a mixture.

c Estimated for pure chlordane using Equations 4-5 and 4-8 in Lyman (1982).

d Vapor pressure for technical chlordane may differ from that of individual components of technical chlordane.

e Calculated from the supercooled value.