# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR CHLORDANE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to chlordane.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, and chemical interactions data for chlordane. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of chlordane have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of chlordane are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects; Species; Human; Laboratory mammals; Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data); Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer
Toxicokinetics; Absorption; Distribution; Metabolism; Excretion; PBPK models; Biomarkers; Biomarkers of exposure; Biomarkers of effect; Interactions with other chemicals

### B.1.1 Literature Search

The current literature search was intended to update the health effects sections of the existing toxicological profile for chlordane (ATSDR 1994), thus, the literature search was restricted to studies published between January 1990 to April 2017. The following main databases were searched in April 2017:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, and Medical Subject Headings (MeSH) terms for chlordane. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance priority list (SPL) resource page, and other items as needed. Regulations applicable to chlordane were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
04/2017 | (((“Chlordan”[mh]) OR (“nonachlor”[nm])) AND (1992/01/01 : 3000[mhda] OR 1992/01/01 : 3000[dp])) OR ((((“1,2,4,5,6,7,10,10-Octachloro-4,7,8,9-tetrahydro-4,7-methyleneindane”[tw] “1,2,4,5,6,7,8,8-Octachloro-2,3,3a, 4,7,7a-hexahydro-4,7-methanoindene”[tw] OR “1,2,4,5,6,7,8,8-Octachloro-4,7-methano-3a, 4,7,7a-tetrahydroindane”[tw] OR “1,2,4,5,6,7,8,8-Ottochloro-3a, 4,7,7a-tetraidro-4,7-endo-metano-indano”[tw] OR “1,2,4,5,6,7,8,8-Ottochloro-3a, 4,7,7a-tetraidro-4,7-endo-metano-indano [Italian]”[tw] OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a, 4,7,7a-hexahydro-”[tw] OR “4,7-Methanoindan, 1,2,4,5,6,7,8,8-octachloro-2,3,3a, 4,7,7a-hexahydro-”[tw] OR “4,7-Methanoindan, 1,2,4,5,6,7,8,8-octachloro-3a, 4,7,7a-tetrahydro-”[tw] OR “4,7-Methanoinden, 1,2,4,5,6,7,8,9-octachloro-3a, 4,7,7a-tetrahydro-”[tw] OR “Aspon-chlordane”[tw] OR “Chlor Kil”[tw] OR “Chlordan”[tw] OR “Chlordane”[tw] OR “Chlordane, technical”[tw] OR “Chlordane-technical”[tw] OR “Chlorindan”[tw] OR “Chlorotox”[tw] OR “Clordano”[tw] OR “Corodane”[tw] OR “Cortilan-neu”[tw] OR “Dichlorochlordene”[tw] OR “Dowchlor”[tw] OR “HCS 3260”[tw] OR “Intox”[tw] OR “Kilex lindane”[tw] OR “Kypchlor”[tw] OR “Octa-klor”[tw] OR “Octachlor”[tw] OR “Octachlordane”[tw] OR “Octachloro-4,7-methanotetrahydroindane”[tw] OR “Octachlorodihydrodicyclopentadiene”[tw] OR “Oktaterr”[tw] OR “OMS 1437”[tw] OR “Ortho-Klor”[tw] OR “SD 5532”[tw] OR “Shell SD-5532”[tw] OR “Starchlor”[tw] OR “Sydane”[tw] OR “Synklor”[tw] OR “TAT chlor 4”[tw] OR “Termex”[tw] OR “Termi-ded”[tw] OR “Topichlor 20”[tw] OR “Topiclor”[tw] OR “Toxichlor”[tw] OR “Unexan-Koeder”[tw] OR “Velsicol 1068”[tw] OR “(1alpha, 2alpha, 3aalpha, 4beta, 7beta, 7aalpha)-1,2,4,5,6,7,8,8-Octachloro-2,3,3a, 4,7,7a-hexahydro-4,7-methano-1H-indene”[tw] OR “(1alpha, 2beta, 3aalpha, 4beta, 7beta, 7aalpha)-1,2,4,5,6,7,8,8-Octachloro-2,3,3a, 4,7,7a-hexahydro-4,7-methano-1H-indene”[tw] OR “1,4-Ethenopentalene, 1,2,3,5,7,8-hexachloro-1,3a, 4,5,6,6a-hexahydro-,(1-alpha, 3a-alpha, 4-beta, 5-alpha, 6a-alpha)-”[tw] OR “1,4-Ethenopentalene, 1,2,3,5,7,8-hexachloro-1,3a, 4,5,6,6a-hexahydro-,(1R, 3aS, 4S, 5S, 6aS)-rel-”[tw] OR “1,6-Methano-1H-indene, 2,3,3a, 4,5,8-hexachloro-3a, 6,7,7a-tetrahydro-,(1-alpha, 3a-beta, 6-alpha, 7a-beta, 8R*)-”[tw] OR “1,6-Methano-1H-indene, 2,3,3a, 4,5,8-hexachloro-3a, 6,7,7a-tetrahydro-,(1R, 3aR, 6S, 7aR, 8R)-rel-”[tw] OR “1-exo, 2-endo, 4,5,6,7,8,8-Octachloro-2,3-exo-epoxy-2,3,3a, 4,7,7a-hexahydro-4,7-methanoindene”[tw] OR “2,5-Methano-2H-indeno(1,2-b)oxirene, 2,3,4,5,6,6a, 7,7-octachloro-1a, 1b, 5,5a, 6,6a-hexahydro-”[tw] OR “2,5-Methano-2H-indeno(1,2-b)oxirene, 2,3,4,5,6,6a, 7,7-octachloro-1a, 1b, 5,5a, 6,6a-hexahydro-,(1aR, 1bS, 2R, 5S, 5aR, 6S, 6aS)-rel-”[tw] OR “3a, 4,7,7a-Tetrahydro-1,2-epoxy-4,5,6,7,8,8-hexachloro-4,7-methanoindan”[tw] OR “4,5,6,7,8,8-Hexachlor-delta(sup 1,5)-tetrahydro-4,7-methanoinden”[tw] OR “4,5,6,7,8,8-Hexachloro-3a, 4,7,7a-tetrahydro-4,7-methano-1H-indene”[tw] OR “4,5,6,7,8,8-Hexachloro-3a, 4,7,7a-tetrahydro-4,7-methanoindene”[tw] OR “4,7-Methano-1H-indene, 1,2,3,4,5,6,7,8,8-nonachlor-2,3,3a, 4,7,7a-hexahydro-,(1-alpha, 2-beta, 3-alpha, 3a-alpha, 4-beta, 7-beta, 7a-alpha)-”[tw] OR “4,7-Methano-1H-indene, 1,2,3,4,5,6,7,8,8-nonachloro-2,3,3a, 4,7,7a-hexahydro-,(1alpha, 2alpha, 3alpha)-”[tw] OR “4,7-Methano-1H-indene, 1,2,3,4,5,6,7,8,8-nonachloro-2,3,3a, 4,7,7a-hexahydro-,(1alpha, 2alpha, 3alpha, 3aalpha, 4beta, 7beta, 7aalph”[tw] OR “4,7-Methano-1H-indene, 1,2,3,4,5,6,7,8,8-nonachloro-2,3,3a, 4,7,7a-hexahydro-,(1alpha, 2beta, 3alpha, 3aalpha, 4beta, 7beta,”[tw] OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a, 4,7,7a-hexahydro-,(1alpha, 2alpha, 3a alpha, 4beta, 7beta, 7a alpha)-”[tw] OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro2,3,3a, 4,7,7a-hexahydro-,(1alpha, 2beta, 3a alpha, 4beta, 7beta, 7a alpha)-”[tw] OR “4,7Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a, 4,7,7a-hexahydro-,(1R, 2R, 3aS, 4S, 7R, 7aS)-rel-”[tw] OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a, 4,7,7a-hexahydro-,(1R, 2S, 3aS, 4S, 7R, 7aS)-rel”[tw] OR “4,7-Methano-1H-indene, 4,5,6,7,8,8-hexachloro-3a, 4,7,7a-tetrahydro-”[tw] OR “4,7-Methanoindan, 1,2,4,5,6,7,8,8-octachloro-2,3-epoxy-3a, 4,7,7a-tetrahydro-, exo, endo-”[tw] OR “4,7-Methanoindan, 1-alpha, 2-alpha, 4-beta, 5,6,7-beta, 8,8-octachloro-3a-alpha, 4,7,7a-alpha-tetrahydro-”[tw] OR “4,7-Methanoindan, 3a, 4,7,7a-tetrahydro-2,3-epoxy-1,2,4,5,6,7,8,8-octachloro-, exo, endo-”[tw] OR “4,7-Methanoindan, 3a-beta, 4,7,7a-beta-tetrahydro-1-beta, 2-alpha, 4-alpha, 5,6,7-alpha, 8,8-octachloro-”[tw] OR “4,7-Methanoindene, 4,5,6,7,8,8-hexachloro-3a, 4,7,7a-tetrahydro-”[tw] OR “4,7-Methanoindene, 4,5,6,7,8,8-hexachloro-delta(sup 1,5)-tetrahydro-”[tw] OR “c-Nonachlor”[tw] OR “Chlordene”[tw] OR “cis-Nonachlor”[tw] OR “gamma-Chlordene”[tw] OR “Nonachlor, cis-”[tw] OR “Nonachlor, trans-”[tw] OR “Oxychlordan”[tw] OR “Oxychlordane”[tw] OR “t-Nonachlor”[tw] OR “trans-Nonachlor”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic “[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[sh:noexp] OR “chlordan/antagonists and inhibitors”[Mesh Terms] OR “hydrocarbons, chlorinated/antagonists and inhibitors”[Mesh Terms] OR toxicokinetics[mh:noexp])) OR ((“1,2,4,5,6,7,10,10-Octachloro-4,7,8,9-tetrahydro-4,7-methyleneindane”[tw] OR “1,2,4,5,6,7,8,8-Octachloro-2,3,3a, 4,7,7a-hexahydro-4,7-methanoindene”[tw] OR “1,2,4,5,6,7,8,8-Octachloro-4,7-methano-3a, 4,7,7a-tetrahydroindane”[tw] OR “1,2,4,5,6,7,8,8-Ottochloro-3a, 4,7,7a-tetraidro-4,7-endo-metano-indano”[tw] OR “1,2,4,5,6,7,8,8-Ottochloro-3a, 4,7,7a-tetraidro-4,7-endo-metano-indano [Italian]”[tw] OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a, 4,7,7a-hexahydro-”[tw] OR “4,7-Methanoindan, 1,2,4,5,6,7,8,8-octachloro-2,3,3a, 4,7,7a-hexahydro-”[tw] OR “4,7-Methanoindan, 1,2,4,5,6,7,8,8-octachloro-3a, 4,7,7a-tetrahydro”-[tw] OR “4,7-Methanoinden, 1,2,4,5,6,7,8,9-octachloro-3a, 4,7,7a-tetrahydro-”[tw] OR “Aspon-chlordane”[tw] OR “Chlor Kil”[tw] OR “Chlordan”[tw] OR “Chlordane”[tw] OR “Chlordane, technical”[tw] OR “Chlordane-technical”[tw] OR “Chlorindan”[tw] OR “Chlorotox”[tw] OR “Clordano”[tw] OR “Corodane”[tw] OR “Cortilan-neu”[tw] OR “Dichlorochlordene”[tw] OR “Dowchlor”[tw] OR “HCS 3260”[tw] OR “Intox”[tw] OR “Kilex lindane”[tw] OR “Kypchlor”[tw] OR “Octa-klor”[tw] OR “Octachlor”[tw] OR “Octachlordane”[tw] OR “Octachloro-4,7-methanotetrahydroindane”[tw] OR “Octachlorodihydrodicyclopentadiene”[tw] OR “Oktaterr”[tw] OR “OMS 1437”[tw] OR “Ortho-Klor”[tw] OR “SD 5532”[tw] OR “Shell SD-5532”[tw] OR “Starchlor”[tw] OR “Sydane”[tw] OR “Synklor”[tw] OR “TAT chlor 4”[tw] OR “Termex”[tw] OR “Termi-ded”[tw] OR “Topichlor 20”[tw] OR “Topiclor”[tw] OR “Toxichlor”[tw] OR “Unexan-Koeder”[tw] OR “Velsicol 1068”[tw] OR “(1alpha, 2alpha, 3aalpha, 4beta, 7beta, 7aalpha)-1,2,4,5,6,7,8,8-Octachloro-2,3,3a, 4,7,7a-hexahydro-4,7-methano-1H-indene”[tw] OR “(1alpha, 2beta, 3aalpha, 4beta, 7beta, 7aalpha)-1,2,4,5,6,7,8,8-Octachloro-2,3,3a, 4,7,7a-hexahydro-4,7-methano-1H-indene”[tw] OR “1,4-Ethenopentalene, 1,2,3,5,7,8-hexachloro-1,3a, 4,5,6,6a-hexahydro-,(1-alpha, 3a-alpha, 4-beta, 5-alpha, 6a-alpha)-”[tw] OR “1,4-Ethenopentalene, 1,2,3,5,7,8-hexachloro-1,3a, 4,5,6,6a-hexahydro-,(1R, 3aS, 4S, 5S, 6aS)-rel-”[tw] OR “1,6-Methano-1H-indene, 2,3,3a, 4,5,8-hexachloro-3a, 6,7,7a-tetrahydro-,(1-alpha, 3a-beta, 6-alpha, 7a-beta, 8R*)-”[tw] OR “1,6-Methano-1H-indene, 2,3,3a, 4,5,8-hexachloro-3a, 6,7,7a-tetrahydro-,(1R, 3aR, 6S, 7aR, 8R)-rel-”[tw] OR “1-exo, 2-endo, 4,5,6,7,8,8-Octachloro-2,3-exo-epoxy-2,3,3a, 4,7,7a-hexahydro-4,7-methanoindene”[tw] OR “2,5-Methano-2H-indeno(1,2-b)oxirene, 2,3,4,5,6,6a, 7,7-octachloro-1a, 1b, 5,5a, 6,6a-hexahydro-”[tw] OR “2,5-Methano-2H-indeno(1,2-b)oxirene, 2,3,4,5,6,6a, 7,7-octachloro-1a, 1b, 5,5a, 6,6a-hexahydro-,(1aR, 1bS, 2R, 5S, 5aR, 6S, 6aS)-rel-”[tw] OR “3a, 4,7,7a-Tetrahydro-1,2-epoxy-4,5,6,7,8,8-hexachloro-4,7-methanoindan”[tw] OR “4,5,6,7,8,8-Hexachlor-delta(sup 1,5)-tetrahydro-4,7-methanoinden”[tw] OR “4,5,6,7,8,8-Hexachloro-3a, 4,7,7a-tetrahydro-4,7-methano-1H-indene”[tw] OR “4,5,6,7,8,8-Hexachloro-3a, 4,7,7a-tetrahydro-4,7-methanoindene”[tw] OR “4,7-Methano-1H-indene, 1,2,3,4,5,6,7,8,8-nonachlor-2,3,3a, 4,7,7a-hexahydro-,(1-alpha, 2-beta, 3-alpha, 3a-alpha, 4-beta, 7-beta, 7a-alpha)-”[tw] OR “4,7-Methano-1H-indene, 1,2,3,4,5,6,7,8,8-nonachloro-2,3,3a, 4,7,7a-hexahydro-,(1alpha, 2alpha, 3alpha)-”[tw] OR “4,7-Methano-1H-indene, 1,2,3,4,5,6,7,8,8-nonachloro-2,3,3a, 4,7,7a-hexahydro-,(1alpha, 2alpha, 3alpha, 3aalpha, 4beta, 7beta, 7aalph”[tw] OR “4,7-Methano-1H-indene, 1,2,3,4,5,6,7,8,8-nonachloro-2,3,3a, 4,7,7a-hexahydro-,(1alpha, 2beta, 3alpha, 3aalpha, 4beta, 7beta,”[tw] OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a, 4,7,7a-hexahydro-,(1alpha, 2alpha, 3a alpha, 4beta, 7beta, 7a alpha)-”[tw] OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a, 4,7,7a-hexahydro-,(1alpha, 2beta, 3a alpha, 4beta, 7beta, 7a alpha)-”[tw] OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a, 4,7,7a-hexahydro-,(1R, 2R, 3aS, 4S, 7R, 7aS)-rel-”[tw] OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a, 4,7,7a-hexahydro-,(1R, 2S, 3aS, 4S, 7R, 7aS)-rel”[tw] OR “4,7-Methano-1H-indene, 4,5,6,7,8,8-hexachloro-3a, 4,7,7a-tetrahydro-”[tw] OR “4,7-Methanoindan, 1,2,4,5,6,7,8,8-octachloro-2,3-epoxy-3a, 4,7,7a-tetrahydro-, exo, endo-”[tw] OR “4,7-Methanoindan, 1-alpha, 2-alpha, 4-beta, 5,6,7-beta, 8,8-octachloro-3a-alpha, 4,7,7a-alpha-tetrahydro-”[tw] OR “4,7-Methanoindan, 3a, 4,7,7a-tetrahydro-2,3-epoxy-1,2,4,5,6,7,8,8-octachloro-, exo, endo-”[tw] OR “4,7-Methanoindan, 3a-beta, 4,7,7a-beta-tetrahydro-1-beta, 2-alpha, 4-alpha, 5,6,7-alpha, 8,8-octachloro-”[tw] OR “4,7-Methanoindene, 4,5,6,7,8,8-hexachloro-3a, 4,7,7a-tetrahydro-”[tw] OR “4,7-Methanoindene, 4,5,6,7,8,8-hexachloro-delta(sup 1,5)-tetrahydro-”[tw] OR “c-Nonachlor”[tw] OR “Chlordene”[tw] OR “cis-Nonachlor”[tw] OR “gamma-Chlordene”[tw] OR “Nonachlor, cis-”[tw] OR “Nonachlor, trans-”[tw] OR “Oxychlordan”[tw] OR “Oxychlordane”[tw] OR “t-Nonachlor”[tw] OR “trans-Nonachlor”[tw]) NOT medline[sb])) AND (1992/01/01 : 3000[dp] OR 1992/01/01 : 3000[crdt] OR 1992/01/01 : 3000[edat]))
Toxline
04/2017 | “( 57-74-9 [rn] ) AND 1992:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) [not] PubMed [org] [not] pubdart [org]; ( 5103-71-9 [rn] ) AND 1992:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) [not] PubMed [org] [not] pubdart [org]; ( 5103-74-2 [rn] ) AND 1992:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) [not] PubMed [org] [not] pubdart [org]; ( 27304-13-8 [rn] ) AND 1992:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) [not] PubMed [org] [not] pubdart [org]; ( 56641-38-4 [rn] ) AND 1992:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) [not] PubMed [org] [not] pubdart [org]; ( 12789-03-6 [rn] ) AND 1992:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) [not] PubMed [org] [not] pubdart [org]; ( 56534-02-2 [rn] ) AND 1992:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) [not] PubMed [org] [not] pubdart [org]; ( 39765-80-5 [rn] ) AND 1992:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) [not] PubMed [org] [not] pubdart [org]; ( 5103-73-1 [rn] ) AND 1992:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) [not] PubMed [org] [not] pubdart [org]; ( 3734-48-3 [rn] ) AND 1992:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) [not] PubMed [org] [not] pubdart [org]; 39765-80-5 [rn] [not] PubMed [org] [not] pubdart [org]; ( “4 7 methanoindan 1 2 4 5 6 7 8 8 octachloro 2 3 3a 4 7 7a hexahydro “ OR “4 7 methanoindan 1 2 4 5 6 7 8 8 octachloro 3a 4 7 7a tetrahydro “ OR “4 7 methanoinden 1 2 4 5 6 7 8 9 octachloro 3a 4 7 7a tetrahydro “ OR “aspon chlordane” OR “chlor kil” OR “chlordan” OR “chlordane” ) AND 1992:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “chlordane technical” OR “chlordane technical” OR “chlorindan” OR “chlorotox” OR “clordano” OR “corodane” OR “cortilan neu” OR “dichlorochlordene” OR “dowchlor” OR “hcs 3260” OR “intox” OR “kilex lindane” OR “kypchlor” OR “octa klor” OR “octachlor” OR “octachlordane” OR “octachloro 4 7 methanotetrahydroindane” ) AND 1992:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “c nonachlor” OR “chlordene” OR “cis nonachlor” OR “gamma chlordene” OR “nonachlor cis “ OR “nonachlor trans “ OR “oxychlordan” OR “oxychlordane” OR “t nonachlor” OR “trans nonachlor” ) AND 1992:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]
Toxcenter
04/2017 | (FILE ‘HOME’ ENTERED AT 13:26:52 ON 06 APR 2017); FILE ‘TOXCENTER’ ENTERED AT 13:27:06 ON 06 APR 2017; CHARGED TO COST=EH011.13.01.01; L1 5760 SEA FILE=TOXCENTER 12789-03-6; L2 1053 SEA FILE=TOXCENTER 57-74-9; L3 4698 SEA FILE=TOXCENTER 5103-71-9 OR 5103-74-2 OR 27304-13-8 OR 56641-38-4 OR 56534-02-2 OR 39765-80-5 OR 5103-73-1 OR 3734-48-3; L4 10746 SEA FILE=TOXCENTER L1 OR L2 OR L3; L5 10719 SEA FILE=TOXCENTER L4 NOT TSCATS/FS; L6 10484 SEA FILE=TOXCENTER L5 NOT PATENT/DT; L7 6220 SEA FILE=TOXCENTER L6 AND PY>1991; ACT TOXQUERY/Q; ---------; L8 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L9 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L10 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L11 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L12 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L13 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L14 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L15 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L16 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L17 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L18 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L19 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L20 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L21 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L22 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L23 QUE (ENDOCRIN? AND DISRUPT?); L24 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L25 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L26 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L27 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L28 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L29 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L30 QUE (NEPHROTOX? OR HEPATOTOX?); L31 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L32 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L33 QUE L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31 OR L32; L34 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L35 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L36 QUE L33 OR L34 OR L35; L37 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L38 QUE L36 OR L37; ---------; L39 3586 SEA FILE=TOXCENTER L7 AND L38; L40 198 SEA FILE=TOXCENTER L39 AND MEDLINE/FS; L41 882 SEA FILE=TOXCENTER L39 AND BIOSIS/FS; L42 2446 SEA FILE=TOXCENTER L39 AND CAPLUS/FS; L43 60 SEA FILE=TOXCENTER L39 NOT (L40 OR L41 OR L42) SAVE TEMP L42 CHLORDANECA CHLORDANECA/A; L44 3074 DUP REM L40 L41 L43 L42 (512 DUPLICATES REMOVED); ANSWERS ‘1-3074’ FROM FILE TOXCENTER; L*** DEL 198 S L39 AND MEDLINE/FS; L*** DEL 198 S L39 AND MEDLINE/FS; L45 198 SEA FILE=TOXCENTER L44; L*** DEL 882 S L39 AND BIOSIS/FS; L*** DEL 882 S L39 AND BIOSIS/FS; L46 788 SEA FILE=TOXCENTER L44; L*** DEL 2446 S L39 AND CAPLUS/FS; L*** DEL 2446 S L39 AND CAPLUS/FS; L47 2037 SEA FILE=TOXCENTER L44; L*** DEL 60 S L39 NOT (L40 OR L41 OR L42); L*** DEL 60 S L39 NOT (L40 OR L41 OR L42); L48 51 SEA FILE=TOXCENTER L44; L49 788 SEA FILE=TOXCENTER (L45 OR L46 OR L47 OR L48) AND BIOSIS/FS; L50 643 SEA FILE=TOXCENTER L49 AND PY>1998; L51 0 SEA FILE=TOXCENTER L49 AND CAPLUS/FS; L*** DEL 198 S L39 AND MEDLINE/FS; L*** DEL 198 S L39 AND MEDLINE/FS; L52 198 SEA FILE=TOXCENTER L44; L*** DEL 882 S L39 AND BIOSIS/FS; L*** DEL 882 S L39 AND BIOSIS/FS; L53 788 SEA FILE=TOXCENTER L44; L*** DEL 2446 S L39 AND CAPLUS/FS; L*** DEL 2446 S L39 AND CAPLUS/FS; L54 2037 SEA FILE=TOXCENTER L44; L*** DEL 60 S L39 NOT (L40 OR L41 OR L42); L*** DEL 60 S L39 NOT (L40 OR L41 OR L42); L55 51 SEA FILE=TOXCENTER L44; L56 2037 SEA FILE=TOXCENTER (L52 OR L53 OR L54 OR L55) AND CAPLUS/FS SAVE TEMP L56 CHLORDANECA/A; L*** DEL 198 S L39 AND MEDLINE/FS; L*** DEL 198 S L39 AND MEDLINE/FS; L57 198 SEA FILE=TOXCENTER L44; L*** DEL 882 S L39 AND BIOSIS/FS; L*** DEL 882 S L39 AND BIOSIS/FS; L58 788 SEA FILE=TOXCENTER L44; L*** DEL 2446 S L39 AND CAPLUS/FS; L*** DEL 2446 S L39 AND CAPLUS/FS; L59 2037 SEA FILE=TOXCENTER L44; L*** DEL 60 S L39 NOT (L40 OR L41 OR L42); L*** DEL 60 S L39 NOT (L40 OR L41 OR L42); L60 51 SEA FILE=TOXCENTER L44; L61 51 SEA FILE=TOXCENTER (L57 OR L58 OR L59 OR L60) NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS) L62 694 SEA FILE=TOXCENTER L50 OR L61; L63 2731 SEA FILE=TOXCENTER L62 OR L56; D SCAN L62; D SCAN L56

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS ^a^
04/2017 | Compound searched:; 57-74-9; 5103-71-9; 5103-74-2; 27304-13-8; 56641-38-4; 12789-03-6; 56534-02-2; 39765-80-5; 5103-73-1; 3734-48-3
NTP
04/2017 | 57-74-9; 5103-71-9; 5103-74-2; 27304-13-8; 56641-38-4; 12789-03-6; 56534-02-2; 39765-80-5; 5103-73-1; 3734-48-3; chlordan; chlordane; chlordene; oxychlordane; cis-Nonachlor; trans-Nonachlor
NIH RePORTER
08/2017 | Text Search: “1,2,4,5,6,7,10,10-Octachloro-4,7,8,9-tetrahydro-4,7-methyleneindane” OR “1,2,4,5,6,7,8,8-Octachloro-2,3,3a,4,7,7a-hexahydro-4,7-methanoindene” OR “1,2,4,5,6,7,8,8-Octachloro-4,7-methano-3a,4,7,7a-tetrahydroindane” OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a,4,7,7a-hexahydro-” OR “4,7-Methanoindan, 1,2,4,5,6,7,8,8-octachloro-2,3,3a,4,7,7a-hexahydro-” OR “4,7-Methanoindan, 1,2,4,5,6,7,8,8-octachloro-3a,4,7,7a-tetrahydro-” OR “4,7-Methanoinden, 1,2,4,5,6,7,8,9-octachloro-3a,4,7,7a-tetrahydro-” OR “Aspon-chlordane” OR “Chlor Kil” OR “Chlordan” OR “Chlordane” OR “Chlordane, technical” OR “Chlordane-technical” OR “Chlorindan” OR “Chlorotox” OR “Clordano” OR “Corodane” OR “Cortilan-neu” OR “Dichlorochlordene” OR “Dowchlor” OR “HCS 3260” OR “Intox” OR “Kilex lindane” OR “Kypchlor” OR “Octa-klor” OR “Octachlor” OR “Octachlordane” OR “Octachloro-4,7-methanotetrahydroindane” OR “Octachlorodihydrodicyclopentadiene” OR “Oktaterr” OR “OMS 1437” OR “Ortho-Klor” OR “SD 5532” OR “Shell SD-5532” OR “Starchlor” OR “Sydane” OR “Synklor” OR “TAT chlor 4” OR “Termex” OR “Termi-ded” OR “Topichlor 20” OR “Topiclor” OR “Toxichlor” OR “Unexan-Koeder” OR “Velsicol 1068” OR “(1alpha,2alpha,3aalpha,4beta,7beta,7aalpha)-1,2,4,5,6,7,8,8-Octachloro-2,3,3a,4,7,7a-hexahydro-4,7-methano-1H-indene” OR “(1alpha,2beta,3aalpha,4beta,7beta,7aalpha)-1,2,4,5,6,7,8,8-Octachloro-2,3,3a,4,7,7a-hexahydro-4,7-methano-1H-indene” OR “1,4-Ethenopentalene, 1,2,3,5,7,8-hexachloro-1,3a,4,5,6,6a-hexahydro-, (1-alpha,3a-alpha,4-beta,5-alpha,6a-alpha)-” OR “1,4-Ethenopentalene, 1,2,3,5,7,8-hexachloro-1,3a,4,5,6,6a-hexahydro-, (1R,3aS,4S,5S,6aS)-rel-” OR “1,6-Methano-1H-indene, 2,3,3a,4,5,8-hexachloro-3a,6,7,7a-tetrahydro-, (1-alpha,3a-beta,6-alpha,7a-beta,8R)-” OR “1,6-Methano-1H-indene, 2,3,3a,4,5,8-hexachloro-3a,6,7,7a-tetrahydro-, (1R,3aR,6S,7aR,8R)-rel-” OR “1-exo,2-endo,4,5,6,7,8,8-Octachloro-2,3-exo-epoxy-2,3,3a,4,7,7a-hexahydro-4,7-methanoindene” OR “2,5-Methano-2H-indeno(1,2-b)oxirene, 2,3,4,5,6,6a,7,7-octachloro-1a,1b,5,5a,6,6a-hexahydro-” OR “2,5-Methano-2H-indeno(1,2-b)oxirene, 2,3,4,5,6,6a,7,7-octachloro-1a,1b,5,5a,6,6a-hexahydro-, (1aR,1bS,2R,5S,5aR,6S,6aS)-rel-” OR “3a,4,7,7a-Tetrahydro-1,2-epoxy-4,5,6,7,8,8-hexachloro-4,7-methanoindan” OR “4,5,6,7,8,8-Hexachlor-delta(sup 1,5)-tetrahydro-4,7-methanoinden” OR “4,5,6,7,8,8-Hexachloro-3a,4,7,7a-tetrahydro-4,7-methano-1H-indene” OR “4,5,6,7,8,8-Hexachloro-3a,4,7,7a-tetrahydro-4,7-methanoindene” (Advanced), Search in: Projects AdminIC: All, Fiscal Year: Active Projects; Text Search: “4,7-Methano-1H-indene, 1,2,3,4,5,6,7,8,8-nonachlor-2,3,3a,4,7,7a-hexahydro-, (1-alpha,2-beta,3-alpha,3a-alpha,4-beta,7-beta,7a-alpha)-” OR “4,7-Methano-1H-indene, 1,2,3,4,5,6,7,8,8-nonachloro-2,3,3a,4,7,7a-hexahydro-, (1alpha,2alpha,3alpha)-” OR “4,7-Methano-1H-indene, 1,2,3,4,5,6,7,8,8-nonachloro-2,3,3a,4,7,7a-hexahydro-, (1alpha,2alpha,3alpha,3aalpha,4beta,7beta,7aalph” OR “4,7-Methano-1H-indene, 1,2,3,4,5,6,7,8,8-nonachloro-2,3,3a,4,7,7a-hexahydro-, (1alpha,2beta,3alpha,3aalpha,4beta,7beta,” OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a,4,7,7a-hexahydro-, (1alpha,2alpha,3a alpha,4beta,7beta,7a alpha)-” OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a,4,7,7a-hexahydro-, (1alpha,2beta,3a alpha,4beta,7beta,7a alpha)-” OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a,4,7,7a-hexahydro-, (1R,2R,3aS,4S,7R,7aS)-rel-” OR “4,7-Methano-1H-indene, 1,2,4,5,6,7,8,8-octachloro-2,3,3a,4,7,7a-hexahydro-, (1R,2S,3aS,4S,7R,7aS)-rel” OR “4,7-Methano-1H-indene, 4,5,6,7,8,8-hexachloro-3a,4,7,7a-tetrahydro-” OR “4,7-Methanoindan, 1,2,4,5,6,7,8,8-octachloro-2,3-epoxy-3a,4,7,7a-tetrahydro-, exo,endo-” OR “4,7-Methanoindan, 1-alpha,2-alpha,4-beta,5,6,7-beta,8,8-octachloro-3a-alpha,4,7,7a-alpha-tetrahydro-” OR “4,7-Methanoindan, 3a,4,7,7a-tetrahydro-2,3-epoxy-1,2,4,5,6,7,8,8-octachloro-, exo,endo-” OR “4,7-Methanoindan, 3a-beta,4,7,7a-beta-tetrahydro-1-beta,2-alpha,4-alpha,5,6,7-alpha,8,8-octachloro-” OR “4,7-Methanoindene, 4,5,6,7,8,8-hexachloro-3a,4,7,7a-tetrahydro-” OR “4,7-Methanoindene, 4,5,6,7,8,8-hexachloro-delta(sup 1,5)-tetrahydro-” OR “c-Nonachlor” OR “Chlordene” OR “cis-Nonachlor” OR “gamma-Chlordene” OR “Nonachlor, cis-” OR “Nonachlor, trans-” OR “Oxychlordan” OR “Oxychlordane” OR “t-Nonachlor” OR “trans-Nonachlor” (Advanced), Search in: Projects AdminIC: All, Fiscal Year: Active Projects
Other | Identified throughout the assessment process

a Several versions of the TSCATS database were searched, as needed, by CASRN including TSCATS1 via Toxline (no date limit), TSCATS2 via https://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearch?OpenForm (date restricted by EPA receipt date), and TSCATS via CDAT (date restricted by ‘Mail Received Date Range’), as well as google for recent TSCA submissions.

The 2017 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 4,696
- Number of records identified from other strategies: 27
- Total number of records to undergo literature screening: 4,723

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on chlordane:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 4,723
- Number of studies considered relevant and moved to the next step: 60

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 60
- Number of studies cited in the health effects sections of the existing toxicological profile (May,1994): 169
- Total number of studies cited in the health effects sections of the updated profile: 228

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 April 2017 Literature Search Results and Screen for Chlordane

This figure shows April 2017 Literature Search Results and Screen for Chlordane