# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## Chlordane Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlordane
CAS Numbers: | 12789-03-6 (chlordane technical)
Date: | May 1994
| April 2017-Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: An MRL has not been derived for acute-duration inhalation exposure to chlordane. Only one acute inhalation study (Khasawinah et al. 1989; Velsicol Chemical Co. 1984) was located, and this study did not sufficiently identify target organs, and serious effects (death, convulsions) occurred at the lowest concentration tested.

Agency Contact (Chemical Manager): Jennifer Przybyla

## Chlordane Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlordane
CAS Numbers: | 12789-03-6 (chlordane technical)
Date: | May 1994
| April 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL | 0.0002 mg/m^3^
Critical Effect: | Hepatocellular hypertrophy
Reference: | Khasawinah et al. 1989; Velsicol Chemical Co. 1984
Point of Departure: | NOAEL_ADJ_ of 0.024 mg/m^3^
Uncertainty Factor: | 100
LSE Graph Key: | 3
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.0002 mg/m^3^ was derived for chlordane technical. The MRL is based on a NOAEL of 0.1 mg/m^3^ and a LOAEL of 1.0 mg/m^3^ for hepatocellular hypertrophy in rats exposed to chlordane technical for 8 hours/day, 5 days/week for 90 days (Khasawinah et al. 1989; Velsicol Chemical Co. 1984). The NOAEL was adjusted for intermittent exposure, converted to a human equivalent concentration, and divided by an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Intermediate-duration inhalation exposure data in rats have identified the hematological system, liver, central nervous system, thyroid, and possibly the thymus in female rats, as the target organs (Khasawinah et al. 1989; Velsicol Chemical Co. 1984). A NOAEL of 5.8 mg/m^3^ was associated with a LOAEL of 28.2 mg/m^3^ for hypersensitivity to touch and decreased thymus weight in female rats and hepatocellular hypertrophy in male and female rats exposed to chlordane technical by inhalation for 8 hours/day, 5 days/week, for 28 days. A 90-day repeated exposure study (8 hours/day, 5 days/week) identified a NOAEL of 0.1 mg/m^3^ and a LOAEL of 1.0 mg/m^3^ for hepatocellular hypertrophy, increased leukocytes, and decreased platelets in female rats. Altered follicular cell structure was noted in male rats exposed at 10 mg/m^3^. Among available intermediate-duration inhalation studies for chlordane technical, hepatocellular hypertrophy was the most common effect and occurred in male and female rats at the lowest LOAEL (1.0 mg/m^3^) and was therefore selected as the critical effect for deriving an intermediate-duration inhalation MRL for chlordane technical.

Selection of the Principal Study: No adverse effects were observed among monkeys following inhalation exposure to chlordane technical at 10 mg/m^3^ for 8 hours/day, 5 days/week for 90 days (Khasawinah et al. 1989; Velsicol Chemical Co. 1984). Two rat studies (a 28-day study and a 90-day study) evaluated the effects of repeated inhalation exposure to chlordane technical. The 90-day study identified the lowest LOAEL for liver effects and was selected as the principal study for deriving an intermediate-duration inhalation MRL for chlordane (Khasawinah et al. 1989; Velsicol Chemical Co. 1984).

Summary of the Principal Study:

Khasawinah AM, Hardy CJ, Clark GC. 1989. Comparative inhalation toxicity of technical chlordane in rats and monkeys. J Toxicol Environ Health 28:327–347.2585538

Velsicol Chemical Co. 1984. Chlordane: A 90-day inhalation toxicity study in the rat and monkey. Unpublished study No. VCL28 conducted by Huntingdon Research Centre . (cited in EPA 1987f).

Groups of Wistar rats (35–47/sex/group) were exposed to 0, 0.1, 1.0, or 10 mg/m^3^ technical chlordane for 8 hours/day, 5 days/week for 13 weeks, followed by a 13-week recovery period. Blood chemistry and urinalysis were performed prior to the beginning of exposure and at exposure weeks 5 and 13. Rats were sacrificed at 9 weeks (5/sex/group) and 13 weeks (15/sex/group). The remaining rats were sacrificed following 13 weeks of recovery. There were no exposure-related effects on mortality, clinical signs (with the exception of sensitivity to touch at the highest exposure level), food consumption, body weight, ophthalmoscopy, rectal temperature, or urinalysis. Exposure-related hematological changes (e.g., increases in total white blood cells, lymphocytes, neutrophils; decreases in hemoglobin and platelets) were of relatively small magnitude, occurred primarily in female rats, and values were within normal ranges for rats; therefore, these changes are not considered adverse. Exposure-related changes indicative of liver effects were observed at 1 mg/m^3^ and included increases serum P-450 activity, globulins, total protein, and cholesterol; and decreased albumin and albumin/globulin ratio. Histopathologic examinations revealed hepatocellular hypertrophy in all rats of the 10 mg/m^3^ exposure group and 5/15 males and 5/15 females of the 1 mg/m^3^ exposure group (compared to 0/15/sex/group at 0 or 0.1 mg/m^3^).

Selection of the Point of Departure for the MRL: The NOAEL of 0.1 mg/m^3^ was selected as the basis for the MRL.

Intermittent Exposure: The NOAEL was adjusted from intermittent exposure (8 hours/day, 5 days/week) to account for continuous exposure according to the following equation:

NOAEL_ADJ_ = NOAEL ( 0.1 mg / m^3^ ) × 8 hours / 24 hours × 5 days / 7 days = 0.024 mg / m^3.^

Human Equivalent Concentration: The duration-adjusted NOAEL_ADJ_ of 0.024 mg/m^3^ was converted to a human equivalent concentration (HEC) according to the equation used to calculate a HEC for extrarespiratory effects of a Category 3 gas (EPA 1994): NOAEL_HEC_ (mg/m^3^) = NOAEL_ADJ_ (mg/m^3^) × (H_b/g_)A/(H_b/g_)H (i.e., the ratio of the blood:gas [air] partition coefficient of the chemical for the laboratory animal species to the human value; the value of 1.0 is used when measured values are not available).

NOAEL_HEC_ = 0.024 mg / m^3^ × 1 = 0.024 mg / m^3^ .

Uncertainty Factor: The NOAEL_HEC_ was divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Liver effects were observed in the 28-day and 90-day rat studies (Khasawinah et al. 1989; Velsicol Chemical Co. 1984).

Agency Contact (Chemical Manager): Jennifer Przybyla

## Chlordane Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlordane
CAS Numbers: | 12789-03-6 (chlordane technical)
Date: | May 1994
| April 2017-Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic
MRL | 0.00002 mg/m^3^
Critical Effect: | Hepatocellular hypertrophy
Reference: | Khasawinah et al. 1989; Velsicol Chemical Co. 1984
Point of Departure: | NOAEL of 0.1 mg/m^3^
Uncertainty Factor: | 1,000
LSE Graph Key: | 3
Species: | Rat

MRL Summary: A chronic-duration inhalation MRL of 0.0002 mg/m^3^ was derived for chlordane technical. The MRL is based on a NOAEL of 0.1 mg/m^3^ and a LOAEL of 1.0 mg/m^3^ for hepatocellular hypertrophy in rats exposed to chlordane technical for 8 hours/day, 5 days/week for 90 days (Khasawinah et al. 1989; Velsicol Chemical Co. 1984). The NOAEL was adjusted for intermittent exposure, converted to a human equivalent concentration, and divided by an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: Intermediate-duration inhalation exposure data in rats have identified the hematological system, liver, central nervous system, thyroid, and possibly the thymus in female rats, as the target organs (Khasawinah et al. 1989; Velsicol Chemical Co. 1984). A NOAEL of 5.8 mg/m^3^ was associated with a LOAEL of 28.2 mg/m^3^ for hypersensitivity to touch and decreased thymus weight in female rats and hepatocellular hypertrophy in male and female rats exposed to chlordane technical by inhalation for 8 hours/day, 5 days/week, for 28 days. A 90-day repeated exposure study (8 hours/day, 5 days/week) identified a NOAEL of 0.1 mg/m^3^ and a LOAEL of 1.0 mg/m^3^ for hepatocellular hypertrophy, increased leukocytes, and decreased platelets in female rats. Altered follicular cell structure was noted in male rats exposed at 10 mg/m^3^. Among available intermediate-duration inhalation studies for chlordane technical, hepatocellular hypertrophy was the most common effect and occurred in male and female rats at the lowest LOAEL (1.0 mg/m^3^) and was therefore selected as the critical effect for deriving an intermediate-duration inhalation MRL for chlordane technical.

Selection of the Principal Study: No adverse effects were observed among monkeys following inhalation exposure to chlordane technical at 10 mg/m^3^ for 8 hours/day, 5 days/week for 90 days (Khasawinah et al. 1989; Velsicol Chemical Co. 1984). Two rat studies (a 28-day study and a 90-day study) evaluated the effects of repeated inhalation exposure to chlordane technical. The 90-day study identified the lowest LOAEL for liver effects and was selected as the principal study for deriving an intermediate-duration inhalation MRL for chlordane (Khasawinah et al. 1989; Velsicol Chemical Co. 1984).

Summary of the Principal Study:

Khasawinah AM, Hardy CJ, Clark GC. 1989. Comparative inhalation toxicity of technical chlordane in rats and monkeys. J Toxicol Environ Health 28:327–347.2585538

Velsicol Chemical Co. 1984. Chlordane: A 90-day inhalation toxicity study in the rat and monkey. Unpublished study No. VCL28 conducted by Huntingdon Research Centre . (cited in EPA 1987f).

Groups of Wistar rats (35–47/sex/group) were exposed to 0, 0.1, 1.0, or 10 mg/m^3^ technical chlordane for 8 hours/day, 5 days/week for 13 weeks, followed by a 13-week recovery period. Blood chemistry and urinalysis were performed prior to the beginning of exposure and at exposure weeks 5 and 13. Rats were sacrificed at 9 weeks (5/sex/group) and 13 weeks (15/sex/group). The remaining rats were sacrificed following 13 weeks of recovery. There were no exposure-related effects on mortality, clinical signs (with the exception of sensitivity to touch at the highest exposure level), food consumption, body weight, ophthalmoscopy, rectal temperature, or urinalysis. Exposure-related hematological changes (e.g., increases in total white blood cells, lymphocytes, neutrophils; decreases in hemoglobin and platelets) were of relatively small magnitude, occurred primarily in female rats, and values were within normal ranges for rats; therefore, these changes are not considered adverse. Exposure-related changes indicative of liver effects were observed at 1 mg/m^3^ and included increases serum P-450 activity, globulins, total protein, and cholesterol; and decreased albumin and albumin/globulin ratio. Histopathologic examinations revealed hepatocellular hypertrophy in all rats of the 10 mg/m^3^ exposure group and 5/15 males and 5/15 females of the 1 mg/m^3^ exposure group (compared to 0/15/sex/group at 0 or 0.1 mg/m^3^).

Selection of the Point of Departure for the MRL: The NOAEL of 0.1 mg/m^3^ was selected as the basis for the MRL.

Intermittent Exposure: The NOAEL was adjusted from intermittent exposure (8 hours/day, 5 days/week) to account for continuous exposure according to the following equation:

NOAEL_ADJ_ = NOAEL ( 0.1 mg / m^3^ ) × 8 hours / 24 hours × 5 days / 7 days = 0.024 mg / m^3.^

Human Equivalent Concentration: The duration-adjusted NOAEL_ADJ_ of 0.024 mg/m^3^ was converted to a human equivalent concentration (HEC) according to the equation used to calculate a HEC for extrarespiratory effects of a Category 3 gas (EPA 1994): NOAEL_HEC_ (mg/m^3^) = NOAEL_ADJ_ (mg/m^3^) × (H_b/g_)A/(H_b/g_)H (i.e., the ratio of the blood:gas [air] partition coefficient of the chemical for the laboratory animal species to the human value; the value of 1.0 is used when measured values are not available).

NOAEL_HEC_ = 0.024 mg / m^3^ × 1 = 0.024 mg / m^3^ .

Uncertainty Factor: The NOAEL_HEC_ was divided by a total uncertainty factor of 1000:

- 10 for extrapolation from intermediate-duration to chronic-duration exposure
- 10 for extrapolation from animals to humans
- 10 for human variability

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Liver effects were observed in the 28-day and 90-day rat studies (Khasawinah et al. 1989; Velsicol Chemical Co. 1984)

Agency Contact (Chemical Manager): Jennifer Przybyla

## Chlordane Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlordane
CAS Numbers: | 12789-03-6 (chlordane technical)
Date: | May 1994
| April 2017-Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL | 0.001 mg/kg/day
Critical Effect: | Developmental effects
Reference: | Al-Hachim and Al-Baker 1973
Point of Departure: | LOAEL of 1 mg/kg/day
Uncertainty Factor: | 1,000
LSE Graph Key: | 17
Species: | Mouse

MRL Summary: An acute-duration oral MRL of 0.001 mg/kg/day was derived for chlordane technical. The MRL is based on a LOAEL of 1 mg/kg/day for developmental effects (depressed conditioned avoidance response acquisition, increased exploratory activity in open field testing, and increased seizure threshold) in offspring of mice exposed to chlordane during the third trimester of gestation (7 days) (Al-Hachim and Al-Baker 1973). The LOAEL divided by an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: Acute oral data have identified the liver and the central nervous system as target organs in rats and mice; LOAELs range from 50 to 200 mg/kg/day (Ambrose et al. 1953a; Hrdina et al. 1974; Ogata and Izushi 1991; Truhaut et al. 1974, 1975). One oral study in mice identified the lowest LOAEL (1 mg/kg/day for developmental effects) associated with acute-duration oral exposure to chlordane technical (Al-Hachim and Al-Baker 1973). This study identified the lowest LOAEL; therefore, it serves as the critical effect for deriving an acute-duration oral MRL for chlordane technical.

Selection of the Principal Study: The study of Al-Hachim and Al-Baker (1973) was selected as the principal study because it provided the lowest LOAEL (1 mg/kg/day for developmental effects) among candidate acute-duration oral toxicity studies.

Summary of the Principal Study:

Al-Hachim GM, Al-Baker A. 1973. Effects of chlordane on conditioned avoidance response, brain seizure threshold and open-field performance of prentally-reated mice. Br J Pharmacol 49:311–315.4793333

Groups of pregnant albino mice (6/group) were administered technical-grade chlordane by gavage (in olive oil) for 7 days during the third trimester) at 0, 1, or 2.5 mg/kg/day. Ten mice/litter were tested for conditioned avoidance response during postnatal days 30–37. Electroshock seizure threshold was measured at 38 days of age, and open field testing was performed during postnatal weeks 6 and 7. Offspring exhibited significantly depressed conditioned avoidance response acquisition, increased exploratory activity in open field testing, and increased seizure threshold at the lowest maternal dose level (1 mg/kg/day).

Selection of the Point of Departure for the MRL: The LOAEL of 1 mg/kg/day was selected as the basis for the MRL.

Intermittent Exposure: Not applicable.

Human Equivalent Concentration: Not applicable.

Uncertainty Factor: The LOAEL was divided by a total uncertainty factor of 1,000:

- 10 for use of a LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = LOAEL ÷ UFs 1 mg / kg / day ÷ 1,000 = 0.001 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: No supporting study results.

Agency Contact (Chemical Manager): Jennifer Przybyla

## Chlordane Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlordane
CAS Numbers: | 12789-03-6 (chlordane technical)
Date: | May 1994
| April 2017-Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL | 0.0006 mg/kg/day
Critical Effect: | Liver effects
Reference: | EPA 1985a; Khasawinah and Grutsch 1989a
Point of Departure: | LOAEL of 0.055 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 47
Species: | Rat

MRL Summary: The chronic-duration oral MRL for chlordane technical was adopted as the intermediate-duration oral MRL as well. See the MRL Worksheet for the chronic-duration oral MRL for details regarding selection of the critical effect and principal study, summary of the principal study, selection of the point of departure for the MRL, and uncertainty factors.

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Centrilobular hypertrophy was also observed in rats receiving chlordane technical from the diet for up to 9 months at an estimated dose of 0.125 mg/kg/day, the lowest dose tested (Ortega et al. 1957).

Agency Contact (Chemical Manager): Jennifer Przybyla

## Chlordane Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlordane
CAS Numbers: | 12789-03-6 (chlordane technical)
Date: | May 1994
| April 2017-Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL | 0.0006 mg/kg/day
Critical Effect: | Hepatocellular hypertrophy
Reference: | EPA 1985a; Khasawinah and Grutsch 1989a
Point of Departure: | NOAEL of 0.055 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 47
Species: | Rat

MRL Summary: A chronic-duration oral MRL of 0.0006 mg/kg/day was derived for chlordane technical. The MRL is based on a NOAEL of 0.055 mg/kg/day and a LOAEL of 0.237 mg/kg/day for hepatocellular hypertrophy in female rats administered chlordane technical in the diet for 30 months (EPA 1985a; Khasawinah and Grutsch 1989a). The NOAEL was divided by an uncertainty factor of 100 (10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: Among available chronic-duration oral animal studies for chlordane technical, targets of toxicity include the liver and body weight (Ambrose et al. 1953; EPA 1985a; Khasawinah and Grutsch 1989a). Body weight effects were observed at 16 mg/kg/day (Ambrose et al. 1953), whereas hepatocellular hypertrophy was noted in rats at doses as low as 0.273 mg/kg/day in one rat study (EPA 1985a; Khasawinah and Grutsch 1989a) and 4 mg/kg/day in another rat study (Ambrose et al. 1953). Hepatocellular hypertrophy was also noted in male and female mice at 0.47 mg/kg/day, with a corresponding NOAEL of 0.1 mg/kg/day (EPA 1985a; Khasawinah and Grutsch 1989a). NCI (1977) reported neurological effects in rats and mice administered analytical-grade chlordane in the diet at estimated doses of 7.3–12.1 mg/kg/day (corresponding NOAELs were 3.9 and 6.0 mg/kg/day for rats and mice, respectively). Among available chronic-duration oral animal data, the most sensitive effect is hepatocellular hypertrophy, which was selected as the critical effect for deriving a chronic-duration oral MRL for chlordane technical.

Selection of the Principal Study: Treatment-related liver effects were associated with chronic-duration oral exposure to chlordane technical in rats (Ambrose et al. 1953; Khasawinah and Grutsch 1989a) and mice (Khasawinah and Grutsch 1989a). The study reports that reported the lowest LOAEL for liver effects (0.273 mg/kg/day in female rats) and corresponding NOAEL (0.055 mg/kg/day in female rats) were selected to represent the principal study for deriving a chronic-duration oral MRL for chlordane technical.

Summary of the Principal Study:

EPA. 1985a. Memorandum. 6(a)(2) Data on chlordane. Chronic mouse and rat studies for oncogenicity testing. Act. Nos. 252267, 254665, 251815, Review No. 004635. Office of Pesticides and Toxic Substances, Washington, DC.

Khasawinah AM, Grutsch JF. 1989a. Chlordane thirty-month tumorigenicity and chronic toxicity test in rats. Regul Toxicol Pharmacol 10:95–109.2813873

Groups of Fischer 344 rats (80/sex/group) were administered chlordane technical in the diet for up to 30 months at 0, 1, 5, or 25 ppm (author-calculated doses of 0, 0.045, 0.229, and 1.175 mg/kg/day, respectively, for males and 0, 0.055, 0.273, and 1.409 mg/kg/day, respectively, for females). The only reported treatment-related nonneoplastic effect was that of hepatocellular hypertrophy in females at 0.273 mg/kg/day. There were no apparent treatment-related effects on respiratory, cardiovascular, gastrointestinal, hematological, musculoskeletal, or renal systems, or dermal/ocular or body weight effects at the highest dose tested (1.175 and 1.409 mg/kg/day for males and females, respectively).

Selection of the Point of Departure for the MRL: The NOAEL of 0.055 mg/kg/day for female rats was selected as the basis for the MRL.

Uncertainty Factor: The NOAEL was divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = NOAEL ÷ UFs 0.055 mg / kg / day ÷ 100 = 0.0006 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Hepatocellular hypertrophy was also observed in male and female mice orally exposed to chlordane technical for 24 months at 0.47 mg/kg/day; the corresponding NOAEL was 0.10 mg/kg/day (EPA 1985a; Khasawinah and Grutsch 1989a).

Agency Contact (Chemical Manager): Jennifer Przybyla