# 9 REFERENCES

*Cited in text

Aage HK, Korsbech U, Bargholz K, . 1999. A new technique for processing airborne gamma ray spectrometry data for mapping low level contaminations. Appl Radiat Isot 51:651–662.10581680
Aarkrog A. 1994. Doses from the Chernobyl accident to the nordic populations. In: Dahlgaard H, ed. Studies in environmental science. Nordic radioecology: The transfer of radionuclides through nordic ecosystems to man. Vol. 62. New York, NY: Elsevier Science Publishers, 433–456.
Aarkrog A, Baxter MS, Bettencourt AO, . 1997. A comparison of doses from ^137^Cs and ^210^Po in marine food: A major international study. J Environ Radioact 34(1):69–90.
Abdul-Majid S, Abulfaraj W. 1992. Radioactivity concentration in soil in Jeddah area, Saudi Arabia. J Environ Sci Health Part A 27(1):105–116.
*Abdul-Majid S, Abdul-Fattah A, Abulfaraj WH. 1992. Radiation dose assessment from ingestion pathway in Saudi Arabia. J Environ Sci Health A27(4):1045–1057.
*ACGIH. 2000. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*ACGIH. 2001. Cesium hydroxide. Documentation of the threshold limit values for chemical substances.
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Agency for Toxic Substance Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles: Notice. Agency for Toxic Substances and Disease Registry. Federal Register 54(174):37618–37634.
*Agency for Toxic Substance Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Atlanta, GA: Subcommittee on Biomarkers of Organ Damage and Dysfunction. Agency for Toxic Substances and Disease Registry.
*Agency for Toxic Substance Disease Registry. 1999. Toxicological profile for ionizing radiation. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Ahman B. 1994. Body burden and distribution of ^137^Cs in reindeer. Rangifer 14(1):23–28.
*Ahman B, Ahman G. 1994. Radiocesium in Swedish reindeer after the Chernobyl fallout: Seasonal variations and long-term decline. Health Phys 66(5):503–512.8175357
*Ahmad S, Waheed S, Mannan A, . 1994. Evaluation of trace elements in wheat and wheat by-products. J AOAC Int 77(1):11–18.
*Ajdacic N, Martic M. 1990. Radionuclides in the ground layer of air. J Radioanal Nucl Chem 140(2):295–300.
Albinsson Y, Engkvist I. 1989. Diffusion of americium, plutonium, uranium, neptunium, cesium, iodine and technetium in compacted sand-bentonite mixture. Goeteborg, Sweden: Chalmers University of Technology, Department of Nuclear Chemistry. SKB Tech. Rep. 89-22.
Al`Ferovich AA, Gotlib VYA, Pelevina II. 1996. Appearance of micronuclei in generation of hela cells irradiated at low doses. Izv Akad Nauk SSSR Ser Biol 3:261–264.
*Allaye-Chan AC, White RG, Holleman DF, . 1990. Seasonal concentrations of cesium-137 in rumen content, skeletal muscles and feces of caribou from the porcupine herd: lichen ingestion rates and implications for human consumption. Rangifer 3:17–24.
Allott RW, Kelly M, Hewitt CN. 1992. Behavior of urban dust contaminated by Chernobyl fallout: environmental half-lives and transfer coefficients. Environ Sci Technol 26:2142–2147.
Al-Sabati K. 1992. Monitoring the genotoxicity of radiocontaminants in Swedish lakes by fish micronuclei. Cytobios 70:101–106.1451530
*Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Ames M, Gullu G, Olmez I. 1998. Atmospheric mercury in the vapor phase, and in fine and course particulate matter at Perch River, New York. Atmos Environ 32(5):865–872.
Amiro BD, Sheppard SC, Johnston FL, . 1996. Burning radionuclide question: What happens to iodine, cesium and chlorine in biomass fires? Sci Total Environ 187:93–103.8766727
*Amundsen I, Iosijp M, Reistad O, . 2002. The accidental sinking of the nuclear submarine, the Kursk: monitoring of radioactivity and the preliminary assessment of the potential impact of radioactive releases. Mar Pollut Bull 44(6):459–468.12146829
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
*Anderson P, Davidson CM, Littlejohn D, . 1996. The determination of caesium and silver in soil and fungla fruiting bodies by electrothermal atomic absorption spectrometry. Anal Chim Acta 327:53–60.
Anderson SH, Dodson GJ, Van Hook RI. 1976. Comparative retention of ^60^Co, ^109^Cd and ^137^Cs following acute and chronic feeding in bobwhite quail. In: Radioecology and energy resources. Oakridge, TN: Environmental Science Division. Vol. 1. Oak Ridge National Laboratory, 321–324.
Andersson I, Hansson I. 1989. Distribution of ^137^Cs to different muscles and internal organs of lambs fed contaminated hay. Swed J Agric Res 19:93–98.
Andersson I, Hakansson J, Anner K. 1990. Transfer of ^137^Cs from grain to muscle and internal organs of growing finishing pigs, and the effect of feeding bentonite. Swed J Agric Res 20:43–48.
Anisimov VN, Miretskii GI, Morozov VG, . 1992. The effect of synthetic immunomodulator thymogen on radiation carcinogenesis in rats. Vopr Onkol 38:481–488.
*APHA. 1998. 7120 Gamma-emitting radionuclides. Standard methods for the examination of water and wastewater, 20^th^ ed. Washington, DC: American Public Health Association.
*Arnalds O, Cutshall NH, Nielsen GA. 1989. Cesium-137 in Montana soils. Health Phys 57:955–958.2584030
*Arslan NC, Geard CR, Hall EJ. 1986. Low dose-rate effects of cesium-137 and iodine-125 on cell survival, cell progression, and chromosomal alterations. Am J Clin Oncol 9(2):114–115.
Ashwood TL, Olsen CR. 1988. Pearl Harbor bombing attack: A contamination legacy revealed in the sedimentary record. Mar Pollut Bull 19(2):68–71.
Askbrant S, Melin J, Sandalls J, . 1996. Mobility of radionuclides in undisturbed and cultivated soils in Ukraine, Belarus and Russia six years after the Chernobyl fallout. J Environ Radioact 31(3):287–312.
Assimakopoulos PA, Ioannides KG, Pakou AA, . 1993. Transport of radiocaesium from a sheep’s diet to its tissues. Sci Total Environ 136:1–11.8211104
Astakhova LN, Anspaugh LR, Beebe GW, . 1998. Chernobyl-related thyroid cancer in children of Belarus: A case-control study. Radiat Res 150:349–356.9728663
Astakhova LN, Demidchik EP, Kasakov VS, . 1993. Thyroid cancer in children of the Belarus Republic after the Chernobyl accident: Publisher’s summary. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc, 425–427.
*ASTM. 1999. Annual book of ASTM standards, Vol. 11.02. Philadelphia, PA: American Society for Testing of Materials. ASTM, 290–300.
*Asubiojo OI, Nkono NA, Ogunsua AO, . 1997. Trace elements in drinking and groundwater samples in southern Nigeria. Sci Total Environ 208:1–8.9496643
Baeza A, del Rio M, Miro C, . 1999. Recent evolution of the multi-isotopic radioactive content in ice of Livingston Island, Antarctica. Bull Environ Contam Toxicol 63:139–149.10441629
Baker CE, Dunaway PB. 1969. Retention of ^134^Cs as an index to metabolism in the cotton rat (Sigmodon hispidus). Health Phys 16:227–230.5772187
*Balasem AN, Ali ASK. 1991. Establishment of dose-response relationships between doses of Cs-137 γ-rays and frequencies of micronuclei in human peripheral blood lymphocytes. Mutat Res 259:133–138.1994244
Balduini W, Costa LG, Murphy SD. 1990. Potassium ions potentiate the muscarinic receptor-stimulated phosphoinositide metabolism in cerebral cortex slices: A comparison of neonatal and adult rats. Neurochem Res 15(1):33–39.2157990
*Balonov MI. 1993. Overview of doses to the Soviet population from the Chernobyl accident and the protective actions applied. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc., 23–45.
Balonov MI, Travnikova IG. 1993. Importance of diet and protective actions on internal dose from Cs radionuclides in inhabitants of the Chernobyl region. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc., 127–166.
*Bangh S, Houlihan R, Anderson D, . 2001. Prolonged QT and polymorphic VT with chronic cesium use. J Toxicol Clin Toxicol 39(5):556.
*Baratta EJ, Apidianakis JC, Ferri ES. 1969. Cesium-137, lead-210 and polonium-210 concentrations in selected human tissues in the United States. Am Ind Hyg Assoc J 30:443–448.5823424
Bard D, Verger P, Hubert P. 1997. Chernobyl, 10 years after: Health consequences. Epidemiol Rev 19(2):187–204.9494782
*Barnaby CF, Smith T. 1971. Calibration of a whole-body counter suitable for use in routine clinical investigations. Phys Med Biol 16:97–104.4996246
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Barrie LA, Gregor D, Hargrave B, . 1992. Arctic contaminants: sources, occurrence and pathways. Sci Total Environ 122:1–74.1514103
Barry SF. 1988. Epidemiology in occupational radiation exposure. Radiat Prot Dosim 25:85–92.
*Bartstra RW, Bentvelzen PAJ, Zoetelief J, . 1998. Induction of mammary tumors in rats by single-dose gamma irradiation at different ages. Radiat Res 150:442–450.9768859
Baryakhtar V, Poyarkov V, Kholosha V, . 2000. The accident. In: Vargo GJ, ed. The Chernobyl accident. Columbus, OH: Batelle Press.
*Beaugelin-Seiller K, Baudin JP, Brottet D. 1994. Use of aquatic mosses for monitoring artificial radionuclides downstream of the nuclear power plant of Bugey (River Rhone, France). J Environ Radioact 24:217–233.
*Beck HL, Krey PW. 1983. Radiation exposures in Utah from Nevada nuclear tests. Science 220:18–24.6828876
*Becker PR, Mackey EA, Demiralp R, . 1997. Concentrations of chlorinated hydrocarbons and trace elements in marine mammal tissues archived in the U.S. National Biomonitoring Specimen Bank. Chemosphere 34(9/10):2067–2098.9159906
Begovic J, Stankovic S, Mitrovic R. 1980. Dynamics of Cs-137 distribution in the muscle tissue of swine by single and repeated contamination. In: Radiation protection: A systematic approach to safety: Proceedings of the 5^th^ Congress of the International Radiation Protection Society, Jerusalem, March 1980. Vol. 2. New York, NY: Pergamon Press, 1029–1142.
Behne D, Gebner H. 1987. Effects of dietary K in the absorption and excretion of radiocesium in the rat. Health Phys 53(3):331–332.
*BEIR V. 1990. Health effects of exposure to low levels of ionizing radiation. In: Health effects of exposure to low level levels of ionizing radiation. Washington, DC: National Academy Press.
*Bengtsson LG, Haversten Y, Svvensson KG. 1964. Maternal and infantile metabolism of cesium. In: Assessment of radioactivity in man. Vol. II, Vienna: International Atomic Energy Agency, 21–32.
Benjamin SA, Boecker BB, Chiffelle TL, . 1973. Neoplasia in beagle dogs after inhalation of ^144^CeCl_3_. In: United States atomic energy commission symposium series. Vol 29. Springfield, VA: U.S. Atomic Energy Commision, 181–200.
Benjamin SA, Boecker BB, Cuddihy RG, . 1979. Nasal carcinomas in beagles after inhalation of relatively soluble forms of beta-emitting radionuclides. J Natl Cancer Inst 63(1):133–139.286823
Benjamin SA, Hahn FF, Chiffelle TL, . 1975. Occurrence of hemangiosarcomas in beagles with internally deposited radionuclides. Cancer Res 35:1745–1755.1169116
Benoit G, Rozan TF, Patton PC, . 1999. Trace metals and radionuclides reveal sediment sources ans accumulation rates in Jordan Cove, Connecticut. Estuaries 22(1):65–80.
Berg D, Kollmer WE, Kriegel H, . 1987. Radioactive iodine and cesium in Bavarian citizens after the nuclear reactor accident in Chernobyl. Trace Subst Environ Health 21:219–225.
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
Berger ME, Hurtado R, Dunlap J, . 1997. Accidental radiation injury to the hand: Anatomical and physiological considerations. Health Phys 72(3):343–348.9030835
*Bermejo-Barrera P, Beceiro-Gonzalez E, Bermejo-Barrera A, . 1989. Determination of cesium in mineral and thermal waters by electrothermal atomic absorption spectrophotometry. Microchem J 40:103–108.
*Betti M, Giannarelli S, Hiernaut T, . 1996. Detection of trace radioisotopes in soil, sediment and vegetation by glow discharge mass spectrometry. Fresenius J Anal Chem 355:642–646.
Bettinelli M, Baffi C, Beone GM, . 2000. Soils and sediments analysis by spectroscopic techniques part II: Determination of trace elements by ICP-MS. Atom Spectrosc 21(2):60–70.
Beukema AA, Hekstra GP, Venema C. 1986. The Netherlands’ environmental policy for the North Sea and Wadden Sea. Environ Monit Assess 7:117–155.24254829
*Bhat IS, Hedge AG, Chandramouli S, . 1973. Evaluation of internal exposure to radionuclides of I, Cs, and Co, during maintenance operations on primary steam leak in a nuclear power station. Health Phys 25:135–139.4206136
*Bibak A, Behrens A, Sturup S, . 1998. Concentrations of 63 major and trace elements in Danish agricultural crops measured by inductively coupled plasma mass spectrometry. Onion (Allium cepa Hysam). J Agric Food Chem 46:3139–3145.
*Biedermann KA, Sun J, Giaccia AJ, . 1991. Acid mutation in mice confers hypersensitivity to ionizing radiation and deficiency DNA double-strand break repair. Proc Natl Acad Sci USA 88:1394–1397.1996340
Bird GA, Hesslein RH, Mills KH, . 1998. Bioaccumulation of radionuclides in fertilized Canadian Shield Lake basins. Sci Total Environ 218:67–83.9718743
*Blatz AL, Magleby KL. 1984. Ion conductance and selectivity of single calcium-activated potassium in cultured rat muscles. J Gen Physiol 84:1–23.6086805
*Boecker BB. 1969a. Comparison of ^137^Cs metabolism in the beagle dog following inhalation and intravenous injection. Health Phys 16(6):785–788.5795271
*Boecker BB. 1969b. The metabolism of ^137^Cs inhaled as ^137^CsCl by the beagle dog. Proc Soc Exp Biol Med 130(3):966–971.5773699
Boecker BB. 1972. Toxicity of ^137^CsCl in the beagle: Metabolism and dosimetry. Radiat Res 50:556–573.4624034
Boecker BB, McClellan RO, Scott JK. 1969a. Retention and distribution of ^137^Cs in the beagle dog following inhalation of ^137^Cs in fused montmorillonite clay particles. In: Fission Product Inhalation Program, ed. Fission product inhalation program annual report 1968-69. Albuquerque, NM: Lovelace Foundation for Medical Research and Education, 105–110.
Boecker BB, Redman HC, Chiffelle TL, . 1969b. Toxicity of inhaled ^137^CsCl in the beagle dog. II. In: Fission Product Inhalation Program, ed. Fission product inhalation program annual report 1968-69. Albuquerque, NM: Lovelace Foundation for Medical Research and Education, 36–54.
*Boecker BB, Thomas RG, McClellan RO. 1974. Retention patterns in beagle dogs repeatedly exposed to aerosols of ^137^Cs-labeled fused clay particles. II. In: Inhalation Toxicology Research Institute, ed. Annual report of the Inhalation Toxicology Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 318–321.
*Boecker BB, Thomas RG, McClellan RO. 1977. Accumulation and retention of ^137^Cs-labelled fused aluminosilicate particles by beagle dogs after repeated inhalation exposures. In: Inhaled particles IV: proceedings of an international symposium. Vol. 1. New York, NY: Pergamon Press, 221–237.
*Bonatti V, Rolli A, Botti G. 1983. Recording of nonphasic action potentials of the right ventricle in long QT syndromes complicated by severe ventricular arrhythmias. Eur Heart J 4:168–179.6190653
*Boni AL. 1966. Rapid ion exchange analysis of radiocesium in milk, urine, sea water, and environmental samples. Anal Chem 38:89–92.5900772
Boni AL. 1969a. Organ specific inhibitor of mitosis in the amphibian kidney. Nature 222:1189.5788990
*Boni AL. 1969b. Variations in the retention and excretion of ^137^Cs with age and sex. Nature 222:1188–1189.5796001
Borovec J. 1995. Changes in incidence of carcinoma in situ after the Chernobyl disaster in central Europe. Arch Environ Contam Toxicol 29:266–269.7661631
Borzilov VA, Klepikova NV. 1993. Effect of meteorological conditions and release composition on radionuclide deposition after the Chernobyl accident. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc., 47–68.
*Bose R, Pinsky C. 1981. Cesium impairs conditioned avoidance response (CAR) in mice and rats. Proc Can Fed Biol Soc 24:101.
Bose R, Pinsky C. 1983a. Antipsychotic effects of cesium are suggested by mutual synergism between cesium chloride, chlorpromazine and haloperidol on conditioned avoidance response in mice. Res Commun Psychol Psychiatr Behav 8(4):317–329.
*Bose R, Pinsky C. 1983b. Cesium attenuates conditioned avoidance response in rats and mice. Pharmacol Biochem Behav 18:867–871.6889415
*Bose R, Pinsky C. 1984. Central depressant action of cesium in mice. Psychopharmacology 84:80–84.6436894
*Bose R, Pinsky C, Jasper SC, . 1981. Cesium on acquisition of conditioned avoidance response (CAR) and motor behavior in mice. Pharmacologist 23:151.
*Brachmann J, Scherlag BJ, Rosenshtraukh LV, . 1983. Bradycardia-dependent triggered activity: relevance to drug-induced multiform ventricular tachycardia. Circulation 68(4):846–856.6616779
Bramham J, Riddell FG. 1994. Cesium uptake studies on human erythrocytes. J Inorg Biochem 53:169–176.8133253
*Brandão-Mello CE, Oliveira AR, Valverde NJ, . 1991. Clinical and hematological aspects of ^137^Cs: The Goiania radiation accident. Health Phys 60(1):31–39.1983978
Bretfeld G, Muth H, Oberhausen E. 1968. Organspezifische Caesium 137-aufnahme bei Ratten. Biophysik 4:343–355.5663927
Brewer AK. 1984. The high pH therapy for cancer tests on mice and humans. Pharmacol Biochem Behav 21(Suppl. 1):1–5.
Brogger A, Reitan JB, Strand P, . 1996. Chromosome analysis of peripheral lymphocytes from persons exposed to radioactive fallout in Norway from the Chernobyl accident. Mutat Res 361:73–79.8980691
*Brown JE, McDonald P, Parker A, . 1999. The vertical distribution of radionuclides in a Ribble Estuary saltmarsh: transport and deposition of radionuclides. J Environ Radioact 43:259–275.
Browning E. 1969. Toxicity of industrial metals. 2nd ed., Butterworths: London.
Brunn H, Georgii S, Eskens U. 1993. ^137^Cesium and ^134^cesium in roe deer from north and middle Hesse (Germany) subsequent to the reactor accident in Chernobyl. Bull Environ Contam Toxicol 51:633–639.8241617
Brynildsen LI, Selnaes TD, Strand P, . 1996. Countermeasures for radiocesium in animal products in Norway after the Chernobyl accident - techniques, effectiveness, and costs. Health Phys 70(5):665–672.8690577
*Bunzl K, Schimmack W. 1989. Associations between the fluctuations of the distribution coefficients of Cs, Zn, Sr, Co, Cd, Ce, Ru, Tc and I in the upper two horizons of a podzol forest soil. Chemosphere 18:2109–2120.
Burrows BA, Chalmers TC. 1990. Cesium-137/potassium-40 ratios in firewood ashes as a reflection of worldwide radioactive contamination of the environment. Ann N Y Acad Sci 609:334–339.
Burruel VR, Raabe OG, Wiley LM. 1997. In vitro fertilization rate of mouse oocytes with spermatozoa from the F1 offspring of males irradiated with 1.0 Gy ^137^Cs γ-rays. Mutat Res 381:59–66.9403031
*Burt C. 1966. The genetic determination of differences in intelligence: A study of monozygotic twins reared together and apart. Br J Psychol 57(1+2):137–153.
*Burt RO. 1993. Cesium and cesium compounds. In: Kroschwitz JI, Howe-Grant M, eds., Kirk-Othmer encyclopedia of chemical technology. 4^th^ ed. Vol 5. New York: John Wiley & Sons, 749–764.
*Buzulukov YP, Dobrynin YL. 1993. Release of radionuclides during the Chernobyl accident. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc, 3–21.
*Cahill DF, Wheeler JK. 1968. The biological half-life of cesium-137 in children determined by urinary assay. Health Phys 14:293–297.5689358
*Capar SG, Cunningham WC. 2000. Element and radionuclide concentrations in food: FDA total diet study 1991-1996. J AOAC Int 83(1):157–177.
Capra E, Drigo A, Menin A. 1989. Cesium-137 urinary excretion by northeastern (pordenone) Italian people following the Chernobyl nuclear accident. Health Phys 57(1):99–106.2745102
Castronovo FP. 1999. Teratogen update: Radiation and Chernobyl. Teratology 60:100–106.10440782
Caywood K, Ice R, Hertel N. 1997. Biokinetic model for ^137^Cs in the fetus. Health Phys 73(5):736–746.9378649
*CDC. 2001. National report on human exposure to environmental chemicals. Atlanta, GA: National Center for Environmental Health: Centers for Disease Control and Prevention.
*CDC. 2003. National report on human exposure to environmental chemicals. Atlanta, GA: National Center for Environmental Health: Centers for Disease Control and Prevention.
*Cecchi X, Wolff D, Alvarez O, . 1987. Mechanisms of Cs+ blockade in a Ca2+ -activated K+ channel from smooth muscle. Biophys J 52:707–716.2447963
*Cereijido M, Meza I, Martinez-Palmo A. 1981. Occluding junctions in cultured epithelial monolayers. Am J Physiol 240:C96–C102.7212057
Chaplygin VI, Zorov NB, Kuzyakov YY. 1983. Laser atomic-ionization determination of caesium in flames. Talanta 30(7):505–508.18963406
Chernyshov VP, Vykhovanets EV, Slukvin II, . 1997. Analysis of blood lymphocyte subsets in children living on territory that received high amounts of fallout of Chernobyl accident. Clin Immunol Immunopathol 84(2):122–128.9245542
Cherouati DE, Djeffal S. 1988. Measurements of radon and radon daughters in dwellings in Algiers. Radiat Prot Dosim 25:137–139.
Chesnokov AV, Fedin VI, Govorun AP, . 1997. Collimated detector technique for measuring a ^137^Cs deposit in soil under a clean protected layer. Appl Radiat Isot 48:1265–1272.9418213
Chiasson AG. 1990. Interference in determination of rubidium and cesium in fish and zooplankton by graphite furnace atomic absorption spectrometry. J Chem Ecol 16(8):2503–2510.24264215
*Chiavarini S, Galletti M, Michetti I, . 1994. Environmental monitoring at Terra Nova Bay Station from 1989-1991. Int J Environ Anal Chem 55:331–340.
Chibowski S, Mitura A. 1995. Studies of the rate of migration of radiocesium in some types of soils of Eastern Poland. Sci Total Environ 170:193–198.
Chillrud SN, Bopp RF, Simpson HJ, . 1999. Twentieth century atmospheric metal fluxes into Central Park Lake, New York City. Environ Sci Technol 33(5):657–662.21850150
*Chutke NT, Ambulkar MN, Garg AN. 1995. An environmental pollution study from multielemental analysis of pedestrian dust in Nagpur City, Central India. Sci Total Environ 164:185–194.
Clemente GF, Mariani A, Santaroni GP. 1971. Sex differences in Cs metabolism in man. Health Phys 21:709–711.5112183
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cochran KW, Doull J, Mazur M, . 1950. Acute toxicity of zirconium, columbium, strontium, lanthanum, cesium, tantalum and yttrium. Arch Ind Hyg Occup Med 1:637–650.15433507
Coquery M, Carvalho FP, Azemard S, . 2000. Certification of trace and major elements and methylmercury concentrations in a macroalgae (fucus sp.) reference material, IAEA-140. Fresenius J Anal Chem 366:792–801.11227410
Cornelis R, Speecke A, Hoste J. 1975. Neutron activation analysis for bulk and trace elements in urine. Anal Chim Acta 78:317–327.1166961
*Coronado R, Rosenberg RI, Miller C. 1980. Ionic selectivity, saturation, and block in a K^+^- selective channel from sarcoplasmic reticulum. J Gen Physiol 76:425–446.6255062
Cristaldi M, D’Arcangelo ED, Ieradi LA, . 1990. ^137^Cs determination and mutagenicity tests in wild Mus musculus domesticus before and after the Chernobyl accident. Environ Pollut 64:1–9.
Cristaldi M, Ieradi LA, Mascanzoni D, . 1991. Environmental impact of the Chernobyl accident: mutagenesis in bank voles from Sweden. Int J Radiat Biol 59(1):31–40.1671073
Croudace IW, Cundy AB. 1995. Heavy metal and hydrocarbon pollution in recent sediments from Southampton water, Southern England: A geochemical and isotopic study. Environ Sci Technol 29:1288–1296.22192024
Cryer MA, Baverstock KF. 1972. Biological half-life of ^137^Cs in man. Health Phys 23(3):394–395.4642964
Cuddihy RG, Ozog JA. 1973. Nasal absorption of CsCl, SrCl_2_, BaCl_2_, CeCl_2_ in Syrian hamsters. Health Phys 25:219–224.4785408
Cuddihy RG, Finch GL, Newton GJ, . 1989. Characteristics of radioactive particles released from the Chernobyl nuclear reactor. Environ Sci Technol 23:89–95.
*Cukierman S, Yellen G, Miller C. 1985. The K^+^ channel of sarcoplasmic reticulum. A new look at Cs^+^ block. Biophys J 48:477–484.2412606
Cunningham WC, Anderson DL, Baratta EJ. 1994. Radionuclides in domestic and imported foods in the United States, 1987-1992. J AOAC Int 77(6):1422–1427.7819751
Cunningham WC, Stroube WB, Baratta EJ. 1989. Chemical contaminants monitoring: Radionuclides in domestic and imported foods in the United States, 1983-1986. J Assoc Off Anal Chem 72(1):15–18.2715131
Daburan F, Fayart G, Tricaud Y. 1989. Caesium and iodine metabolism in lactating cows under chronic administration. Sci Total Environ 85:253–261.2814453
da Cruz AD, Glickman BW. 1997. Nature of mutation in the human hprt gene following in vivo exposure to ionizing radiation of cesium-137. Environ Mol Mutagen 30:385–395.9435879
da Cruz AD, Curado MP, Glickman BW. 1995. The spectrum of mutation of the hprt gene in human T-lymphocytes following in vivo exposure to ionizing radiation of cesium-137. Environ Mol Mutagen 25(Suppl. 25):10.
da Cruz AD, Curry J, Curado MP, . 1996. Monitoring hprt mutant frequency over time in T-lymphocytes of people accidentally exposed to high doses of ionizing radiation. Environ Mol Mutagen 27:165–175.8625952
da Cruz AD, McArthur AG, Silva CC, . 1994. Human micronucleus counts are correlated with age, smoking, and cesium137 dose in the Goiania (Brazil) radiological accident. Mutat Res 313:57–68.7519311
Dam K, Bankl H, Mostbeck A. 1988. Radiocesium incorporation in 250 patients deceased within the year following the Chernobyl disaster. Wien Klin Wochenschr 100(7):193–197.3376478
Danetskaya EV, Ershova VP, Ushakova AP, . 1970. [The effect of protein content on ^137^Cs incorporation and resistance of the organism to chronic internal irradiation.] Med Radiol 15(12):25–30. (Russian)
Dang HS, Jaiswal DD, Sharma RC, . 1995. Studies on the biological half-lives of three important radionuclides released in nuclear power reactor operations. Health Phys 69(3):400–402.7635738
Das HA, Comans RNJ. 1990. On the limits of low level measurements of ^137^Cs as a natural radiotracer. J Radioanal Nucl Chem 139(2):287–295.
*Dasch JM, Wolff GT. 1989. Trace inorganic species in precipitation and their potential use in source apportionment studies. Water Air Soil Pollut 43:401–412.
Densmore CL, Luyyge WG, Emadian SM. 1984. Effects of metal ions and chelating agents on in vitro stability of glucocorticoid receptors in brain cytosol. Life Sci 35:2237–2246.6438426
DeVita R, Olivieri A, Spinelli A, . 2000. Health status and internal radiocontamination assessment in children exposed to the fallout of the Chernobyl accident. Arch Environ Health 55(3):181–186.10908101
DeWoody JA. 1999. Nucleotide variation in the p53 tumor-suppressor gene of voles from Chernobyl, Ukraine. Mutat Res 439:25–36.10029670
Dierickx PJ. 1980. Urinary gamma-glutamyl transferase as a specific marker for mercury after heavy metal treatment of rats. Toxicol Lett 6:235–238.6106975
Ding-Hua F, Qi-Jun C. 1998. Study on accumulation of ^137^Cs in aquatic organisms. Nucl Sci Tech 9(3):184–185.
Dinter H, Pang J, Tesch K. 1988. Calculations of doses due to electron-photon stray radiation from a high energy electron beam behind lateral shielding. Radiat Prot Dosim 25:127–131.
Diomond ML, Mackay D, Cornett RJ, . 1990. A model of the exchange of inorganic chemicals between water and sediments. Environ Sci Technol 24:713–722.
*Djingova R, Wagner G, Peshev D. 1995. Heavy metal distribution in Bulgaria using Populus nigra ‘Italica’ as a biomonitor. Sci Total Environ 172:151–158.
*DOE. 1986. A compendium of the environmental measurements laboratory’s research projects related to the Chernobyl nuclear accident. New York, NY: Environmental Measurements Laboratory. U.S. Department of Energy. EML-460. DE87-001847.
*DOE. 1992. Chemical contaminants on DOE lands and selection of contaminant mixtures for subsurface science research. Washington, DC: U.S. Department of Energy. DE92-014826.
*DOE. 1996a. Closing the circle on the splitting of the atom: The environmental legacy of nuclear weapons production in the United States and what the department of energy is doing about it. Washington, DC: Office of Environmental Management. U.S. Department of Energy. DOE/EM-0266.
*DOE. 1996b. Selected radionuclides important to low-level radioactive waste management: National low-level waste management program. U.S. Department of Energy. DOE/LLW-238.
*DOE. 1998a. Heavy element radionuclides (Pu, Np, U) and ^137^Cs in soils collected from the Idaho national engineering and environmental laboratory and other sites in Idaho, Montana, and Wyoming. New York, NY: Environmental Measurements Laboratory. U.S. Department of Energy. EML-599.
*DOE. 1998b. Savannah river site environmental report for 1998. Aiken, SC: U.S. Department of Energy. WSRC-TR-98-00312. DE-ACO9-96SR18500.
*Doggett NA, McKenzie WH. 1983. An analysis of the distribution and dose response of chromosome aberrations in human lymphocytes after in vitro exposure to ^137^cesium gamma radiation. Radiat Environ Biophys 22:33–51.6611844
Dokiya T, Wada T, Shi-Long L, . 1978. Effect of single irradiation by Californium-252 compared with that of cesium-137 on skins of C3H mice. Nippon Igaku Hoshasen Gakkai Zasshi 38(6):570–576.693270
*Dombovári J, Becker JS, Kuhn AJ, . 2000. Multielement analysis of small plant tissue samples using inductively coupled plasma mass spectrometry. Atom Spectrosc 21(2):37–41.
Domby AH, Paine D, McFarlane RW. 1977. Radiocesium dynamics in herons inhabiting a contaminated reservoir system. Health Phys 33:523–532.604295
*Dreizen S, Levy BM, Niedermeier W, . 1970. Comparative concentrations of selected trace metals in human and marmoset saliva. Arch Oral Biol 15:179–188.4986993
Drichko VF, Popov DK. 1971. Age-related speed of elimination of Cs^137^ from the human body. Med Radiol 16(6):55–57.
Dua SK, Maniyan CG, Kotrappa P. 1987. Inhalation exposures during operations in spent fuel bays. Radiat Prot Dosim 19(3):165–172.
*Ducousso R, Causse A, Pasquier C. 1975. Comparative effects of acetazolamide and Prussian blue on ^137^Cs retention in the rat. Health Phys 28:75–78.
*Eaman M. 1986. Transfer of radionuclides from the environment to human milk - a review. Ottawa, Canada: Atomic Energy Control Board. DE88705117.
Edelson A, Gottesfeld Z, Samuel D, . 1976. Effect of lithium and other alkali metals on brain chemistry and behavior: II. Intracranial self-stimulation behavior. Psychopharmacologia 45:233–237.943117
*Edwards C. 1982. The selectivity of ion channels in nerve and muscle. Neuroscience 7:1335–1366.6289166
*Eisenbud M, ed. 1987. Environmental radioactivity: From natural, industrial, and military sources. New York: Academic Press, Inc.
*Eisler R. 1995. Ecological and toxicological aspects of the partial meltdown of the Chernobyl nuclear power plant reactor. In: Hoffman DJ, Rattner BA, Burton GAJ, ., eds. Handbook of ecotoxicology. Tokyo: Lewis Publishers, 15.
Elder JF, Collins JJ. 1991. Freshwater molluscs as indicators of bioavailability and toxicity of metals in surface-water systems. Rev Environ Contam Toxicol 122:37–79.1771274
Eliseeva KN, Kartel NA, Voitovich AM, . 1996. Chromosomal aberrations in different tissues of rodents and amphibians from the regions of Belarus contaminated by radionuclides. Tsitol Genet 30(4):20–25.9005632
*Ellenhorn MJ, Schonwald S, Ordog G, . 1997. Medical toxicology: Diagnosis and treatment of human poisoning. 2^nd^ ed. Baltimore: Williams & Wilkins, 1682–1723.
EMMI. 1992. EML Procedures Manual, 27^th^ ed. Vol 1. Environmental Measurements Laboratory. U.S. Department of Energy. Environmental Methods Monitoring Index.
*EPA. 1980. Prescribed procedures for measurement of radioactivity in drinking water. Cincinnati, OH: Office of Research and Development. U.S. Environmental Protection Agency. EPA-600/4-80-032.
*EPA. 1989. Environmental radiation data. Report 58. Montgomery, AL: Office of Radiation Programs. U.S. Environmental Protection Agency. EPA 520/5-89-034.
*EPA. 1990a. Characterization of municipal waste combustion ash, ash extracts, and leachates. Solid Waste and Emergency Response. U.S. Environmental Protection Agency. EPA 530-SW-90-029A.
*EPA. 1990b. Interim methods for development of inhalation reference concentrations. Washington, DC: Office of Health and Environmental Assessment. Office of Research and Development. Environmental Criteria and Assessment Office. U.S. Environmental Protection Agency. EPA 600/8-90/066A.
*EPA. 1993a. Limiting values of radionuclide intake and air concentration and dose conversion factors for inhalation, submersion, and ingestion. Federal Guidance Report No. 11. Office of Radiation Programs. U.S. Environmental Protection Agency. EPA 520/1-88-020.
*EPA. 1993b. External exposure to radionuclides in air, water, and soil. Federal Guidance Report No. 12. Office of Radiation and Indoor Air. U.S. Environmental Protection Agency. EPA 402/R-93-081.
*EPA. 1997a. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: Risk Assessment Forum. U.S. Environmental Protection Agency. EPA/630/R-96/012.
*EPA. 1997b. Health effects assessment summary tables. Washington, DC: Office of Emergency and Remedial Response. Office of Research and Development. U.S. Environmental Protection Agency. EPA 540/R-97-036. PB97-921199.
*EPA. 1998. Ionizing radiation series No. 1. Office of Radiation and Indoor Air Radiation Protection Division. U.S. Environmental Protection Agency. EPA 402-F-98-009. Http://www.epa.gov/radiationionize.htm. October 11, 2000.
*EPA. 1999a. Compliance procedures method for determining compliance with subpart I. U.S. Environmental Protection Agency. 40 CFR 61 App E.
*EPA. 1999b. Analytical methods for radioactivity. U.S. Environmental Protection Agency. 40 CFR 141.25.
*EPA. 1999c. Offsite environmental monitoring report: Radiation monitoring around United States nuclear test areas, calender year 1997. Washington, DC: Office of Radiation and Indoor Air. U.S. Environmental Protection Agency. EPA 402/R-98-013.
*EPA. 2000. Federal Guidance Report No. 13. Cancer risk coefficients for environmental exposure to radionuclides, CD Supplement [CD-ROM]. EPA 402/C-99-001.
*EPA. 2002. Radionuclide carcinogenicity slope factors. http://www.epa.gov/radiation/heast/docs/heast2_table_4-d2_0401.pdf. November 1, 2002.
Erkin VG, Lebedev OV. 1993. Thermoluminescent dosimeter measurements of external doses to the population of the Bryansk region after the Chernobyl accident. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc., 289–311.
Erten HN, Aksoyoglu S, Gokturk H. 1988. Sorption, desorption of Cs on clay and soil fractions from various regions of Turkey. Sci Total Environ 69:269–296.
Evets LV, Lyalikov SA, Orekhova SD, . 1992. The biological effect of low-level radiation on morphological composition. Radiobiologiia 32(5):627–631.1448549
*Eyman LD, Kevern NR. 1975. Cesium-137 and stable cesium in a hypereutrophic lake. Health Phys 28:549–555.1158695
Fabbris R, Gonella F, De Angelis A, . 1988. Environmental large-scale monitoring of ^137^Cs activity by milk contamination measurements and resultant doses. Radiat Prot Dosim 25:141–142.
Farkas RH, Chien P-Y, Nakajima S, . 1996. Properties of a slow nonselective cation conductance modulated by neurotensin and other neurotransmitters in midbrain dopaminergic neurons. J Neurophysiol 76(3):1968–1981.8890307
*FDA. 1998. Accidental radioactive contamination of human food and animal feeds: Recommendations for state and local agencies. Rockville, MD: U.S. Department of Health and Human Services. Food and Drug Administration. Center for Devices and Radiological Health.
*FDA. 2003. Rockville, MD: U.S. Department of Health and Human Services. Food and Drug Administration. Center for Devices and Radiological Health. http://www.FDA.gov/cdrh/pdf31k030162,pdf (http://www.FDA.gov/cdrh/pdf31k030162.pdf).
Fedorova A, Yakovleva N, Nechev K. 1975. Effect of isolated radionuclides on the hematolytic and biochemical blood indexes. Rentgenol Radiol 14(2):108–112.
*FEDRIP. 2002. Federal Research in Progress. Dialog Information Services, Inc. Palo Alto, CA.
*Feely HW, Helfer IK, Juzdan ZR, . 1988. Fallout in the New York metropolitan area following the Chernobyl accident. J Environ Radioact 7:177–191.
Fehlings MG, Nashmi R. 1996. Changes in pharmacological sensitivity of the spinal cord to potassium channel blockers following acute spinal cord injury. Brain Res 736:135–145.8930318
*Feldman C, Rains TC. 1964. The collection and flame photometric determination of cesium. Anal Chem 36:405–409.
*Fernandez MA, Martinez L, Segarra M, . 1992. Behavior of heavy metals in the combustion gases of urban waste incinerators. Environ Sci Technol 26(5):1040–1047.
*Fernandez-Turiel JL, Lopez-Soler A, Llorens JF, . 1995. Environmental monitoring using surface water, river sediments, and vegetation: A case study in the Famatina range, La Rioja, NW Argentina. Environ Int 21(6):807–820.
Feuger GF. 1986. Biological effects and risks of accidental radionuclide uptake. Acta Med Austriaca 13:86–93.3554876
Fields DE, Yalcintas MG. 1989. Lifestyle and age as determinates of intake and dose from inhaled radionuclides. J Radiol Prot 9(4):251–255.
*Fisher NS, Fowler SW, Boisson F, . 1999. Radionuclide bioconcentration factors and sediment partition coefficients in arctic seas subject to contamination form dumped nuclear wastes. Environ Sci Technol 33(12):1979–1982.
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant.” In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
*Forth W, Oberhausen E, Pfleger K, . 1963. Beitrag zur Klärung der Ursachen der Anreicherung von Cesium-137 im Organismus. Experientia 19:25–26.13958845
Fowler SW. 1986. Trace metal monitoring of palagic organisms from the open Mediterranean Sea. Environ Monit Assess 7:59–78.24254798
Francois A, Aigueperse J, Gourmelon P, . 1998. Exposure to ionizing radiation modifies neurally-evoked electrolyte transport and some inflammatory responses in rat colon in vitro. Int J Radiat Biol 73(1):93–101.9464481
Frantsevich L, Korniushin A, Pankov I, . 1996. Application of molluscs for radioecological monitoring of the Chernobyl outburst. Environ Pollut 94(1):91–100.15093522
Fredrickson L, Garner RJ, Russell RS. 1966. Caesium-137. In: Russell RS, ed. Radioactivity and human diet. Oxford: Pergamon Press, 317–352.
Frenzilli G, Lori A, Panasiuk G, . 1998. Comet assay on children’s leukocytes 8 years after the Chernobyl disaster. Mutat Res 415:151–158.9711271
*Fresquez PR, Armstrong DR, Mullen MA. 1998. Radionuclides in soils collected from within and around Los Alamos National Laboratory: 1974-1996. J Environ Sci Health Part A 33(2):263–278.
*Fresquez PR, Biggs JR, Bennett KD, . 1999a. Radionuclides in deer and elk from Los Alamos National Laboratory and the doses to humans from the ingestion of muscle and bone. J Environ Sci Health B 34(5):901–915.10466109
Fresquez PR, Kraig DH, Mullen MA, . 1999b. Radionuclides and trace elements in fish collected upstream and downstream of Los Alamos National Laboratory and the doses to humans from the consumption of muscle and bone. J Environ Sci Health B 34(5):885–889.10466108
*Frigieri P, Trucco R, Ciaccolini I, . 1980. Determination of caesium in river and seawaters by electrothermal atomic-absorption spectrometry. Interference of cobalt and iron. Analyst 105:651–656.
Fuchs VR. 1981. Low-level radiation and infant mortality. Health Phys 40:847–854.7251360
Fujita M, Iwamoto J, Kondo M. 1966. Comparative metabolism of cesium and potassium in mammals - interspecies correlation between body weight and equilibrium level. Health Phys 12:1237–1247.5970976
Fujita M, Takata K, Iwamoto J. 1968. Retention, excretion and blood concentration of ^137^Cs by rat as influenced by starvation. J Radiat Res 9:129–134.5719667
Fujita M, Yabe A, Akaishi J, . 1966. Relationship between ingestion, excretion and accumulation of fallout cesium-137 in man on long-term scale. Health Phys 12:1649–1653.
*Fülöp M, Ragan P. 1997. In-situ measurements of ^137^Cs in soil by unfolding method. Health Phys 72:923–930.9169934
Furchner JE, Richmond CR, Drake GA. 1965. Effects of environmental temperature on retention of chronically administered cesium-137. Health Phys 11:623–628.14345933
*Furchner JE, Trafton GA, Richmond CR. 1964. Distribution of cesium^137^ after chronic exposure in dogs and mice. Proc Soc Exp Biol Med 116:375–378.14189143
Ganzerli Valentini MI, Stella R, Maggi L, . 1987. Copper hexacyanoferrate(II) and (III) as trace cesium absorbers from natural waters. J Radioanal Nucl Chem 114(1):105–112.
Garnier J-M, Pham MK, Ciffroy P, . 1997. Kinetics of trace element complexion with suspended matter and with filterable ligands in freshwater. Environ Sci Technol 31:1597–1606.
*Gaur S. 1996. Determination of Cs-137 in environmental water by ion-exchange chromatography. J Chromatog A733:57–71.
*Gautier MA. 1983. Manual of analytical methods for radiobioassay. Los Alamos, NM: Los Alamos National Laboratory. LA-9763-M Manual.
Gawlik D, Behne D, Kraft D, . 1989. The influence of renal insufficiency on caesium metabolism in man and rat (with a note in the Cs content of some biological standard materials). J Trace Elem Electrolytes Health Dis 3:43–50.2535319
*Gay LA, Stanfield PR. 1978. The selectivity of the delayed potassium conductance of frog skeletal muscle fibers. Pflugers Arch 378:177–179.569840
Genicot J-L. 1997. Room-temperature semiconductor detectors for in vivo monitoring of internal contamination. Environ Health Perspect 105(Suppl. 6):1423–1426.9467055
*Gerber GB, Thomas RG. 1992. Guidebook for the treatment of accidental internal radionuclide contamination of workers. Radiat Prot Dosim 41:1–49.
*Ghosh A, Sharma A, Talukder G. 1990. Clastogenic effects of cesium chloride on mouse marrow cells in vivo. Mutat Res 244:295–298.2385244
*Ghosh A, Sharma A, Talukder G. 1991. Cytogenetic damage induced in vivo to mice by single exposure to cesium chloride. Environ Mol Mutagen 18:87–91.1879407
*Ghosh A, Sharma A, Talukder G. 1993. Clastogenic effects of caesium chloride on human peripheral blood lymphocytes in vitro. Toxicol in Vitro 7(2):137–140.20732181
Ginsborg BL, Hamilton JT. 1968. The effect of caesium ions on neuromuscular transmission in the frog. Q J Exp Physiol 53:162–169.4297293
Gitterman M, Webster EW. 1984. Shielding hospital rooms for brachytherapy patients: Design, regulatory and cost/benefit factors. Health Phys 46(3):617–625.6421772
Giusti L, Yang Y-L, Hewitt CN, . 1993. The solubility and partitioning of atmospherically derived trace metals in artificial and natural waters: A review. Atmos Environ 27A(10):1567–1578.
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
*Glowiak BJ, Pacyna J, Halawa B. 1977a. Contamination of individual human organs by strontium-90 and cesium-137. Nachr Mensch-Umwelt 5(4):12–29.
*Glowiak BJ, Pacyna J, Palczynski RJ. 1977b. Strontium and caesium-137 contents in human teeth. Environ Pollut 14:101–111.
Gluzman DF, Simonet ML, Moutet A, . 1994. Ionizing radiation induced leukemias. Eksp Onkol 16:83–95.
Gnedko TV. 1995. Blood indices in newborns and their mothers from Belarus districts contaminated with radionuclides after the Chernobyl accident. Biorheology 32:403.
Golikov VY, Balonov MI, Ponomarev AV. 1993. Estimation of external gamma radiation doses to the population after the Chernobyl accident. In: Merwin SE, Balonov MI, ed. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc., 247–288.
*Gomes MA, Wascheck CC, Scully C, . 1990. Orofacial manifestations from accidental exposure to caesium 137 in Goiania, Brazil. J Oral Pathol Med 19(7):322–325.2231437
*Gone JK, Olmez I, Ames MR. 2000. Size distribution and probable sources of trace elements in submicron atmospheric particulate material. J Radioanal Nucl Chem 244:133–139.
*Gorman ALF, Woolum JC, Cornwall MC. 1982. Selectivity of the Ca^2+^- activated and light-dependent K+ channels for monovalent cations. Biophys J 38:319–322.6286001
*Gottlöber P, Bezold G, Weber L, . 2000. The radiation accident in Georgia: clinical appearance and diagnosis of cutaneous radiation syndrome. J Am Acad Dermatol 42(3):453–458.10688716
Goulko GM, Chepurny NI, Jacob P, . 1998. Thyroid dose and thyroid cancer incidence after the Chernobyl accident: Assessments for the Zhytomyr region (Ukraine). Radiat Environ Biophys 36:261–273.9523343
*Greger R. 1981. Cation selectivity of the isolated perfused cortical thick ascending limb of Henle’s loop of rabbit kidney. Pflugers Arch 390:30–37.7195550
*Grobenski Z, Weber D, Welz B, . 1983. Determination of caesium and rubidium by flame and furnace atomic-absorption spectrometry. Analyst 108:925–932.
Grovoba OM, Chernikov VP. 1996. [The occurrence of ^137^Cs in the tissue of pulmonary tumor in a man exposed to radiation after the Chernobyl incident.] Ter Arkh 68(3):26–30. (Russian)
Gupta MM, Jain SC, Nagaratnam A. 1998. Effective dose estimates for Indian adults from ingestion of ^3^H, ^131^I and ^137^Cs. Radiat Prot Dosim 79:287–288.
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
*Haddad LM, Shannon MW, Winchester JF, eds. 1998. Clinical management of poisoning and drug overdose. 3^rd^ ed. Philadelphia: WB Saunders. 413–425.
Hahn FF, McClellan RO, Benjamin SA, . 1977a. Toxicity of inhaled beta-emitting radionuclides - an experimental approach. In: Annual report of the inhalation toxicology research institute. Albuquerque: Inhalation Toxicology Research Institute, 149–153.
Hahn FF, McClellan RO, Benjamin SA, . 1977b. Toxicity studies of inhaled beta-emitting radionuclides - an experimental approach. In: Annual report of the inhalation toxicology research institute. Albuquerque: Inhalation Toxicology Research Institute, 57–61.
Hahn FF, McClellan RO, Boecker BB, . 1979. Toxicity studies of inhaled beta-emitting radionuclides - status report. In: Annual report of the inhalation toxicology research institute. Albuquerque: Inhalation Toxicology Research Institute, 51–56.
*Hakem N, Mahamid A, Apps J, . 1997. Sorption of cesium and strontium on Savannah river soils impregnated with colloidal silica. In: Conference proceedings - International containment technology conference. Springfield, VA: National Technical Information Service, 652–657.
*Hakonson TE, Whicker FW. 1975. Cesium kinetics in a montane lake ecosystem. Health Phys 28:699–706.1140974
Halbrook RS, Jenkins JH. 1988. Cesium-137 levels detected in Georgia otters. Bull Environ Contam Toxicol 41:765–769.3233376
Hammond SE, Bold FO, Macdonald NS. 1963. Cesium-137 excretion and retention following single exposure. Health Phys 9:523–528.13952411
Hanich RF, Levine JH, Spear JF, . 1988. Autonomic modulation of ventricular arrhymia in cesium chloride-induced long GT syndrome. Circulation 77(5):1149–1161.3359592
Hanika-Rebar C, Rebar AH, Boecker BB, . 1978. Toxicity of injected ^137^CsCl in beagle dogs. XI. In: McClellan RO, ed. Annual report of the inhalation toxicology research institute. Albuquerque: Lovelace Biomedical and Environmental Research Institute, 80–83.
Hanlon DP, Ferm VH. 1986. Teratogen concentration changes as the basis of the heat stress enhancement of arsenate teratogenesis in hamsters. Teratology 34:189–193.3775670
Hanna LA, Peters JM, Wiley LM, . 1997. Enhancing effect of maternal zinc deficiency and ^137^Cs γ-irradiation on the frequency of fetal malformations in mice. Teratog Carcinog Mutagen 17:127137.
*Harik NS, Stowe CD, Seib PM. 2002. Cesium induced prolonged QT syndrome. J Invest Med 50(1):141A.
Harjulehto T, Aro T, Rita H, . 1989. The accident at Chernobyl and outcome of pregnancy in Finland. Br Med J 298:995–997.2499391
Harrison JD. 1995. Ingested radionuclides. In: Potten CS, Hendry JH, eds. Radiation and gut. New York, NY: Elsevier Science Publishers, 253–289.
Harrison SE, Klaverkamp JF, Hesslein RH. 1990. Fates of metal radiotracers added to a whole lake: Accumulation in fathead minnow (Pimephales promelas) and lake trout (Salvelinus namaucush). Water Air Soil Pollut 52:277–293.
Havlicek F. 1968. Metabolism of radiocesium during gestation and lactation as influenced by ferric-cyanoferrate(II). Int J Appl Radiat Isot 19:487–488.
Hawthorne HA, Zellmer SD, Eberhardt LL, . 1976. ^137^Cesium cycling in a Utah dairy farm. Health Phys 30:447–464.955901
Haynes RM. 1988. The distribution of domestic radon concentrations and lung cancer mortality in England and Whales. Radiat Prot Dosim 25:93–96.
HazDat. 2000. Cesium. ATSDR’s hazardous substance release and health effects database. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html. August 29, 2000.
*HazDat. 2003. Atlanta, GA: Agency for Toxic Substances and Disease Registry (ATSDR). http://www.atsdr.cdc.gov/gsql/getsubstance.script?incas=007440-46-2. December 23, 2003.
Hellman S. 1977. The place of radiation in the definitive management of carcinoma of the breast. Int J Radiat Oncol Biol Phys 2:369–370.863769
*Hellou J, Fancey LL, Payne JF. 1992a. Concentrations of twenty-four elements in bluefin tuna, Thunnus thynnus from the Northwest Atlantic. Chemosphere 24(2):211–218.
*Hellou J, Warren WG, Payne JF, . 1992b. Heavy metals and other elements in three tissues of cod, Gadus morhua from the Northwest Atlantic. Mar Pollut Bull 24(9):452–458.
*Helmers E. 1996. Elements accompanying platinum emitted from automobile catalysts. Chemosphere 33(3):405–419.
*Henrichs K, Paretzke HG, Voigt G, . 1989. Measurements of Cs absorption and retention in man. Health Phys 57(4):571–578.2793472
Herman P, Tietveld EC, Weseman JM. 1987. The metabolism and tissue accumulation of radio-cesium in veal calves throughout the entire fattening period. J Anim Physiol Anim Nutr 60:108–112.
*Hewitt PJ. 1988. Accumulation of metals in the tissues of occupationally exposed workers. Environ Geochem Health 10:113–116.24213651
*Hille B. 1973. Potassium channels in myelinated nerve. Selected permeability to small cations. J Gen Physiol 61:669–686.4541077
*Hillmann U, Schimmack W, Jacob P, . 1996. In situ γ-spectrometry several years after deposition of radiocesium: Part I: Approximation of depth distributions by the Lorentz function. Radiat Environ Biophys 35:297–303.9008007
*Hilton J, Livens FR, Spezzano P, . 1993. Retention of radioactive caesium by different soils in the catchment of a small lake. Sci Total Environ 129:253–266.
*Hintenlang DE. 1993. Synergistic effects of ionizing radiation and 60 Hz magnetic fields. Bioelectromagnetics 14:545–551.8297398
*Hirose K, Takatani S, Aoyama M. 1993. Wet deposition of radionuclides derived from the Chernobyl accident. J Atmos Chem 17:61–71.
*Hodgkin AL. 1947. The effect of potassium on the surface membrane of an isolated axon. J Physiol 106:319–340.16991764
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
*Hölgye Z, Malỳ M. 2002. A case of repeated accidental inhalation contamination of a male subject with ^137^Cs. Health Phys 82(4):517–520.11906141
Hood SL, Comar CL. 1953. Metabolism of cesium-137 in rats and farm animals. Arch Biochem Biophys 45:423–433.13081150
Hoshi M, Shibata Y, Okajima S, . 1994a. ^137^Cs concentration among children in areas contaminated with radioactive fallout from the Chernobyl accident: Mogilev and Gomel Oblasts, Belarus. Health Phys 67(3):272–275.8056594
Hoshi M, Yamamoto M, Kawamura H, . 1994b. Fallout radioactivity in soil and food samples in the Ukraine: Measurements of iodine, plutonium, cesium, and strontium isotopes. Health Phys 67(2):187–191.7619095
Huang C-Y, Lee J-D, Tseng C-L, . 1994. A rapid method for the determination of ^137^Cs in environmental water samples. Anal Chim Acta 294:221–226.
*Huda M, Sourkes AM, Tracy BL. 1988. Chernobyl - The radiological impact on Canada. J Can Assoc Radiol 39:37–41.
*IAEA. 1962. Whole-body counting. Vienna: International Atomic Energy Agency. IAEA Publication No. STI/PUB/47.
*IAEA. 1970. Directory of whole-body radioactivity monitors. Vienna: International Atomic Energy Agency. IAEA Publication No. STI/PUB/213.
*IAEA. 1972. Assessment of radioactive contamination in man. Vienna: International Atomic Energy Agency. IAEA Publication No. STI/PUB/290.
*IAEA. 1976. Diagnosis and treatment of incorporated radionuclides. Vienna: International Atomic Energy Agency. IAEA Publication No. STI/PUB/411.
*IAEA. 1985. Assessment of radioactive contamination in man 1984. Vienna: International Atomic Energy Agency. IAEA Publication No. STI/PUB/674.
*IAEA. 1988. The radiological accident in Goiania. Vienna: International Atomic Energy Agency. IAEA Publication No. STI/PUB/815.
*IAEA. 1991. The international Chernobyl project technical report, page 2 of 7. International Atomic Energy Agency, Vienna. Publication No. STI/PUB/885.
*IARC. 2000. Cesium. International Agency for Research on Cancer. http://193.51.164.11.html. October 13, 2000.
ICRP. 1975. Report of the task group on reference man. International Commission on Radiological Protection. Oxford: Pergamon Press: ICRP Publication 23.
*ICRP. 1979. Limits for intakes of radionuclides by workers. International Commission on Radiological Protection. Oxford: Pergamon Press. ICRP Publication 30, Part 1; Annuals of the ICRP 2(3/4).
*ICRP. 1983. Radionuclide transformations: Energy and intensity of emissions. International Commission on Radiological Protection. Oxford: Pergamon Press. ICRP publication 38. 484–503.
*ICRP. 1989. Age dependent doses to members of the public from intake of radionuclides. International Commission on Radiological Protection. Oxford: Pergamon Press. ICRP Publication 56, Part 1; Annuals of the ICRP 20(2).
*ICRP. 1993. Age dependent doses to members of the public from intake of radionuclides. Part 2; Ingestion dose coefficients. International Commission on Radiological Protection. Oxford: Pergamon Press. ICRP Publication 67, Part 1; Annuals of the ICRP 23(3/4).
*ICRP. 1994. Human respiratory tract model for radiological protection. International Commission on Radiological Protection. Pergamon Press, Oxford. Publication No. 66.
*ICRP. 1995. Age-dependent doses to members of the public from intake of radionuclides: Part 4 inhalation dose coefficients. Pergamon Press, Oxford. Publication No. 71.
*ICRP. 1996. Age-dependent doses to members of the public from intake of radionuclides. Part 5. International Commission on Radiological Protection. Pergamon Press, Oxford. Publication No. 72.
ICRP. 1999. Protection of the public in situations of prolonged radiation exposure. International Commission on Radiological Protection. Pergamon Press, Oxford. Publication No. 82
*Ide HM, McInroy JF. 1975. Cesium-134 in human autopsy tissue. Health Phys 29:871–872.1201955
*Iijima K, Morimoto K. 1991. Quantitative analysis of the induction of chromosome aberrations and sister-chromatid exchanges in human lymphocytes exposed to γ-rays and mitomycin-C in combination. Mutat Res 263:263–268.1907353
*Iinuma T, Nagai T, Ishihara T. 1965. Cesium turnover in man following single administration of 132Cs: 1. Whole body retention and excretion pattern. J Radiat Res 6:73–81.5883137
*Iinuma T, Watari K, Nagi T, . 1967. Comparative studies of Cs-132 and Rb-86 turnover in man using a double-tracer method. J Radiat Res 8:11–115.
Ilyin LA, Ivannikov AT, Popov BA, . 1998. [Study of ^137^Cs transfer regularities through the placenta to the rat fetuses and the effect of ferrocinum on these processes.] Radiat Biol Radioecol 38(4):616–623. (Russian)
Ilyinskikh NN, Ilyinskikh EN, Ilyinskikh IN. 1998. Micronucleated erthrocytes frequency and radiocesium bioconcentration in pikes (Esox lucius) caught in the Tom River near the nuclear facilities of the Siberian chemical complex (Tomsk-7). Mutat Res 421:197–203.9852993
Ilyinskikh NN, Ilyinskikh IN, Smirnov BV, . 1999. Micronuceated erthrocytes and radionuclide activity in persons living in a radiation contaminated area near the Mayak nuclear facility (Russia). J Hum Ecol 10(4):237–244.
Inaba J, Matsusaka N, Ichikawa R. 1967. Whole-body retention and tissue distribution of cesium-134 in new-born, young and adult rats. J Radiat Res 8:132–140.5590721
Inalsingh CHA, Chandrasekaran MS, Julian C, . 1976. A seven year review of invasive carcinoma of the cervix treated at the Johns Hopkins Hospital. Johns Hopkins Med J 139:147–151.978858
*IRIS. 2002. Cesium. U.S. Environmental Protection Agency. Integrated Risk Information System. http://www.epa.gov/iris/subst/index.htm. October 24, 2002.
*Isenberg G. 1976. Cardiac purkinje fibers: Cesium as a tool to block inward rectifying potassium currents. Pflugers Arch 365:99–106.988568
Ito M, Yamashita S, Ashizawa K, . 1996. Histopathological characteristics of childhood thyroid cancer in Gomel, Belarus. Int J Cancer 65:29–33.8543392
*Iyengar V, Woittiez J. 1988. Trace elements in human clinical specimens: Evaluation of literature data to identify reference values. Clin Chem 34:474–481.3280162
Jenner FA, Judd A, Parker J. 1975. The effects of lithium, rubidium and caesium on the response of rats to tranylcypromine and alpha-methyl-p-tyrosine given separately or in combination. Br J Pharmacol 54:233–234.
Jin H, Gao L, Xu Z, . 1996. Effect of low dose irradiation on nutrition metabolism in rats. Yingyang Xuebao 18(2):134–138.
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
*Johansson L, Bjoreland A, Agren G. 1998. Transfer of ^137^Cs to infants via human breast milk. Radiat Prot Dosim 79:165–167.
*Johnson FN. 1972. Effects of alkali metal chlorides on activity in rats. Nature 238:333–334.4561839
*Johnson GT, Lewis TR, Wagner WD. 1975. Acute toxicity of cesium and rubidium compounds. Toxicol Appl Pharmacol 32:239–245.1154391
Jouve A, Lejeune M, Rey J. 1999. A new method for determining the bioavailability of radionuclides in the soil solution. J Environ Radioact 43:277–289.
*Kahn B, Smith DK, Straub CP. 1957. Determination of low concentrations of radioactive cesium in water. Anal Chem 29:1210–1213.
Kali AK, Whitmore R, Roache W. 1985. Behavior of cesium in fish tissues from Savannah River. Environ Int 11:23–24.
*Kamiguchi Y, Tateno H, Mikamo K. 1991. Micronucleus test in 2-cell embryos as a simple assay for human sperm chromosome aberrations. Mutat Res 252:297–303.2052009
*Kanapilly GM, Stanley JA, Newton GJ, . 1983. Characterization of an aerosol sample from the auxillary building of the Three Mile Island reactor. Health Phys 45:981–989.6643066
Kasatkani EP, Shilin DE, Rosenbloom AL, . 1997. Effects of low level radiation from the chernobyl accident in a population with iodine deficiency. Eur J Pediatr 156:916–920.9453372
Kashparov VA, Protsak VP, Yoschenko VI, . 1994. Inhalation of radionuclides during agricultural work in areas contaminated as a result of the Chernobyl reactor accident. J Aerosol Sci 25(5):761–766.
Kennish MJ. 1998. Trace metal-sediment dynamics in estuaries: Pollution assessment. Rev Environ Contam Toxicol 155:69–110.
*Khosid GM. 1967. ЦЕЗИЙ И РУБИДИЙ. In: Israelson AL, ed. Novye dannye po toksikologii redkikh metalovi. Moscow. 56–63.
*Kim EY, Goto R, Tanabe S, . 1998. Distribution of 14 elements in tissues and organs of oceanic seabirds. Arch Environ Contam Toxicol 35:638–645.9776782
Kirchner G. 1994. Transport of iodine and cesium via the grass-cow-milk pathway after the Chernobyl accident. Health Phys 66(6):653–665.8181940
Kirchner TB, Whicker FW, Anspaugh LR, . 1996. Estimating internal dose due to ingestion of radionuclides from Nevada test site fallout. Health Phys 71(4):487–501.8830750
Kirillov SA, Vissonov YV. 1971. Clinical picture of Cs^137^ and Cs^134^ poisoning during long-term periods. Med Radiol 16(11):47–52.
Koenig W. 1974. Significance of radiation hazard for the fixing of radiation protection limits. Rep - Staatl Zent Strahlenschutz DDR 157:38–41.
Koike K, Yabuhara A, Yang F-C, . 1995. Frequent natural killer cell abnormality in children in an area highly contaminated by the Chernobyl accident. Int J Hematal 61:139–145.
*Kolb W. 1971. Tungsten-181 and other short lived fission products in ground level air in north Germany and north Norway. Nature 232:552–553.4937494
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Konings J, Kirchmann R, Gerber GB, . 1984. Distribution of ^60^Co and ^137^Cs in mallard ducks (Anas platyrhynchus). Health Phys 46(3):681–684.6698795
Konshin OV. 1992. Transfer of ^137^Cs from soil to grass-analysis of possible sources of uncertainty. Health Phys 63(3):307–315.1644567
Korky JK, Kowalski L. 1989. Radioactive cesium in edible mushrooms. J Agric Food Chem 37:568–569.
Kornberg HA. 1961. The use of element-pairs in radiation hazard assessment. Health Phys 6:46–62.13753187
*Korobova E, Ermakov A, Linnik V. 1998. ^137^Cs and ^90^Sr mobility in soils and transfer in soil-plant systems in the Novozybkov district affected by the Chernobyl accident. Appl Geochem 13(7):803–814.
Korolev GK. 1965. Distribution of Cs^137^ after endotracheal administration. Fed Proc 25(1):95–98.
*Koshimoto C, Takahashi S, Kubota Y, . 1994. Evaluation of the effect of gamma-irradiation on fetal erythropoiesis in rats using blood cell volume as the index. J Radiat Res 35:74–82.7965992
Kostial K, Vnucec M, Tominac C, . 1980. A method for a simultaneous decrease of strontium, caesium and iodine retention after oral exposure in rats. Int J Radiat Biol 37(3):347–350.
Koulikov AO, Ryabov IN. 1992. Specific cesium activity in freshwater fish and the size effect. Sci Total Environ 112:125–142.1574700
Krachler M, Rossipal E, Micetic-Turk D. 1999. Concentrations of trace elements in arterial and venous umbilical cord sera. Trace Elem Electrolytes 16(1):46–52.
Kraemer SM, Waldren CA. 1997. Chromosomal mutations and chromosome loss measured in a new human-hamster hybrid cell line, A_L_C: studies with colcemid, ultraviolet irradiation, and ^137^Cs γ-rays. Mutat Res 379:151–166.9357544
Kraybill HF. 1983. Assessment of human exposure and health risk to environmental contaminants in the atmosphere and water with special reference to cancer. J Environ Sci Health C 1(2):175–232.
*Krieger HL, Martin ER, Frishkorn GW. 1976. Sequential radiochemical analysis for ruthenium, strontium, and cesium in environmental air. Health Phys 30:465–470.955902
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3^rd^ ed. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kryshev II, Romanov GN, Sazykina TG, . 1998. Environmental contamination and assessment of doses from radiation releases in the southern Urals. Health Phys 74(6):687–697.9600301
Kubic M, Kusmierek E, Michalczuk L, . 1993. Contamination of fruits, soils, and mushrooms in Poland in 1991. J Fruit Ornamental Plant Res 1(2):46–53.
Kudelsky AV, Smith JT, Ovsiannikova SV, . 1996. Mobility of Chernobyl-derived ^137^Cs in a peatbog system within the catchment of the Pripyat River, Belarus. Sci Total Environ 188:101–113.8864245
*Kusama T, Hasegawa Y. 1993. Stage differences in developmental disorders in ICR mouse embryos irradiated with gamma-rays. Congen Anom 33:115–123.
Kwadow M, Chevalier C. 1988. Occupational exposure to radionuclides in French nuclear power plants: Five years excretion monitoring results. Sci Total Environ 70:299–319.3363333
*LaBrecque JL, Rosales PA. 1996. The migration of ^137^Cs in Venezuelan soils. J Trace Microprobe Tech 14(1):213–221.
*LA Dept Environ Quality. 2000. Radiation protection. Louisiana Department of Environmental Quality. http://www.deq.state.la.us. August 29, 2000.
*Landeen DS, Mitchell RM. 1986. Radionuclide uptake by trees at a RAD waste pond in Washington State. Health Phys 50(6):769–774.3710785
Lassy KR. 1979. The transfer of radiostrontium and radiocesium from soil to diet: Models of consistent with fallout analysis. Health Phys 37:557–573.536218
*Latorre R, Miller C. 1983. Conduction and selectivity in potassium channels. J Membr Biol 71:11–30.6300405
Lavrent LN. 1975. Nephrosclerosis induced by various chronic radiation effects. Radiobiologiia 15(5):704–707.1208791
Lazjuk GI, Kirillova IA, Nikolaev DL, . 1993. Monitoring of congenital malformations in Belarus after the Chernobyl accident. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc., 385–397.
Lazjuk GI, Nikolaev DL, Novikova IV. 1997. The dynamics of congenital malformations in Belarus Republic. Am J Hum Genet 61(4):A204.
Lazjuk GI, Nikolaev DI, Khmel RD. 2000. Epidemiology of congenital malformations in Belarus and Chernobyl accident. Am J Hum Genet 67:214.
Lebedev OV, Yakovlev VA. 1993a. The correlation between ^137^Cs half-time and age, body mass and height in individuals contaminated from the Chernobyl accident. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc., 219–243.
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
*Leggett RA, Williams LR, Melo DR, . 2003. A physiologically based biokinetic model for cesium in the human body. Sci Total Environ 317:235–255.14630424
*Leggett RW. 1986. Predicting the retention of Cs in individuals. Health Phys 50(6):747–759.3710783
*Lengemann FW. 1970. ^134^Cs retention in rats from one to 25 months of age. Radiat Res 42:169–174.5444044
*LeRoy GV, Rust JH, Hasterlik RJ. 1966. The consequences of ingestion by man of real and simulated fallout. Health Phys 12:449–473.5960263
*Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol 1. New York, NY: Stockton Press, 153–164.
*Levine JH, Spear JF, Guarnieri T, . 1985. Cesium chloride-induced long QT syndrome: demonstration of after depolarizations and triggered activity in vivo. Circulation 72(5):1092–1103.4042297
*Lewis RJ. 1997. Hawley’s condensed chemical dictionary. 13^th^ ed. New York, NY: John Wiley & Sons. 234–236.
Liaginskaia AM, Osipov VA, Dement’ev SI. 1998. Kinetics of metabolism and mechanisms of formation of absorbed doses in the mouse testis from incorporated Cs^137^. Radiat Biol Radioecol 38(1):27–30.
Liao M, Wang Z, Yu T. 1988. [Study of 45 metal compounds using micronucleus test]. Weisheng Dulixue Zazhi 2(2):83–86. (Chinese)
*Lide DR. 1998. CRC handbook of chemistry and physics: A ready-reference book of chemical and physical data. 79^th^ ed. Boca Raton: CRC Press. 12/43–12/45.
*Lie R. 1964. Deposition and retention of ^137^Cs in the rat following inhalation of the chloride and the nitrate. Health Phys 10:1071–1076.14244754
Lievens P, Cornelis R, Hoste J. 1975. A separation scheme for the determination of trace elements in biological materials by neutron activation analysis. Anal Chim Acta 80:97–108.1200377
*Lipsztein JL, Bertilli L, Melo DR, . 1991. Application of in-vitro bioassay for ^137^Cs during the emergency phase of the Goiânia accident. Health Phys 60:43–49.1983980
Lipsztein JL, Melo DR, Oliveira CAN, . 1998. The Goiania ^137^Cs accident - a review of the internal and cytogenetic dosimetry. Radiat Prot Dosim 79:149–154.
Livens FR, Horrill AD, Singleton DL. 1991. Distribution of radiocesium in the soil-plant systems of upland areas of Europe. Health Phys 60(4):539–545.2001950
*Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Lloyd DC, Finnon P, Edwards AA, . 1997. Chromosome aberrations in Syrian hamsters following very low radiation doses in vivo. Mutat Res 377:63–68.9219580
*Lloyd RD, Mays CW, McFarland SS, . 1973. Metabolism of ^83^Rb and ^137^Cs in persons with muscle disease. Radiat Res 54:463–478.4715867
Lloyd RD, Zundel WS, Mays CW, . 1968. Short caesium half-times in patients with muscular dystrophy. Nature 220:1029–1031.5701838
Lo CK, Fung YS. 1992. Heavy metal pollution profiles of dated sediment cores from Hebe Haven, Hong Kong. Water Res 26(12):1605–1619.
Lockhart WL, Muir CG, Wilkinson P, . 1998. Chemical contaminants in fish and sediment core samples from the Dnipro River, Ukraine, 1994. Water Qual Res J Can 33(4):489–509.
*Lokobauer N, Bauman A, Maracic M. 1988. Assessment of the radiation dose in the republic of Croatia after the Chernobyl reactor accident. Environ Int 14:137–143.
Lorenz R, Deubel W, Leuner K, . 1994. Dose and dose-rate dependency of the frequency of HPRT deficient T lymphocytes in the spleen of the ^137^Cs γ-irradiated mouse. Int J Radiat Biol 66(3):319–326.7930834
Lowe VPW, Horrill AD. 1988. Ecological half-life of caesium in Roe deer (Capreolus capreolus). Environ Pollut 54:81–87.15092525
*Luetzelschwab JW. 1976. A field sampling unit that uses an ion-exchange resin to concentrate radioactive ions in river water. Health Phys 31:387–389.993040
Lundgren DL, Hahn FF, Griffith WC, . 1996. Pulmonary carcinogenicity of relatively low doses of beta-particle radiation from inhaled ^144^CeO_2_ in rats. Radiat Res 146:525–535.8896579
Lundgren DL, Hahn FF, McClellan RO. 1980. Influence of age at the time of inhalation exposure to aerosols of ^144^CeO_2_ on ^144^Ce retention, dosimetry and toxicity in mice. Health Phys 38:643–655.7410082
Lymberis C, Makrigiorgos G, Sbonias E, . 1987. Radiocesium levels in human muscle samples in Greece one year after the Chernobyl accident. Appl Radiat Isot 39(2):175–176.
*Maenhaut W, Zoller WH, Duce RA, . 1979. Concentration and size distribution of particulate trace elements in the south polar atmosphere. J Geophys Res 84(C5):2421–2431.
*Mahara Y. 1993. Heavy metals in the environment: Storage and migration of fallout strontium-90 and cesium-137 for over 40 years in the surface soil of Nagasaki. J Environ Qual 22:722–730.
*Mahlum DD, Sikov MR. 1969. Comparative metabolism of ^137^Cs by adult, suckling and prenatal rats. Comp Biochem Physiol 30:169–175.5804478
Manion PJ, Hanson LH, Fodale MF. 1988. Sterilizing effects of cesium-137 irradiation on male sea lampreys released in the Big Garlic River Michigan USA. Great Lakes Fish Comm Tech Bull 53:1–8.
Marouf BA, Mohamad AS, Taha JS, . 1992. The transfer of ^137^Cs from soil to plants. Environ Int 18:211–215.
Marshall GC, Kessler WV, Born GS, . 1997. Effects of altered thyroid states on cesium-137 accumulation in the liver of rats. Health Phys 33:622–624.
Marshall H, Cooper MB. 1989. Cs^137^ in the barren ground caribou of Canada. Health Phys 56(Suppl. 1):S67–S68.
*Matsuda Y, Tobari I, Yamagiwa J, . 1985. Dose-response relationship of γ-ray-induced reciprocal translocations at low doses in spermatogonia of the crab-eating monkey (Macaca fascicularis). Mutat Res 151:121–127.4022036
Matsumoto K, Yagi M. 1991. Instrumental photon activation analysis of coal fly ashes using the internal standard method coupled with the standard addition method. J Radioanal Nucl Chem 152(1):55–66.
Matsunaga T, Ueno T, Chandradjith RLR, . 1999. Cesium-137 and mercury contamination in lake sediments. Chemosphere 39(2):269–283.10399844
Matsusaka N, Inaba J. 1967. Whole-body retention of caesium-137 in suckling and weanling mice. Nature 214:303–304.6034252
Matsusaka N, Yamakawa Y, Sato I, . 1997. Organ distribution of ^137^Cs in mouse fetuses and their dams. Radioisotopes 46:214–218.
Mayes RW, Eayres HF, Beresford NA, . 1992. Changes with age in the absorption of radiocesium by sheep. Radiat Prot Dosim 41:83–86.
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McAuly IR, Doyle C. 1985. Radiocesium levels in Irish sea fish and the resulting dose to the population of the Irish Republic. Health Phys 48(3):333–337.3980220
McCartney M, Kershaw PJ, Woodhead DS, . 1994. Artificial radionuclides in the surface sediments of the Irish Sea, 1968-1988. Sci Total Environ 141:103–138.
McClellan RO, Rupprecht FC. 1968. Toxicity of ^137^CsCl in the beagle dog. In: Fission Product Inhalation Program, ed. Fission product inhalation program annual report 1967-1968. Albuquerque, NM: Lovelace Foundation for Medical Research and Education, 54–75.
*McCraw TF. 1965. The half-time of cesium-137 in man. Radiol Health Data Rep 6(12):711–718.5853185
*McCreedy CD, Jagoe CH, Glickman LT, . 1997. Bioaccumulation of cesium137 in yellow bullhead catfish (Ameiurus natalis) inhabiting an abandoned nuclear reactor reservoir. Environ Toxicol Chem 16(2):328–335.
*McGee EJ, Synnott HJ, Keatinge M, . 1993. Persistence and prediction of radiocaesium levels in animals grazing semi-natural environments. Sci Total Environ 138:91–99.8259495
McGee EJ, Synnott HJ, O’Keefe C, . 1995. Radionuclide uptake by red deer (Cervus elaphus) on mountain grazing. Br Vet J 151:671–682.8605580
Meiler CF, Katzung BG. 1981. Cesium blockade of delayed outward currents and electrically induced pacemaker activity in mammalian ventricular myocardium. J Gen Physiol 77:531–547.6262430
Mejstrik V, Svacha J. 1988. Concentrations of ^232^Th, ^226^Ra, ^137^Cs and ^40^K in soils, and radioactivity in areas of coal-fired power plants. Sci Total Environ 72:69–79.
Melin J, Wallberg L, Suomela J. 1994. Distribution and retention of cesium and strontium in Swedish boreal forest ecosystems. Sci Total Environ 157:93–105.
*Melo DR, Lipsztein JL, Oliveira CAN, . 1994. A ^137^Cs age-dependent biokinetic study. Health Phys 66(6):S25–S26.
Melo DR, Lipsztein JL, Oliveira CAN, . 1995. ^137^Cs metabolism in pregnant women. Health Phys 68(6):S77.
*Melo DR, Lipsztein JL, Oliveira CAN, . 1997. A biokinetic model for ^137^Cs. Health Phys 73(2):320–332.9228167
*Melo DR, Lundgren DL, Muggenburg BA, . 1996. Prussian blue decorporation of ^137^Cs in beagles of different ages. Health Phys 71(2):190–197.8690602
Messiha FS. 1976. Distribution and retention of exogenously administered alkali metal ions in the mouse brain. Arch Int Pharmacodyn 219:87–96.1267545
*Messiha FS. 1978. Anti-depressant action of caesium chloride and its modification of chlorpromazine toxicity in mice. Br J Pharmacol 64:9–12.698485
Messiha FS. 1985. Cesium: An overview. Neurol Neurobiol 15:247–257.
Messiha FS. 1988a. Effect of separate and combined maternal ingestion of alkali metals on the developing mouse. Neurosci Biobehav Rev 12:205–208.2852326
*Messiha FS. 1988b. Maternal cesium chloride ingestion and the newborn. Neurosci Biobehav Rev 12:209–213.3226644
Messiha FS. 1989a. Maternally-mediated neonatal lithium-cesium interaction in the mouse. Physiol Behav 46:89–95.2554355
*Messiha FS. 1989b. A toxicology evaluation of postnatal maternal exposure to cesium. Physiol Behav 46:85–88.2813559
Messiha FS. 1994. Developmental toxicity of cesium in the mouse. Gen Pharmac 25(3):395–400.
Messiha FS, Larson JW. 1976. A pharmacokinetic study of rubidium and cesium salts. Proc West Pharmacol Soc 19:108–112.995973
*MI Dept Environ Quality. 2000. Maximum contaminant levels; incorporation by reference. Safe drinking water act. State of Michigan Department of Environmental Quality. http://www.deq.state.mi.us. June 14, 2000.
Mietelski JW, Jasinska M, Kubica B, . 1994. Radioactive contamination of Polish mushrooms. Sci Total Environ 157:217–226.
*Mihok S, Schwartz B, Wiewel AM. 1989. Bioconcentration of fallout ^137^Cs by fungi and red-backed voles (Clethrionomys gapperi). Health Phys 57(6):959–966.2684915
*Mikamo K, Kamiguchi Y, Tateno H. 1990. Spontaneous and in vitro radiation-induced chromosome aberrations in human spermatozoa: Application of a new method. In: Mendelsohn ML, Albertini RJ, eds. Mutation and the environment: Part B: Metabolism, testing methods, and chromosomes. New York, NY: Wiley-Liss, 447–456.
*Mikamo K, Kamiguchi Y, Tateno H. 1991. The interspecific in vitro fertilization system to measure human sperm chromosomal damage. In: Gledhill BL, Mauro F, ed. New horizons in biological dosimetry. New York, NY: Wiley-Liss, 531–542.
*Mikhaylovskaya LN, Molchanova IV, Karavayeva YN. 1993. Forms of occurrence and migration of radionuclides in soils affected by the accident at the Chernobyl nuclear power plant. Euras Soil Sci 25(7):103–107.
Millard GC, Fraley L, Markham OD. 1983. Deposition and retention of ^141^Ce and ^134^Cs aerosols on cool desert vegetation. Health Phys 44(4):349–357.6841091
*Miller CE. 1964. Retention and distribution of ^137^Cs after accidental inhalation. Health Phys 10:1065–1070.14244753
Miltenberger RP, Lessard ET, Greenhouse NA. 1981. ^60^Co and ^137^Cs long-term biological removal rate constants for the United Nations scientific committee on the Marshallese population. Health Phys 40:615–623.7263251
*Minamisawa T, Hirokaga K, Sasaki S. 1990. Gross morphological changes of the mouse brain exposed prenatally to ionizing radiation. J Radiat Res 31:214–218.2213692
*Minamisawa T, Hirokaga K, Sasaki S, . 1992. Effects of fetal exposure to gamma rays on aggressive behavior in adult male mice. J Radiat Res 33:243–249.1464856
*Molero J, Sanchez-Cabeza JA, Merino J, . 1999. Impact of ^134^Cs and ^137^Cs from the Chernobyl reactor accident on the Spanish Mediterranean marine environment. J Environ Radioact 43:357–370.
Monakhov AS, Iakovleva TK, Strekalov SA, . 1991. The cytogenetic and hematotoxic effect of cesium137 incorporated in the rat body. Radiobiologiia 31(6):798–802.1767009
*Mondon KJ, Walters B. 1990. Measurement of radiocaesium, radiostrontium, and plutonium in whole diets, following deposition of radioactivity in the UK originating from the Chernobyl power plant accident. Food Addit Contam 7(6):837–848.2079116
*Moore W, Comar CL. 1962. Absorption of caesium 137 from the gastro-intestinal tract of the rat. Int J Radiat Biol 5(3):247–254.
*Moore W, Comar CL. 1963. Movement of ^137^Cs across surviving intestinal segments in vitro. Int J Radiat Biol 6(6):507–511.
Morgan IJ, Tytler P, Bell MV. 1993. The accumulation of 137-caesium from fresh water by alevins and fry of Atlantic salmon and brown trout. J Fish Biol 43:877–888.
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Motelica-Heino M, Le Coustumer P, Thomassin JH, . 1998. Macro and microchemistry of trace metals in vitrified domestic wastes by laser ablation ICP-MS and scanning electron microprobe x-ray energy dispersive spectroscopy. Talanta 46:407–422.18967162
Muggenburg BA, Boecker BB, Hahn FF, . 1983. The risk of liver tumors in dogs and man from radioactive aerosols. In: Thompson RC, Mahaffey JA, eds. Life-span radiation effects studies in animals: What can they tell us? Proceedings of the twenty-second Hanford life science symposium held at Richland, Washington, September 27-29, 1983. Hanford Life Sciences Symposium 22^nd^. Springfield, VA: US Department of Energy, 556–563.
*Mumma RO, Raupach DC, Sahadewan K, . 1990. National survey of elements and radioactivity in municipal incinerator ashes. Arch Environ Contam Toxicol 19:399–404.2353839
*Mumma RO, Raupach DC, Sahadewan K, . 1991. Variation in elemental composition of municipal refuse incinerator ashes with time of sampling. Chemosphere 23(3):391–395.
*Murakawa Y, Sezaki K, Yamashita T, . 1997. Three-dimensional activation sequence of cesium-induced ventricular arrhythmias. Am J Physiol 42:H1377–H1385.
Muramatsu Y, Yoshida S, Sumiya M. 1991. Concentrations of radiocesium and potassium in basidiomycetes collected in Japan. Sci Total Environ 105:29–39.1925522
Myers B, Shaw SM. 1975. Deposition, clearance, and distribution of cesium-137 labeled cesium chloroplatinate in normal and sulfur dioxide exposed rats. AIChE Symp Ser 71(147):107–110.
Nakaoka A, Yokoyama H, Fukushima M, . 1980. Rapid determination method of radiocesium in sea water by cesium-selective resin. J Radioanal Chem 56(1–2):13–24.
*NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy Press. National Academy of Sciences. National Research Council.
*Natarajan AT, Santos SJ, Darroudi F, . 1998. Cesium-induced chromosome aberrations analyzed by flourescence in situ hybridization: Eight years follow up of the Goiania radiation accident victims. Mutat Res 400:299–312.9685685
Nayebpour M, Solymoss BC, Nattel S. 1989. Cardiovascular and metabolic effects of caesium chloride injection in dogs - limitations as a model for the long QT syndrome. Cardiovasc Res 23:756–766.2611814
*NCRP. 1977. Cesium-137 from the environment to man: Metabolism and dose. Bethesda, MD: National Council on Radiation Protection and Measurements. NCRP Report No. 52.
*NCRP. 1985. General concepts for the dosimetry of internally deposited radionuclides. Bethesda, MD: National Council on Radiation Protection and Measurements. NCRP Report No. 84.
*NCRP. 1987. Use of bioassay procedures for assessment of internal radionuclide deposition. Bethesda, MD: National Council on Radiation Protection and Measurements. NCRP Report No. 87.
*NCRP. 1997. Deposition, retention and dosimetry of inhaled radioactive substances. Bathesda, MD: National Council on Radiation Protection and Measurements. NCRP Report No. 125.
Nellessen JE, Fletcher JS. 1993. Assessment of published literature on the uptake, accumulation, and translocation of heavy metals by vascular plants. Chemosphere 27(9):1669–1680.
Nelson A, Ullberg S, Kristoffersson H, . 1961. Distribution of radiocesium in mice. Acta Radiol 55:374–384.13728254
*Neulieb R. 1984. Effects of oral intake of cesium chloride: A single case report. Pharmacol Biochem Behav 21(Suppl. 1):15–16.6522428
*Nevissi AE. 1992. Measurement of actinides and long-lived radionuclides in large coral samples. J Radioanal Nucl Chem 156(2):243–251.
Newman G. 1996. Increased morbidity following the introduction of remote afterloading, with increased dose rate, for cancer of the cervix. Radiother Oncol 39:97–103.8735476
Ng YC, Anspaugh LR, Cederwall RT. 1990. ORERP internal dose estimates for individuals. Health Phys 59(5):693–713.2211124
Nielson SP, Gryning SE, Karlberg O, . 1990. Dry deposition of ^88^Rb and ^138^Cs from a boiling water reactor plume. Health Phys 58(3):283–289.2312294
Nifontova M. 1995. Radionuclides in the moss-lichen cover of tundra communities in the Yamal Peninsula. Sci Total Environ 160/161:749–752.
Niimi AJ. 1987. Biological half-lives of chemicals in fishes. Rev Environ Contam Toxicol 99:1–46.3303179
*Nikula KJ, Muggenburg BA, Chang I-Y, . 1995. Biological effects of ^137^CsCl injected in beagle dogs. Radiat Res 142:347–361.7761585
*Nikula KJ, Muggenburg BA, Griffith WC, . 1996. Biological effects of ^137^CsCl injected in beagle dogs of different ages. Radiat Res 146:536–547.8896580
Nimis PL, Bolognini G, Giovani C. 1994. Radiocontamination patterns of vascular plants in a forest ecosystem. Sci Total Environ 157:181–188.
*NIOSH. 1992. Recommendations for occupational safety and health. Compendium of policy documents and statements. Cincinnati, OH: US Department of Health and Human Services. PB92162536.
*NIOSH. 2000. Cesium. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npgd0145.html. October 13, 2000.
Noboru Y, Kiyoshi I, Teruo N. 1966. In vivo experiment on the metabolism of cesium in human blood with reference to rubidium and potassium. J Radiat Res 7-1:29–46.
*NOES. 1989. National Occupational Exposure Survey. National Institute for Occupational Safety and Health.
*Norton S, Kimler BF. 1987. Correlation of behavior with brain damage after in utero exposure to toxic agents. Neurotoxicol Teratol 9:145–150.3657750
*Norton S, Kimler BF. 1988. Comparison of functional and morphological deficits in the rat after gestational exposure to ionizing radiation. Neurotoxicol Teratol 10:363–371.3226380
Norton S, Kimler BF. 1990. Early effects of low doses of ionizing radiation on the fetal cerebral cortex in rats. Radiat Res 124:235–241.2247604
*NRC. 1993a. Pesticides in the diets of infants and children. Washington, DC: National Academy Press. National Research Council.
Nugis VY, Konchalovskii MV. 1993. Biological dosimetry, diagnosis, and treatment of bone-marrow syndrome in victims of the Chernobyl accident. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc., 349–384.
*Oak Ridge Associated Universities. 2003. Radiogardase-CS. Insoluble Prussian blue (ferric hexacyanoferrate, Fe_4_[Fe(CN)_6_]_3_). Information material package insert. http://www.orau.gov/reacts/prussian.htm
O’Brien DJ, Kaneene JB, Poppenga RH. 1993. The use of mammals as sentinels for human exposure to toxic contaminants in the environment. Environ Health Perspect 99:351–368.8319652
OECD. 1995. Chernobyl ten years on, radiological and health impact. Paris: Organization for Economical Cooperation and Development.
Ohi Y, Yamamura H, Watanabe M, . 2001. Intracellular cesium ion potentiates Ca^2+^ transients induced by depolarization in guinea pig vas deferens smooth muscle cells. Jpn J Pharmacol 85:173P.
Ohno T, Hess CT. 1994. Levels of ^137^Cs and ^40^K in wood ash-amended soils. Sci Total Environ 152:119–123.
*Olivier P, Marzin D. 1987. Study of the genotoxic potential of 48 inorganic derivatives with the SOS chromotest. Mutat Res 189:263–269.3118206
*Olsen CR, Thein M, Larsen IL, . 1989. Plutonium, lead-210, and carbon isotopes in the Savannah Estuary: Riverborne versus marine sources. Environ Sci Technol 23:1475–1481.
*Ondov JM, Choquette CE, Zoller WH, . 1989. Atmospheric behavior of trace elements on particles emitted from a coal-fired power plant. Atmos Environ 23(10):2193–2204.
Oostdam JV, Gilman A, Dewailly E, . 1999. Human health implications of environmental contaminants in Arctic Canada: A review. Sci Total Environ 230:1–82.10466227
Orel VE, Tereschenki VM, Czyatkovskaya NN, . 1998. Physical dosimetry and biological indicators of carcinogenic risk in a cohort of persons exposed to unhealthy ecological factors following the Chernobyl nuclear power plant accident. Arch Environ Health 53(6):398–404.9886158
Osanov DP, Kyruchkov VP, Panova VP. 1990. Skin absorbed doses from ground-deposited radioactive contaminants. At Energ 68(2):107–111.
Osanov DP, Krjuchkov VP, Shaks AI. 1993. Determination of beta radiation doses received by personnel involved in the mitigation of the Chernobyl accident. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc., 313–346.
*OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTA-BA-438.
*Oughton DH, Day JP. 1993. Determination of cesium, rubidium and scandium in biological and environmental materials by neutron activation analysis. J Radioanal Nucl Chem 174(1):177–185.
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
*Owens PN, Walling DE, He Q. 1996. The behaviour of bomb-derived caesium-137 fallout in catchment soils. J Environ Radioact 32(3):169–191.
Paasikallio A. 1984. The effect of time on the availability of ^90^Sr and ^137^Cs to plants from Finnish soils. Ann Agric Fenn 23(2):109–120.
*Paasikallio A. 1999. Effect of biotite, zeolite, heavy clay, bentonite and apatite on the uptake of radiocesium by grass from peat soil. Plant Soil 206:213–222.
*Paasikallio A, Rantavaara A, Sippola J. 1994. The transfer of cesium-137 and strontium-90 from soil to food crops after the Chernobyl accident. Sci Total Environ 155:109–124.7973616
Pacyna JM. 1995. The origin of Arctic air pollutants: lessons learned and future research. Sci Total Environ 160/161:39–53.
*Padovani L, Caprossi D, Tedeschi B, . 1993. Cytogenetic study in lymphocytes from children exposed to ionizing radiation after the Chernobyl accident. Mutat Res 319:55–60.7690459
*Palmer HE, Branson BM, Cohn SH, . 1976. Standard field methods for determining ^137^Cs and ^131^I in vivo. Health Phys 30:113.1244328
*Papastefanou C, Manolopoulou M, Ioannidou A, . 1989. Time-dependent radioactive concentrations of fallout following the Chernobyl reactor accident. Sci Total Environ 84:283–289.2772622
*Papastefanou C, Manolopoulou M, Sawidis T. 1992. Residence time and uptake of ^137^Cs in lichens and mosses at temperate latitude (40 °N). Environ Int 18:397–401.
*Paschal DC, Ting BG, Morrow JC, . 1996. Trace metals in urine of United States residents: Reference range concentrations. Environ Res A76:53–59.
*Patterson E, Szabo B, Scherlag BJ, . 1990. Early and delayed after depolarizations associated with cesium chloride-induced arrhythmias in the dog. J Cardiovasc Pharmacol 15:323–331.1689430
Paunow S, Laussmann D. 1980. Chromosomal bone-marrow changes after ^137^Cs incorporation in dsungaric hamsters. Radiobiol Radiother 21(1):30–35.
*Pearce J. 1995. Radiocesium in migratory bird species in Northern Ireland following the Chernobyl accident. Bull Environ Contam Toxicol 54:805–811.7647493
*Pendic B, Milivojevic K. 1966. Contamination interne au ^137^Cs par voie transcutanée et effet des moyens de décontamination et de protection sur la résorption transcutanée de ce radionuclide. Health Phys 12:1829–1830.
Pendleton RC, Mays CW, Lloyd RD, . 1965. A trophic level effect on ^137^Cs concentration. Health Phys 11:1503–1510 5894392
Pennington JAT, Capar SG, Parfitt CH, . 1996. History of the Food and Drug Administration’s total diet study (part II), 1987-1993. J AOAC Int 79(1):163–170.8620105
*Penttila S, Kairesalo T, Uusi-Rauva A. 1993. The occurrence and bioavailability of radioactive ^137^Cs in small forest lakes in southern Finland. Environ Pollut 82:47–55.15091798
*Petrow HG, Levine H. 1967. Ammonium hexacyanocobalt ferrate as an improved inorganic exchange material for determination of cesium-137. Anal Chem 39:360–362.6044881
Pham MK, Garnier J-M. 1998. Distribution of trace elements associated with dissolved compounds (<0.45 µm-1 nm) in freshwater using coupled (frontal cascade) ultrafiltration and chromatographic separations. Environ Sci Technol 32(4):440–449.
*Pietrzak-Flis Z, Krajewski P, Krajewska G, . 1994. Transfer of radiocesium from uncultivated soils to grass after the Chernobyl accident. Sci Total Environ 141:147–153.
Pietrzak-Flis Z, Rostek J, Lada W. 1988. Estimation of ^137^Cs and ^134^Cs body burden in Warsaw after the Chernobyl accident. Radiat Prot Dosim 25:101–105.
Pinsky C, Bose R. 1984. Pharmacological and toxicological investigations of cesium. Pharmacol Biochem Behav 21(Suppl. 1):17–23.6543004
*Pinsky C, Bose R, Dua AK, . 1980. Interdisciplinary studies on brain level determination and behavioral effects of cesium (Cs). Pharmacologist 22(3):158.
Pinsky C, Bose R, Taylor JR, . 1981. Cesium in mammals: Acute toxicity, organ changes and tissue accumulation. J Environ Sci Health Part A 16(5):549–567.
Pitkyanen GB. 1978. Effect of chronic irradiation of a pike Exxox lucius L. on its reproductive function. Tr Inst Ekol Rast Zhivotn, Ural Nauchn Tsentr, Akad Nauk SSSR 114:74–78.
*Platford RF, Joshi SR. 1989. Radionuclide partitioning across Great Lakes natural interfaces. Environ Geol Water Sci 14(3):183–186.
Pohl-Ruling J, Haas O, Brogger A, . 1991. The effect on lymphocyte chromosomes of additional radiation burden due to fallout in Salzburg (Austria) from the Chernobyl accident. Mutat Res 262:209–217.2002817
Polikarpov GG, Tsytsugina VG. 1993. Distribution of chromosome aberrations among hydrobiont cells under the effect of ionizing radiation and chemical mutagens of the environment. Radiobiologiia 33(2):205–213.8502736
Polyák K, Bódog I, Hlavay J. 1994. Determination of chemical species of selected trace elements in fly ash. Talanta 41(7):1151–1159.18966051
Pomerantseva MD, Ramaiya LK, Chekhovich AV, . 1993. Genetic effect of incorporated ^137^Cs in male mice after single injection of the isotope. Radiat Biol Radioecol 33(1):567–576.
Popov VY, Kutnyakov IV, Zhirnov VG, . 1995. Vertical distribution of ^90^Sr and ^137^Cs in alluvial sod soils in the near zone of the Chernobyl nuclear power plant. Euras Soil Sci 27(11):65–73.
Poston TM, Klopfer DC. 1988. Concentration factors used in the assessment of radiation dose to consumers of fish: A review of 27 radionuclides. Health Phys 55(5):751–766.3182280
Preston RJ, Dean BJ, Galloway S, . 1987. Mammalian in vivo cytogenetic assays: Analysis of chromosome aberrations in bone marrow cells. Mutat Res 189:157–165.3657831
Prisjazhniuk AY. 1993. Spatio-temporal models for incidence of malignant neoplasms in the area subjected to radioactive contamination after the Chernobyl accident. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc., 399–423.
*Prister BS, Omel’Yanenko NP, Yatnikova P. 1990. Migration of radionuclides in soil and their transfer to plants within the zone of the Chernobyl nuclear power plant accident. Sov Soil Sci 23(2):76–86.
*Probst T, Zeh P, Kim J-I. 1995. Multielemental determinations in ground water ultrafiltrates using inductively coupled plasma mass spectrometry and monostandard neutron activation analysis. Fresenius J Anal Chem 351:745–751.
Quastel MR, Goldsmith JR, Mirkin L, . 1997. Thyroid-stimulating hormone levels in children from Chernobyl. Environ Health Perspect Suppl 6:1497–1498.9467071
*Rabitsch H, Feenstra O, Kahr G. 1991. Radiocesium levels in humans over a four-year period. J Nucl Med 32:1491–1495.1908007
*Rabon EW. 1978. Calcium, strontium-89, strontium-90, and cesium-137 in pregnant white-tailed dear and related fetuses. DOE Symp Ser 45:682–690.
*Rabon EW, Johnson JE. 1973. Rapid field-monitoring of cesium-137 in white-tailed deer. Health Phys 25:515–516.4786582
Raghavendran KV, Satbhai PD, Abhyankar B, . 1978. Long-term retention studies of ^131^I and ^137^Cs and ^60^Co in Indian workers. Health Phys 34:185–188.632098
*Rahola T, Suomela M. 1998. The ^137^Cs content in Finnish people consuming foodstuffs of wild origin. Radiat Prot Dosim 79:187–189.
Ramaiya LK, Pomerantseva MD, Chekhovich AV, . 1993. [Genetic efficiency of incorporated ^137^Cs in male mice after long-term administration of the isotope.] Radiat Biol Radioecol 33(1):577–584. (Russian)
*Ramaiya LK, Pomerantseva MD, Chekhovich AV, . 1994. Genetic effects of testicular incorporation of ^137^Cs in mice. Mutat Res 324:139–145.7519738
Ramalho AT, Nascimento ACH. 1991. The fate of chromosomal aberrations in ^137^Cs-exposed individuals in the Goliania radiation accident. Health Phys 60(1):67–70.1983985
Ramalho AT, Nascimento ACH, Littlefield LG, . 1991. Frequency of chromosomal aberrations in a subject accidentally exposed to ^137^Cs in the Goiania (Brazil) radiation accident: Intercomparison among four laboratories. Mutat Res 252:157–160.2017205
Ramalho AT, Nascimento ACH, Natarajan AT. 1988. Dose assessments by cytogenic analysis in the Goiania (Brazil) radiation accident. Radiat Prot Dosim 25:97–100.
Ramboiu S, Derevenco P, Bordas E, . 1990. Effects of ingestion of radioactive cesium on behavioral indices in rats. Rev Roum Physiol 27(1):29–37.2094344
Ramzaev PV, Tarasov SI. 1976. [Hygienic evaluation of the combined effect of different types of harmful factors]. In: Liberman AN, ed. [Hygienic evaluation of factors of radiation and nonradiation natures and their combinations]. Leningrad, USSR: Leningradskii Nauchno-Issledovatel’skii Institut Radiatsionnoi Gigieny, 5–10. (Russian)
*Rank D, Maringer FJ, Terlunen J. 1990. The radioactivity of sediments in Danube reservoirs in Austria before and after the Chernobyl accident. Water Sci Technol 22(5):211–218.
*Rastogi RB, Singhal RL, Lapierre YD. 1980. Effects of rubidium and cesium on central catecholamines and locomotor behavior in rats. J Neurochem 34(6):1764–1767.7381502
Raven KP, Loeppert RH. 1997. Trace element composition of fertilizers and soil amendments. J Environ Qual 26:551–557.
Reddi PR, Nussbaum H, Wollin M, . 1974. Treatment of carcinoma of the cervix uteri with special reference to radium system. Obstet Gynecol 43(2):238–247.4589460
*Redman HC, McClellan RO, Jones RK, . 1972. Toxicity of ^137^CsCl in the beagle. Early biological effects. Radiat Res 50:620–648.
Reish DJ, Geesey GG, Wilkes FG, . 1982. Marine and estuarine pollution. J Water Pollut Control Fed 54(6):786–811.
Remez VP, Sapozhnikov YA. 1996. The rapid determination of caesium radionuclides in water systems using composite sorbents. Appl Radiat Isot 47(9–10):885–886.8976043
Renaud P, Pourcelot L, Metivier J-M, . 2003. Mapping of ^137^Cs deposition over eastern France 16 years after the Chernobyl accident. Sci Total Environ 309:257–264.12798109
*Reuter H, Stevens CF. 1980. Ion conductance and ion selectivity of potassium channels in snail neurones. J Membr Biol 57:103–118.6259361
*Richmond CR, Furchner JE. 1961. Enhancement of cesium^137^ excretion by rats fed potassium-supplemented diets. Proc Soc Exp Biol Med 108:797–798.14492010
*Richmond CR, Furchner JE, Langham WH. 1962. Long-term retention of radiocesium by man. Health Phys 8:201–205.14492005
*Richter T, Schroder G, Kaminski S, . 1993. Transport of particles contaminated with cesium radionuclides into the sediment of Lake Constance. Water Sci Technol 28:117–121.
*Riga-Karandinos AN, Karandinos MG. 1998. Caesium-137 concentrations and ecological half-lives in three epiphytic lichen species from southern Greece (Megalopolis). Bryologist 101(3):422–427.
Riget F, Johansen P, Asmund G. 1997. Baseline levels and natural variability of elements in three seaweed species from west Greenland. Mar Pollut Bull 34(3):171–176.
*Risica S, Grisanti G, Tancredi F, . 1994. A study on some stable elements and radionuclides in human milk. ACH Models Chem 131:651–660.
Rivera J. 1965. Dietary intakes and body burdens of cesium-137. Radiol Health Data Rep 6(9):504–506.5830537
*Robb P, Owen LMW, Crews HM. 1995. Stable isotope approach to fission product element studies of soil-to-plant transfer and in vitro modelling of ruminant digestion using inductively coupled plasma mass spectrometry. J Anal Atom Spectrom 10:625–629.
*Robbins JA, Mudroch A, Oliver BG. 1990. Transport and storage of ^137^Cs and ^210^Pb in sediments of Lake St. Clair. Can J Fish Aquat Sci 47:572–587.
Roberto B, Gemignani F, Morizzo C, . 1998. Cytogenetic damage in lymphocytes of healthy and thyroid tumor-affected children from the Gomel region (Belarus). Mutat Res 405:89–95.9729299
*Robinson WL, Phillips WA. 1989. Estimates of the radiological dose form ingestion of ^137^Cs and ^90^Sr to infants, children, and adults in the Marshall Islands. Livermore, CA: Lawrence Livermore National Laboratory.
Roca MC, Vallejo VR, Roig M, . 1997. Prediction of cesium-134 and strontium-85 crop uptake based on soil properties. J Environ Qual 26:1354–1362.
Romanenko AM, Gaiyrov AG. 1998. Particular features of morphogenesis of transition cell tumors of human urinary bladder in Ukraine after Chernobyl accident. Lik Sprava 26(3):11–14.
*Ropolo R, Cesana P. 1997. ^137^Cs urinary excretion by northwestern Italians ten years after the Chernobyl accident. Health Phys 73(3):498–501.9287092
Rosen K, Eriksson A, Haak E. 1996. Transfer of radiocesium in sensitive agricultural environments after the Chernobyl fallout in Sweden. I. County of Gavleborg. Sci Total Environ 182:117–133.8854942
Rosen K, Haak E, Eriksson A. 1998. Transfer of radiocesium in sensitive agricultural environments after the Chernobyl fallout in Sweden: III. County of Vasternorrland. Sci Total Environ 209:91–105.9514031
*Rosenthal JJ, de Almeida CE, Mendonca AH. 1991. The radiological accident in Goiania: The initial remedial actions. Health Phys 60(1):7–15.
*Rosoff B, Cohn SH, Spencer H. 1963. Cesium-137 in man. Radiat Res 19:643–654.14062237
*Rowan DJ, Chant LA, Rasmussen JB. 1998. The fate of radiocesium in freshwater communities- why is biomagnification variable both within and between species? J Environ Radioact 40(1):15–36.
Rowan JS, Walling DE. 1992. The transport and fluvial redistribution of Chernobyl-derived radiocesium within the River Wye basin, UK. Sci Total Environ 121:109–131.1439724
Ruhm W, Kammerer L, Hiersch L, . 1996. Migration of ^137^Cs and ^134^Cs in different forest soil layers. J Environ Radioact 33(1):63–75.
*Rundo J. 1964. A survey of the metabolism of caesium in man. Br J Radiol 37:108–114.14120787
Rundo J. 1965. A case of accidental inhalation of irradiated uranium. Br J Radiol 38:39–50.14236020
*Rundo J, Newton D. 1964. Increase in the cesium-137 content of man due to radioactive fallout, 1962-1964. Nature 203:537–538.14202389
Rundo J, Richmond CR. 1970. Altitude effect on the biological half life of caesium in man. Nature 225:83–84.5410208
*Rundo J, Turner FM. 1966. Metabolism of caesium-137 during pregnancy. British Atomic Energy Research Establishment Progress Report, AEKE-PR/HPM 11, 32.
Rundo J, Turner FM. 1967. Metabolism of caesium-137 during pregnancy. British Atomic Energy Research Establishment Progress Report, AEKE-PR/HPM 12, 34.
*Rundo J, Mason JI, Newton D, . 1963. Biological half-life of caesium in man in acute chronic exposure. Nature 200:188–189.14073052
*Ruse ME, Peart MR. 2000. Intrasite sampling of Hong Kong soils contaminated by caesium-137. Chemosphere 41:45–51.10819178
Russell WL, Kelly EM. 1982. Mutation frequencies in male mice and the estimation of genetic hazards of radiation in men. Proc Natl Acad Sci U S A 79:542–544.6952206
*Rybacek K, Wilhelmova L, Tomasek M. 1994. Behavior of radiocesium in atmospheric aerosol and fallout in Prague. J Radioanal Nucl Chem 186(3):245–255.
*Saad AY, Abdelazim AA, El-Khashab MM, . 1991. Effects of gamma radiation on incisor development of the prenatal albino mouse. J Oral Pathol Med 20:385–388.1941655
*Saad AY, Abdelazim AA, El-Khashab MM, . 1994. Induction of cleft palate by gamma-irradiation of prenatal CD-1 mice. Cleft Palate Craniofac J 31(5):351–355.7986795
Sachdev P, Sachdev MS, Deb DL. 1995. Adsorption-desorption of radiocaesium (^137^Cs) in semi-arid and tropical soils. J Nucl Agric Biol 24(4):201–209.
Sachdev P, Sachdev MS, Deb DL. 1998. The uptake and transfer of caesium-137, strontium-90 and zinc-65 from soil to food crops in tropical environment. J Nucl Agric Biol 27(1):1–9.
*Saliba W, Erdogan O, Niebauer M. 2001. Case Reports: Polymorphic ventricular tachycardia in a woman taking cesium chloride. PACE 24(4 Pt 1):515–517.11341093
Sanchez AL, Schell WR. 1986. Uptake mechanisms for Co-60, Sr-85, Cs-137 on peat. Health Phys 50(Suppl. 1):S87.
*Sanchez AL, Wright SM, Smolders E, . 1999. High plant uptake of radiocesium from organic soils due to Cs mobility and low soil K content. Environ Sci Technol 33:2752–2757.
*Santos-Mello R, Schmidt T, Neuhauss E. 1999. Induction of micronuclei by CsCl in vivo and in vitro. Mutat Res 446:239–244.10635347
*Santos-Mello R, Deimling LI, Almeida A. 2001. Induction of micronuclei in mouse polychromatic erythrocytes by the administration of nonradioactive CsCl by the oral and intraperitoneal route. Mutat Res 497(1–2):147–151.11525917
*Sarkka J, Keskitalo A, Luukko A. 1996. Temporal changes in concentration of radiocesium in lake sediment and fish of southern Finland as related to environmental factors. Sci Total Environ 191:125–136.8885427
Sauras T, Roca MC, Tent J, . 1994. Migration study of radionuclides in a Mediterranean forest soil using synthetic aerosols. Sci Total Environ 157:231–238.
*Sawidis T, Drossos E, Heinrich G, . 1990. Cesium-137 accumulation in higher plants before and after Chernobyl. Environ Int 16:163–169.
Sbrignadello G, Degetto S, Battiston GA, . 1994. Distribution of ^210^Pb and ^137^Cs in snow and soil samples from Antarctica. Int J Environ Anal Chem 55:235–242.
Schell WR, Tobin MJ, Massey CD. 1989. Evaluation of trace metal deposition history and potential element mobility in selected cores from peat and wetland ecosystems. Sci Total Environ 87/88:19–42.
Schimmack W, Bunzl K. 1992. Migration of radiocesium in two forest soils as obtained from field and column investigations. Sci Total Environ 116:93–107.1411495
*Schull WJ, Otake M. 1999. Cognitive function and prenatal exposure to ionizing radiation. Teratology 59:222–226.10331523
*Schull WJ, Otake M, Yoshimaru H. 1988. Effect on intelligence test score of prenatal exposure to ionizing radiation in Hiroshima and Nagasaki: A comparison of the T65DR and DS86 dosimetry systems. Radiation Effects Research Foundation. RERF TR 3-88. Research project 24-62.
*Schuller P, Ellies A, Kirchner G. 1997. Vertical migration of fallout ^137^Cs in agricultural soils from Southern Chile. Sci Total Environ 193:197–205.
Schwarz G, Dunning DE. 1982. Imprecision in estimates of dose ingested ^137^Cs due to variability in human biological characteristics. Health Phys 43(5):631–645.7152925
Seel JF, Whicker FW, Adriano DC. 1995. Uptake of ^137^Cs in vegetable crops grown on a contaminated lakebed. Health Phys 68(6):793–799.7759257
Seelye JG, Hesselberg RJ, Mac MJ. 1982. Accumulation by fish of contaminants released from dredged sediments. Environ Sci Technol 16:459–464.
Sekimoto H, Nakamura H, Takagi N. 1996. Toxicity of radioactive wastes discharged from nuclear energy center in the future equilibrium state. Ann Nucl Energy 23(8):663–668.
Senekowitsch R, Kriegel H. 1984. Diaplacental transfer and distribution of some radionuclides in fetal organs at different stages of gestation - experimental results. EUR 8067:183–197.
*Senges JC, Sterns LD, Freigang KD, . 2000. Cesium chloride induced ventricular arrhythmias in dogs: three-dimensional activation patterns and their relation to the cesium dose applied. Basic Research in Cardiology 95(2):152–162.10826508
*Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
Sevan’Kaev AV, Lloyd DC, Potetnya OI, . 1995. Chromosomal aberrations in lymphocytes of residents of areas contaminated by radioactive discharge from the Chernobyl accident. Radiat Prot Dosim 58(4):247–254.
Shah KR, Filby RH, Davis AI. 1971. Determination of trace elements in tea and coffee by neutron activation analysis. Int J Environ Anal Chem 1:63–73.5162054
Shappard SC, Evenden WG, Schwartz WJ. 1995. Ingested soil: Bioavailability of sorbed lead, cadmium, cesium, iodine, and mercury. J Environ Qual 24:498–505.
Sharma A, Das T, Ghosh BB, . 1991. Chromosomal alterations induced by newer metals used in industry. Am J Hum Genet 49(4):451.
*Shenber MA, Johanson KJ. 1992. Influence of zeolite on the availability of radiocesium in soil to plants. Sci Total Environ 113:287–295.1325669
Sheppard MI, Thibault DH. 1991. A four-year mobility study of selected trace elements and heavy metals. J Environ Qual 20:101–114.
Sheppard SC, Evenden WG, Schwartz WJ. 1995. Ingested soil: Bioavailability of sorbed lead, cadmium, cesium, iodine, and mercury. J Environ Qual 24:498–505.
Shilov VP. 1980. [Metabolism of ^137^Cs in pigs in relation to age.] S-kh Biol 15(5):766–769. (Russian)
*Shiraishi K, Tagami K, Ban-nai T, . 1997. Daily intakes of ^134^Cs, ^137^Cs, ^40^K, ^232^Th, and ^238^U in Ukranian adult males. Health Phys 73(5):814–819.9378658
Shubik VM. 1975. Effect of Cs^137^ on immunological reactivity (Review of the literature). J Hyg Epidemiol Microbiol Immunol 19(3):271–278.
Shubik VM, Nevstrueva MA, Kal’nitskii SA, . 1978a. A comparative study of changes in immunological reactivity during prolonged introduction of radioactive and chemical substances into the organism with drinking water. J Hyg Epidemiol Microbiol Immunol 22(4):408–401.
Shubik VM, Nevstrueva MA, Kal’nitskii SA, . 1978b. Comparative study of changes of immunological reactivity during chronic administration of radioactive and chemical substances in the drinking water. Zh Gig Epidemiol Mikrobiol Immunol 22(4):374–380.
Shutov VN, Bruk GY, Balonov MI, . 1993. Cesium and strontium radionuclide migration in the agricultural ecosystem and estimation of internal doses to the population. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc., 167–219.
Shutov VN, Bekyasheva TA, Basalayeva LN, . 1994. Effect of soil properties on ^137^Cs and ^90^Sr uptake by native grasses. Euras Soil Sci 26(7):88–95.
Sikov MR, Meznarich HK, Traub RJ. 1991. Comparison of placental transfer and localization of caesium strontium and iodine in experimental animals and women. Int J Radiat Biol 60(3):553–555.1679097
Simon N, Silverstone SM. 1978. New miniaturized cesium-137 for needle implants. Int J Nucl Med Biol 5:167–169.744694
Simon SL, Graham JC. 1994. Results of a nationwide radiological monitoring program in the Marshall Islands. Health Phys 66(6):S14.
*Simon SL, Graham JC. 1998. A comparison of aerial and ground level measurements of ^137^Cs in the Marshall Islands. Environ Monit Assess 53:363–377.
Sirotkin AN, Shilov VP, Panchenko IYA, . 1976. Kinetics of the accumulation excretion of 90Sr and ^137^Cs in cattle of different ages. S-kh Biol 11(4):538–542.
*Sjodin RA, Beauge LA. 1967. The ion selectivity and concentration dependence of cation active sodium transport in squid axons. Curr Mod Biol 1:105–115.6060857
*Skandalis A, da Cruz AD, Curry J, . 1997. Molecular analysis of T-lymphocyte HPRT mutations in individuals exposed to ionizing radiation in Goiania, Brazil. Environ Mol Mutagen 29:107–116.9118962
Skarlou V, Papanicolaou EP, Nobeli C. 1996. Soil to plant transfer of radioactive cesium and its relation to soil and plant properties. Geoderma 72:53–63.
Snipes MB, Boecker BB, McClellan RO. 1983. Retention of monodisperse or polydisperse aluminosilicate particles inhaled by dogs, rats, and mice. Toxicol Appl Pharmacol 69:345–362.6879606
Sora S, Magni GE. 1988. Induction of meiotic chromosomal malsegregation in yeast. Mutat Res 201:375–384.3050489
Spalding BP. 1994. Volatization of cesium-137 from soil with chloride amendments during heating and vitrification. Environ Sci Technol 28:1116–1123.22176238
Spruill MD, Nelson DO, Ramsey MJ, . 2000. Lifetime persistence and clonality of chromosome aberrations in the peripheral blood of mice acutely exposed to ionizing radiation. Radiat Res 153(1):110–121.10630984
*Stara JF. 1965. Tissue distribution and excretion of cesium-137 in the guinea pig after administration by three different routes. Health Phys 11:1195–1202.5879911
*Stara JF, Thomas RG. 1963. The tissue distribution and excretion of cesium-137 following inhalation: Preliminary data for rats. AEC Res Dev Rep LF-4.
Stather JW, Phipps AW. 1998. The work of committee 2 of ICRP in developing dose coefficients for the embryo and fetus. Radiat Prot Dosim 79:299–302.
Stather JW, Phipps AW. 1999. The work of committee 2 of ICRP in developing dose coefficients for the embryo and fetus following intakes of radionuclides by the mother. Kerntechnik 64:15–20.
*Steele AK. 1990. Derived concentration factors for caesium-137 in edible species of North Sea fish. Mar Pollut Bull 21(12):591–594.
Steinnes E, Rambaek JP, Hanssen JE. 1992. Large scale multi-element survey of atmospheric deposition using naturally growing moss as biomonitor. Chemosphere 25(5):735–752.
Stetar EA, Boston HL, Larsen IL, . 1993. The removal of radioactive cobalt, cesium, and iodine in a conventional municipal wastewater treatment plant. Water Environ Res 65(6):630–639.
Stradling GN, Stather JW, Gray SA, . 1989. Assessment of intake of an actinide-bearing dust formed form the pond storage of spent magnox fuel. Radiat Prot Dosim 26(1/4):201–206.
Strebl F, Gerzabek MH, Karg V, . 1996. ^137^Cs-migration in soils and its transfer to roe deer in an Austrian forest stand. Sci Total Environ 181:237–247.8820439
*Strezov A, Stoilova T, Jordanova A, . 1999. Determination of caesium and natural radionuclide concentrations in sediments, algae and water in the Bulgarian Black Sea coast. Water Sci Technol 39(8):21–26.
Suchanek TH, Lagunas-Solar MC, Raabe OG, . 1996. Radionuclides in fishes and mussels from the Farallon Islands nuclear waste dump site, California. Health Phys 71(2):167–178.8690599
Sugai SF. 1990. Transport and sediment accumulation of ^210^Pb and ^137^Cs in two southeast Alaskan Fjords. Estuaries 13(4):380–392.
Sugiura N, Kusama T. 1992. Biokinetics of radionuclides in pregnant mice and compartment models by the system analysis methods. Radiat Prot Dosim 41(2/4):153–156.
*Sun LC, Clinton JH, Kaplan E, . 1997. ^137^Cs exposure in the Marshallese populations: an assessment based on whole-body counting measurements (1989-1994). Health Phys 73:86–99.9199220
Surkova LV, Pogodin RI. 1991. Status forms of occurrence of cesium-137 in soils as a function of distance from the Chernobyl nuclear power plant. Sov Soil Sci 23(10):100–103.
Suzuki M, Nakano K, Suzuki K, . 2000. Influence of the sampling time on chromosomal aberrations at G^2^ phase in Syrian hamster embryonic cells irradiated with different types of radiation. Int J Radiat Biol 76(6):815–821.10902736
*Szabo B, Patterson E, Scherlag B, . 1987. Early afterdepolarizations induced by Cs^+^ are dependent on intra- and extracellular [Ca^2+^] and [Na^+^]. Circulation 76:IV–115.
Szabo B, Sweidan R, Lazzara R. 1985. Cs-induced potentials in purkinje fibers of guinea pig hearts. Fed Proc 44:806.
Szentkuti VL, Breitruck H, Giese W. 1976. [The accumulation of cesium-134 in heart and skeletal muscle of healthy and muscular dystrophic golden hamsters]. Z Versuchstierkd 18(3):121–129. (German)1266430
Takahashi N, Ito M, Ishida S, . 1992. Effects of vagal stimulation on cesium-induced early after depolarizations and ventricular arrhythmias in rabbits. Circulation 86:1987–1992.1451270
*Takenaka C, Onda Y, Hamajima Y. 1998. Distribution of cesium-137 in Japanese forest soils: Correlation with the contents of organic carbon. Sci Total Environ 222:193–199.9851070
*Talbot RJ, Newton D, Segal MG. 1993. Gastrointestinal absorption by rats of ^137^Cs and ^90^Sr from U_3_O_8_ fuel particles: Implications for radiation doses to man after a nuclear accident. Radiat Prot Dosim 50(1):39–43.
Tamura T. 1965. Experimental studies on the effect of internal exposure of Cs-137 on the male reproductive organ. The distribution of the Cs-137 in mice body and histological changes of testis by its exposure. II. Jpn J Hyg 20(5):320–328.
Tandon L, Iyengar GV, Parr RM. 1998. A review of radiologically important trace elements in human bones. Appl Radiat Isot 49(8):903–910.9650262
*Tanizaki Y, Shimokawa T, Yamazaki M. 1992. Physico-chemical speciation of trace elements in urban streams by size fractionation. Water Res 26(1):55–63.
*Taskaev E. 1987. Neutron-activation determination of rubidium and caesium in mineral waters. J Radioanal Nucl Chem 118:319–322.
Tempel K. 1997. Influence on species of animal on radionuclide metabolism. Berl Muench Tieraerzl Wochenschr 110:451–455.
Thiry Y, Vanhouche M, Van Der Vaeren P, . 1994. Determination of the physico-chemical parameters which influence the Cs availability in forest soils. Sci Total Environ 157:261–265.
*Thomas PA, Gates TE. 1999. Radionuclides in the lichen-caribou-human food chain near uranium mining operations in northern Saskatchewan, Canada. Environ Health Perspect 107(7):527–537.
Thomas RG, Thomas RL. 1968. Long-term retention of ^137^Cs in the rat. Health Phys 15:83–84.5743763
Thompson DF, Church CO. 2001. Prussian blue for treatment of radiocesium poisoning. Pharmacotherapy 21(11):1364–1367.11714209
*Thornberg C, Mattsson S. 2000. Increased ^137^Cs metabolism during pregnancy. Health Phys 78(5):502–506.10772022
*Toader M, Vasilache RA, Toader ML, . 1996. Cs^137^ transfer from mother to embryos, in the first three years after the Chernobyl accident. In: International Congress, ed. International congress on radiation protection: Ninth international congress of the International Radiation Protection Association, April 14-19, Congress Center Hofburg, Vienna, Austria: proceedings. Vol. 2. Seibersdorf, Austria: International Radiation Protection Association, 473–475.
*Tobari I, Matsuda Y, Xiaohung G, . 1988. Dose-response relationship for translocation induction in spermatogonia of the crab-eating monkey (Macaca fascicularis) by chronic γ-ray-irradiation. Mutat Res 201:81–87.3419451
*Todorovic D, Popovic D, Djuric G. 1999. Concentration measurements of ^7^Be and ^137^Cs in ground level air in the Belgrade city area. Environ Int 25(1):59–66.
Tomioka N, Uchiyama H, Yagi O. 1994. Cesium accumulation and growth characteristics of Rhodococcus erythropolis CS98 and Rhodococcus sp. strain CS402. Appl Environ Microbiol 60(7):2227–2231.16349312
Tondel M, Carlsson G, Hardell L, . 1996. Incidence of neoplasms in ages 0-19 Y in parts of Sweden with high ^137^Cs fallout after the Chernobyl accident. Health Phys 71(6):947–950.8919079
Travnikova IG, Bruk GY, Shutov VN. 1999. Dietary pattern and content of cesium radionuclides in foodstuffs and odies of Braynsk Oblast rural population after the Chernobyl accident. Radiochemistry 41(3):298–301.
TRI97. 2000. Toxics Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI99. 2001. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Offices of Environmental Information. U.S. Environmental Protection Agency. Toxic Release Inventory. http://www.epa.gov/triexplorer. April 18, 2001.
*Tyler SA, Kretz ND, Norris WP. 1969. Dependence of ^137^Cs retention on age in the fetal and juvenile beagle dog. AEC Symp Ser 17:191–204.
Uchiyama M. 1977. Estimation of ^137^Cs body burden in Japanese: I. The ratio of ^137^Cs in the urine to that in the total excreta following the continuous intake of ^137^Cs in fall-out. J Radiat Res 18:239–246.926069
Ugedal O, Jonsson B, Njastad O, . 1992. Effects of temperature and body size on radiocaesium retention in brown trout, Salmo trutta. Freshwater Biol 28:165–171.
*Ulsh B, Rademacher S, Whicker FW. 2000. Variations of ^137^Cs depositions and soil concentrations between alpine and montane soils in northern Colorado. J Environ Radioact 47:57–70.
*UN. 1998. Resolution 1172 (1998). United Nations. http://srch0.un.org:80/plweb-cgi/fa…emplateName=predoc.tmpl&setCookie=1. March 23, 2001.
UNSCEAR. 1977. Sources and effects of ionizing radiation: UNSCEAR 1977 report to the general assembly, with annexes. United Nations Scientific Committee on the Effects of Atomic Radiation. New York: United Nations.
*UNSCEAR. 1996. Sources and effects of ionizing radiation: UNSCEAR 1996 report to the general assembly, with scientific annex. United Nations Scientific Committee on the Effects of Atomic Radiation. New York: United Nations.
*USGS. 1999. Cesium: Mineral commodity summary 1999. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/cesium. August 29, 2000.
*USNRC. 1983. Metabolic data and retention functions for the intracellular alkali metals. Washington, DC: U.S. Nuclear Regulatory Commission. NUREG/CR-3245. ORNL/TM-8630. DOE 40-550-75.
*USNRC. 1984. Lower limit of detection: Definition and elaboration of a proposed position for radiological effluent and environmental measurements. Washington, DC: U.S. Nuclear Regulatory Commission. NUREG/CR-4604.
*USNRC. 1991. Nuclear regulatory commission digest. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20, appendix B.
*USNRC. 1993. Radioactive materials released from nuclear power plants: Annual report 1993. Washington, DC: U.S. Nuclear Regulatory Commission. NUREG/CR-2907. BNL-NUREG-51581.
*USNRC. 1997. Minimum detectable concentrations with typical radiation survey instruments for various contaminants and field conditions. Rockville, MD: U.S. Nuclear Regulatory Commission. U.S. Report NUREG-1507.
*USNRC. 1998. Probabilistic accident consequence uncertainty analysis: Uncertainty assessment for internal dosimetry. Vol 1 and 2. Commission of European Communities. U.S. Nuclear Regulatory Committee. NUREG/CR-6571. EUR 16773. SAND98-0119.
*USNRC. 1999a. Annual limits on intake (ALIs) and derived air concentrations (DACs) of radionuclides for occupational exposure; Effluent concentrations; Concentrations for release to sewerage. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20 App B.
*USNRC. 1999b. Quantities of licensed material requiring labeling. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20 App C.
*Vandecasteele CM, Van Hees M, Culot JP, . 1989. Radiocaesium metabolism in pregnant ewes and their progeny. Sci Total Environ 85:213–223.2814449
Vandelannoote R, Blommaert W, Gijbels R, . 1981. Analysis of geothermal waters by spark source mass spectrometry. Fresenius Z Anal Chem 309:291–294.
Vandrot M, Scharbach H, Raylaud G, . 1979. Cesium. Encephale 5(4):359–374.230026
Van Middlesworth L. 1993. ^129^I and ^137^Cs fission products in thyroids of animals, 1984-1991. Health Phys 64(1):52–58.8416215
Varskog P, Naeumann R, Steinnes E. 1994. Mobility and plant availability of radioactive Cs in natural soil in relation to stable Cs, other alkali elements and soil fertility. J Environ Radioact 22:43–53.
Vasilenko II. 1991. Carcinogenic hazards of radioactive cesium. Vopr Onkol 37(4):394–400.1887639
*Vertacnik A, Prohic E, Juracic M, . 1997. Selected element concentrations in alluvial sediments under garbage disposal site (Zagreb, Croatia). Water Res 31(6):1421–1429.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Voigt G, Muller H, Paretzke HG, . 1993. ^137^Cs transfer after Chernobyl from fodder into chicken meat and eggs. Health Phys 65(2):141–146.8330959
Vykhovanets EV, Chernyshov VP, Slukvin II, . 2000. Analysis of blood lymphocyte subsets in children living around Chernobyl exposed long-term to low doses of cesium-137 and various doses of iodine-131. Radiat Res 153(1):110–121.10630984
Wang CC. 1980. Treatment of malignant tumors of the nasopharynx. Otolaryngol Clin North Am 13(3):477–481.7443238
Wang S. 1988. The dependence of thermoluminescence response and glow curve structure of LiF (Mg, Cu, P) TL materials on Mg, Cu, P dopants concentration. Radiat Prot Dosim 25:133–136.
Ward NI, Savage JM. 1994. Metal dispersion and transportational activities using food crops as biomonitors. Sci Total Environ 146/147:309–319.7517069
Warren CJ, Dudas MJ. 1988. Leaching behaviour of selected trace elements in chemically weathered alkaline fly ash. Sci Total Environ 76:229–246.
*Watson WS. 1987. Human radiocesium levels in Scotland. In: Hamphill DD, ed. Trace substances in environmental health-XXI: Proceedings of the University of Missouri’s 21^st^ annual conference on trace substances in environmental health. Columbia, Missouri: University of Missouri, 232–236.
Watson WS, Sumner DJ, Baker JR, . 1999. Radionuclides in seals and porpoises in the coastal waters around the UK. Sci Total Environ 234:1–13.10507144
Wellner U. 1989. A pharmacokinetic approach to investigate the uptake of ^137^Cs by children after the reactor accident in Chernobyl. Nucl Med Commun 28:243–246.
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*WHO. 1983. Selected radionuclides: Tritium, carbon-14, krypton-85, strontium-90, iodine, caesium-137, radon, plutonium. Environmental Health Criteria 25. Geneva: World Health Organization.
*Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Vol II: The elements Part A. New York: Academic Press.
Wiley LM, Baulch JE, Raabe OG, . 1997. Impaired cell proliferation in mice that persists across at least two generations after paternal irradiation. Radiat Res 148:145–151.9254733
*Willey NJ, Martin MH. 1995. Annual patterns of Cs-133 concentrations in British upland vegetation. Chemosphere 30(4):717–724.
Willey NJ, Martin MH. 1997. A comparison of stable caesium uptake by six grass species of contrasting growth strategy. Environ Pollut 95(3):311–317.15093445
*Wright EM. 1972. Mechanisms of ion transport across the choroid plexus. J Physiol 226:545–571.4538945
Wyoff MH. 1971. Distribution of ^134^Cs in the conceptus of the pregnant rat. Radiat Res 47:628–634.5119582
Xie S, Matthew F, Adomat H, . 2001. Pharmacokinetics studies in mice with cesium chloride, a possible high pH therapeutic reagent for prostate cancer. Proc Am Assoc Cancer Res 42:381.
*Yamagata N, Iwashima K. 1966. Distribution of cesium and rubidium in human blood. Nature 211:528–529.5967494
Yamamoto N, Kasai M. 1982. Inhibition of a voltage-dependent cation channel in sarcoplasmic reticulum vesicles by cesium studied by using a potential-sensitive cyanine dye. Biochim Biophys Acta 692:89–96.6293561
Yanagi T, Tatanabe M, Yamamoto K. 1989. Sorption behavior of cesium and strontium ions on mixtures of clay sorbents. 26(9):861–864.
*Yasuda H, Uchida S, Muramatsu Y, . 1995. Sorption of manganese, cobalt, zinc, strontium, and cesium onto agricultural soils: Statistical analysis on effects of soil properties. Water Air Soil Pollut 83:85–96.
Yoshida S, Muramatsu Y. 1994. Accumulation of radiocesium in basidiomycetes collected from Japanese forests. Sci Total Environ 157:197–205.
Yoshimoto Y, Kato H, Schull WJ. 1988. Risk of cancer among children exposed in utero to A-bomb radiations, 1950-1984. Lancet 2(8612):665–669.2901525
*Yoshioka M, Kitahar K, Keida Y, . 1976. Strontium-90 and cesium-137 in human placenta. Acta Med Univ Kagoshima 18:113–117.
Zapoliskaya NA, Lavrentlev LF, Zhorno LYA. 1973. Carcinogenic effect in continuous uptake of some radionuclides and chronic external irradiation. Vopr Onkol 19(9):80–85.
Zhorno L, Iakovleva NG. 1974. Radiation injury to the sexual and somatic cells of rats with a chronic intake of radionuclides. Radiobiologiia 14(1):123–125.4821630
Zhu S, Xia F, Yang W. 1997a. [Comparison of chromosomal aberration induced by signal radionuclide ^134^Cs in somatic and germ cells.] Zhong Fan Yixue Yu Fanghu Zazhi 17(4):239–242. (Chinese)
Zhu S, Xia F, Yang W. 1997b. [Effect of chromosomal aberrations in spermatogonia induced by ^134^Cs retention in germ cells.] Fushe Fanghu 17(3):208–211. (Chinese)
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
*Zundel WS, Tyler FH, Mays CW, . 1969. Short half-times of caesium-137 in pregnant women. Nature 221:89–90.
Zvonova IA, Balonov MI. 1993. Radioiodine dosimetry and prediction of consequences of thyroid exposure of the Russian population following the Chernobyl accident. In: Merwin SE, Balonov MI, eds. The Chernobyl papers: Doses to the Soviet population and early health effects studies. Vol. 1. Richland, WA: Research Enterprises, Inc., 125.