# 8 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding stable cesium in air, water, and other media are summarized in Table 8-1. The regulations regarding radioactive cesium are summarized in Table 8-2.

No MRLs were derived for inhalation or oral exposure to stable or radioactive cesium. Two MRLs, derived by the Agency for Toxic Substances and Disease Registry (1999) for external exposure to ionizing radiation, are applicable to external exposure to radioisotopes of cesium. An MRL of 400 mrem (4.0 mSv) was derived for acute-duration external exposure (14 days or less), based on cognitive learning deficit in children who had been exposed to ionizing radiation at critical stages of fetal development (gestation weeks 8–15) during the atomic bombing of Hiroshima and Nagasaki (Schull et al. 1988). An MRL of 100 mrem/year (1.0 mSv/year) above background was derived for chronic-duration external exposure (365 days or more), based on the BEIR V (1990) report that the average annual effective ionizing radiation dose to the U.S. population is 360 mrem/year (3.6 mSv/year), a dose not expected to produce adverse health effects.

The EPA has not derived reference concentrations (RfCs) or reference doses (RfDs) for stable or radioactive cesium (IRIS 2002). The IRIS database does not provide cancer assessments for radioisotopes of cesium. This function is the responsibility of the EPA Office of Radiation and Indoor Air (ORIA). All radionuclides, including radioisotopes of cesium, are classified as known human (Group A) carcinogens. This classification is based on results of epidemiological studies of Japanese atomic bomb survivors, underground uranium miners, radium dial painters, and patients subjected to a variety of radiation treatments, as well as results of laboratory animal research and mammalian tissue culture studies. ORIA has published cancer slope factors (mortality and morbidity cancer risk estimates) for all known radionuclides, by various exposure routes (inhalation, drinking water ingestion, food ingestion, soil ingestion, immersion in a cloud, and external exposure from contaminated soil) for five age groups and 14 radiogenic cancer sites (EPA 2000). Slope factors for ^137^Cs and ^134^Cs are listed in Table 8-2.

Table 8-1 Regulations and Guidelines Applicable to Cesium

Agency | | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
| IARC | | No data | IARC 2000
[underlined: NATIONAL]
Regulations and Guidelines:
a. | Air
a. | ACGIH | TLV (8-hour TWA for a 40-hour workweek) | | ACGIH 2000, 2001
a. | ACGIH | Cesium hydroxide (based on upper respiratory tract, skin, and eye irritation) | 2 mg/m^3^
a. | EPA | | No data
a. | NIOSH | REL (10-hour TWA for a 40-hour workweek | | NIOSH 1992, 2000
a. | NIOSH | Cesium hydroxide (based on skin, eye, and respiratory irritation) | 2 mg/m^3^
a. | OSHA | | No data
b. | Water | | No data
c. | Food | | No data
d. | Other | | No data
[underlined: STATE] | | | No data

ACGIH = American Conference of Governmental Industrial Hygienists; EPA = Environmental Protection Agency; IARC = International Agency for Research on Cancer; NIOSH = National Institute for Occupational Safety and Health; OSHA = Occupational Safety and Health Administration; REL = recommended exposure limit; TLV = threshold limit value; TWA = time weighted average

Table 8-2 Regulations and Guidelines Applicable to Radioactive Cesium

Agency | | Description | Information | | Reference
[underlined: INTERNATIONAL]
Guidelines:
| IARC | | No data | | IARC 2000
[underlined: NATIONAL]
Regulations and Guidelines:
a. | Air
a. | ACGIH | | No data | | ACGIH 2000
a. | EPA | Detection limits for man-made beta particle and photon emitters | 10 pCi/L | | EPA 1999a; 40 CFR 141.25
a. | NIOSH | | No data | | NIOSH 2000
a. | NRC | Effluent concentrations–air | | | NRC 1999a; 10 CFR 20 App B
a. | NRC | ^134^Cs | 2×10^−10^ µCi/mL | | NRC 1999a; 10 CFR 20 App B
a. | NRC | ^137^Cs | 2×10^−10^ µCi/mL | | NRC 1999a; 10 CFR 20 App B
b. | Water | | | | NRC 1999a; 10 CFR 20 App B
b. | NRC | Effluent concentrations–water | | | NRC 1999a; 10 CFR 20 App B
b. | NRC | ^134^Cs | 9×10^−7^ µCi/ml | | NRC 1999a; 10 CFR 20 App B
b. | NRC | ^137^Cs | 1×10^−6^ µCi/ml | | NRC 1999a; 10 CFR 20 App B
c. | Food | | | | FDA 1998
c. | FDA | Derived intervention level^a^ (DIL; Bq/kg food) in accidentally-contaminated human food | | | FDA 1998
c. | FDA | ^134^Cs | 930 | | FDA 1998
c. | FDA | ^137^Cs | 1360 | | FDA 1998
d. | Other
d. | EPA | Concentration levels for environmental compliance | | | EPA 1999a; 40 CFR 61 App E
d. | EPA | ^134^Cs | 0.7×10^−14^ Ci/m^3^ | | EPA 1999a; 40 CFR 61 App E
d. | EPA | ^137^Cs | 1.9×10^−14^ Ci/m^3^ | | EPA 1999a; 40 CFR 61 App E
d. | EPA | Carcinogenicity–slope factors^b^ | | | EPA 2002
d. | EPA | Lifetime risk per pCi–ingestion | | | EPA 2002
d. | EPA | Water | | | EPA 2002
d. | EPA | ^134^Cs | 4.22×10^−11^ | | EPA 2002
d. | EPA | ^137^Cs | 3.04×10^−11^ | | EPA 2002
d. | EPA | Food | | | EPA 2002
d. | EPA | ^134^Cs | 5.14×10^−11^ | | EPA 2002
d. | EPA | ^137^Cs | 3.74×10^−11^ | | EPA 2002
d. | EPA | Soil | | | EPA 2002
d. | EPA | ^134^Cs | 5.81×10^−11^ | | EPA 2002
d. | EPA | ^137^Cs | 4.33×10^−11^ | | EPA 2002
d. | EPA | Lifetime risk per pCi–inhalation | | | EPA 2002
d. | EPA | ^134^Cs | 1.65×10^−11^ | | EPA 2002
d. | EPA | ^137^Cs | 1.19×10^−11^ | | EPA 2002
d. | EPA | External exposure–risk/year per pCi/g soil | | | EPA 2002
d. | EPA | ^134^Cs | 7.10×10^−6^ | | EPA 2002
d. | EPA | ^137^Cs | 5.32×10^−10^ | | EPA 2002
d. | EPA | ^137^Cs (plus disintegration products) | 2.55×10^−6^ | | EPA 2002
d. | NRC | Occupational inhalation exposure | | | NRC 1999a; 10 CFR 20 App B
d. | NRC | ALIs | | | NRC 1999a; 10 CFR 20 App B
d. | NRC | ^134^Cs | 100 µCi | | NRC 1999a; 10 CFR 20 App B
d. | NRC | ^137^Cs | 200 µCi | | NRC 1999a; 10 CFR 20 App B
d. | NRC | DACs | | | NRC 1999a; 10 CFR 20 App B
d. | NRC | ^134^Cs | 4 ×10^−8^ µCi/mL | | NRC 1999a; 10 CFR 20 App B
d. | NRC | ^137^Cs | 6 ×10^−8^ µCi/mL | | NRC 1999a; 10 CFR 20 App B
d. | NRC | Quantities of licensed material requiring labeling | | | NRC 1999b; 10 CFR App C
d. | NRC | ^134^Cs | 10 µCi | | NRC 1999b; 10 CFR App C
d. | NRC | ^137^Cs | 10 µCi | | NRC 1999b; 10 CFR App C
[underlined: STATE]
a. | Air
a. | Michigan | Gross beta particle activity | | | MI Dept Environ Quality 2000
a. | Michigan | ^134^Cs | 15 pCi/L | | MI Dept Environ Quality 2000
b. | Water | | No data
c. | Food | | No data
d. | Other
d. | Louisiana | Quantity required for consideration of need for emergency plan for responding to a release | Release fraction | Quantity | LA Dept Environ Quality 2000
d. | Louisiana | ^134^Cs | 0.01 | 2,000 Ci | LA Dept Environ Quality 2000
d. | Louisiana | ^137^Cs | 0.01 | 3,000 Ci | LA Dept Environ Quality 2000

a The FDA-recommended Derived Intervention Level (DIL) for radionuclides of cesium, is defined as the DIL for the most sensitive age group (adults) that was calculated from the most limiting Protective Action Goal (PAG; 5 mSv committed effective whole body dose equivalent).

b EPA classifies all radionuclides as Group A (known human) carcinogens. Radionuclide risk coefficients, or slope factors, are calculated by EPA’s Office of Radiation and Indoor Air (ORIA) to assist HEAST users with risk-related evaluations and decision-making at various stages of the remediation process. Ingestion and inhalation slope factors are central estimates in a linear model of the age-averaged, lifetime attributable radiation cancer incidence (fatal and nonfatal cancer) risk per unit of activity inhaled or ingested, expressed as risk/picocurie (pCi). Ingestion values are tabulated separately for ingestion of tap water, dietary intakes (food), and incidental soil ingestion. External exposure slope factors are central estimates of the lifetime attributable radiation cancer incidence risk for each year of exposure to external radiation from photon-emitting radionuclides distributed uniformly in a thick layer of soil, and are expressed as risk/year per pCi/gram of soil.

ACGIH = American Conference of Governmental Industrial Hygienists; ALI = annual limitations on intake; CFR = Code of Federal Regulations; DAC = derived air concentrations; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; NIOSH = National Institute for Occupational Safety and Health; NRC = Nuclear Regulatory Commission; OSHA = Occupational Safety and Health Administration