# 4 CHEMICAL, PHYSICAL, and RADIOLOGICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of cesium is located in Table 4-1.

## 4.2 PHYSICAL, CHEMICAL, AND RADIOLOGICAL PROPERTIES

Information regarding the physical and chemical properties of cesium is located in Table 4-2.

Cesium is a silvery white, soft, ductile metal with only one oxidation state (+1). At slightly above room temperature, cesium exists in the liquid state. Compared to the other stable alkali metals, cesium has the lowest boiling point and melting point, highest vapor pressure, highest density, and lowest ionization potential. These properties make cesium far more reactive than the other members of the alkali metal group. When exposed to air, cesium metal ignites, producing a reddish violet flame, and forms a mixture of cesium oxides. Pure cesium reacts violently with water to form cesium hydroxide, the strongest base known, as well as hydrogen gas. The burning cesium can ignite the liberated hydrogen gas and produce an explosion. Cesium salts and most cesium compounds are generally very water soluble, with the exception of cesium alkyl and aryl compounds, which have low water solubility.

There are several radioactive isotopes of cesium ranging from ^114^Cs to ^145^Cs (Helmers 1996). The radioactive isotopes have a wide range of half-lives ranging from about 0.57 seconds (^114^Cs) to about 3×10^6^ years (^135^Cs) (Helmers 1996). The radioactive isotopes ^137^Cs and ^134^Cs are significant fission products because of their high fission yield, and their relatively long half-lives. The fission yield of ^137^Cs in nuclear reactions is relatively high; about 6 atoms of ^137^Cs are produced per 100 fission events (WHO 1983). ^137^Cs has a radioactive half-life of about 30 years and decays by beta decay either to stable ^137^Ba or a meta-stable form of barium (^137m^Ba). The meta-stable isotope (^137m^Ba) is rapidly converted to stable ^137^Ba (half-life of about 2 minutes) accompanied by gamma ray emission whose energy is 0.662 MeV (ICRP 1983). Figure 4-1 illustrates this decay scheme. The first beta decay mode that forms ^137m^Ba accounts for roughly 95% of the total intensity, while the second mode accounts for about 5% (WHO 1983). Radioactive ^134^Cs primarily decays to stable ^134^Ba by beta decay accompanied by gamma ray emissions or less frequently to stable ^134^Xe by electron capture (EC) accompanied by a single gamma ray emission as depicted in Figure 4-2. The energy of the various gamma rays are in the range of 0.24–1.4 MeV. The half-life average energy of the beta transitions and intensity of the transitions for both ^134^Cs and ^137^Cs are summarized in Table 4-3.

Table 4-1 Chemical Identity of Cesium and Compounds

Characteristic | Cesium (metal) | Cesium chloride | Cesium carbonate | Cesium hydroxide | Cesium oxide | Cesium nitrate
Synonym(s) | Caesium | Cesium monochloride | Dicesium salt | Cesium hydrate
Registered trade name(s) | No data | No data | No data | No data | No data | No data
Chemical formula | Cs | CsCl | Cs_2_CO_3_ | CsOH | Cs_2_O | CsNO_3_
Chemical structure | Cs | Cs—Cl | Cs^+^; [image]; Cs^+^ | Cs—OH | [image] | [image]
Identification numbers:
CAS registry | 7440-46-2 | 7647-17-8 | 534-17-8 | 21351-79-1 | 20281-00-9 | 7789-18-6
NIOSH RTECS | FK9225000 | FK9625000 | FK9400000 | FK9800000 | No data
EPA hazardous waste | No data | No data | No data | No data | No data | No data
OHM/TADS | No data | No data | No data | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data | No data | No data | No data
HSDB | No data | No data | No data | No data | No data | No data
NCI | No data | No data | No data | No data | No data | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Cesium and Compounds^a^

Property | Cesium (metal) | Cesium chloride | Cesium carbonate | Cesium hydroxide | Cesium oxide | Cesium nitrate
Molecular weight | 132.906 | 168.36 | 325.82 | 149.91 | 281.81 | 194.91^b^
Color | Silvery-white | White | White | Colorless | Golden-yellow | White^b^
Physical state | Solid (liquid slightly above room temperature) | Solid | Solid | Solid | Solid | Solid^b^
Melting point | 29 °C | 646 °C | 610 °C | 272 °C | 490 °C | 414 °C^b^
Boiling point | 685 °C | 1290 °C | No data | No data | No data | No Data
Density, g/cm^3^ | 1.93 (20 °C)^b^ | 3.988 (20 °C)^b^ | 4.24 (20 °C)^b^ | 3.68 (20 °C)^b^ | 4.65 (20 °C)^b^ | 3.66 (20 °C)^b^
Odor | No data | No data | No data | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data | No data | No data
Air | No data | No data | No data | No data | No data | No data
Solubility:
Water | Reacts violently with water | 1.87 kg/L (20 °C) | 2.1 kg/L | 4 kg/L (15 °C) | Very soluble in water^b^ | Soluble^b^
Organic-solvent(s) | | Soluble in ethanol^b^ | Soluble in ethanol and ether^b^ | Soluble in ^b^
Partition coefficients:
Log K_ow_ | N/A | N/A | N/A | N/A | N/A | N/A
Log K_oc_ | N/A | N/A | N/A | N/A | N/A | N/A
Vapor pressure | 0.0075 mmHg at 144.5 °C | No data | No data | No data | No data | No data
Henry’s Law constant | N/A | N/A | N/A | N/A | N/A | N/A
Autoignition temperature | No data | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data | No data | No data

a Data from Burt 1993 unless otherwise specified.

b Lide 1998

N/A = not applicable

Figure 4-1 The Decay Scheme of ^137^Cs

β = beta decay; γ= γ -ray emission

Table 4-3 Decay Properties of the Radioactive Isotopes of Cesium^a,b^

Isotope | Half-life (years) | Decay mode | Intensity percent | Beta particle energy (MeV)
^134^Cs | 2.062 | β_1_^−^ | 27 | 0.02309
^134^Cs | 2.062 | β_2_^−^ | 2.5 | 0.1234
^134^Cs | 2.062 | β_3_^−^ | 70 | 0.2101
^137^Cs | 30 | β_1_^−^ | 94.6 | 0.1734
^137^Cs | 30 | β_2_^−^ | 5.4 | 0.4246

a ICRP 1983

b The ^134^Xe daughter yield from the electron capture decay of ^134^Cs is approximately 3×10^−6^.

Figure 4-2 The Decay Scheme of ^134^Cs

EC = electron capture; β = beta decay; γ = gamma-ray emission