# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-32, Atlanta, Georgia 30333.

## Radioactive Cesium Acute External

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Radioactive Cesium
CAS Number: | Multiple
Date: | March 11, 2004
Profile Status: | Draft 3, Post-Public
Route: | [ ] Inhalation [ ] Oral [X] External
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Species: | Human

[underlined: Minimal Risk Level]: 4 [ ] mg/kg/day [ ] ppm [ ] mg/m^3^ [X] mSv (400 mrem)

[underlined: Reference:]

Schull WJ, Otake M, Yoshimaru H. 1988. Effect on intelligence test score of prenatal exposure to ionizing radiation in Hiroshima and Nagasaki: A comparison of the T65DR and DS86 dosimetry systems. Radiation Effects Research Foundation. RERF TR 3-88. Research project 24-62.

Burt C. 1966. The genetic determination of differences in intelligence: A study of monozygotic twins reared together and apart. Brit J Psychol 57(1 & 2):137–153.5949392

[underlined: Experimental design]:

Schull et al. (1988) study: Schull et al. (1988) evaluated the quantitative effect of exposure to ionizing radiation on the developing fetal and embryonic human brain. The end point measured was changes in intelligence test scores. The effects on individuals exposed in utero to the atomic bombing of Hiroshima and Nagasaki were based on the original PE86 samples (n=1,759; data on available intelligence testing) and a clinical sample (n=1,598). The original PE86 sample included virtually all prenatally exposed individuals who received tissue-absorbed doses of 0.50 Gy or more. There were many more individuals in the dose range of 0–0.49 Gy in the PE86 sample than in the clinical sample. The clinical sample does not include children prenatally exposed at distances between 2,000 and 2,999 m in Hiroshima and Nagasaki. Children exposed at greater distances or not present in the city were selected as controls. In 1955–1956, Tanaka-B (emphasis on word-sense, arithmetic abilities, and the like, which were associated with the more subtle processing of visual clues than their simple recognition and depended more on connectedness) and the Koga (emphasis on perception of spatial relationships) intelligence tests were conducted in Nagasaki and the Koga test in Hiroshima.

Burt (1966) study: This study determined differences in intelligence in monozygotic twins reared together (n=95) and apart (n=53). All tests conducted in school consisted of (1) a group test of intelligence containing both nonverbal and verbal items, (2) an individual test (the London Revision of the Terman-Binet Scale) used primarily for standardization and for doubtful cases, and (3) a set of performance tests, based on the Pitner-Paterson tests and standardization. The methods and standard remained much the same throughout the study. Some of the reasons for separation of the twins were given as follows: death of the mother (n=9), unable to bring them up properly, mother’s poor health (n=12), unmarried (n=6), and economic difficulties. The children were brought up by parents or foster parents (occupation ranged from unskilled to professional). IQ scores in the study group ranged from 66 to 137. The standard deviation of the group of separated monozygotic twins was reported at 15.3 as compared to 15.0 of ordinary siblings. Twins brought up in different environments were compared with those brought up in similar circumstances.

[underlined: Effects noted in study and corresponding doses]:

Schull et al. (1986) study: No evidence of radiation-related effect on intelligence was observed among individuals exposed within 0–7 weeks after fertilization or in the 26th or subsequent weeks. The highest risk of radiation damage to the embryonic and fetal brain occurs 8–15 weeks after fertilization under both dosimetric systems. The regression of intelligence score on estimated DS86 uterine absorbed dose is linear with dose, and the diminution in intelligence score is 21–29 points per Gy for the 8–15-week group and 10–26 points per Gy for the 16–25-week group. The results for 8–15 weeks applies regardless whether or not the mentally retarded individuals were included. The cumulative distribution of test scores suggested a progressive shift downwards in individual scores with increasing exposure. The mean IQ scores decrease significantly and systematically with uterine or fetal tissue dose within the 8–15- and 16–25-week groups.

In summary, analysis of intelligence test scores at 10–11 years of age of individuals exposed prenatally showed that:

There is no evidence of a radiation-related effect on intelligence scores among those individuals exposed within 0–7 weeks of fertilization or in the 26^th^ week of gestation and beyond.

The cumulative distribution of test scores suggests a progressive shift downwards in intelligence scores with increasing exposure to ionizing radiation (dose-response relationship).

The most sensitive group was the 8–15 weeks exposure group. The regression in intelligence scores was found to be linear, with 1 Gy dose resulting in a 21–29 point decline in intelligence scores.

There was no indication of groups of individuals with differing sensitivities to radiation.

Burt (1966) study: The average intelligence of the twins measured on a conventional IQ scale (SD=15) was 97.8 for the separated monozygotes, 98.1 for monozygotes brought up together, 99.3 for the dizygotes as compared with 100.2 for the siblings, and 100.0 for the population as a whole. The difference of 0.3 IQ point between the separated and unseparated identical twins is considered a NOAEL for this study.

[underlined: Dose and end point used for MRL derivation]:

[X] NOAEL [ ] LOAEL 0.3 IQ point reduction in twins, between those raised together and those raised apart.

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 1 [ ] 3 [ ] 10 (for use of a NOAEL)
- [X] 1 [ ] 3 [ ] 10 (for extrapolation from animals to humans)
- [ ] 1 [X] 3 [ ] 10 (for human variability/sensitive population)

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose]: Not applicable

[underlined: Was a conversion used from intermittent to continuous exposure?] No.

[underlined: Other additional studies or pertinent information which lend support to this MRL]: Husen (1959) reported a study involving 269 pairs of Swedish monozygotic (identical) twins where the intrapair IQ difference was 4 IQ points for a combination of twins raised together and apart. This is somewhat lower than the value of 7 IQ points for identical twins raised apart, and just larger than the range of IQ scores for Washington, DC children repetitively tested (Jacobi and Glauberman 1995).

Supporting evidence for the acute MRL is provided by Jacobi and Glauberman (1995). Children in the 1^st^, 3^rd^, and 5^th^ grades born in Washington, DC were tested, and average IQ levels of 94.2, 97.6, and 94.6 were reported. The range of 3.4 IQ points is considered to be a LOAEL for this study, which, if used for MRL derivation, would yield an MRL of 0.004 Sv (3.4 IQ points × 1 Sv/25 IQ points ÷ 30 [10 for use of a LOAEL and 3 for a sensitive population]).

Additional supporting evidence for the acute MRL is provided by Berger et al. 1997, in a case study of accidental radiation injury to the hand. A Mexican engineer suffered an accidental injury to the hand while repairing an x-ray spectrometer. The day after the accident, his symptoms included a tingling sensation and itching in the index and middle fingers. On days 4 and 7, a “pinching” sensation, swelling, and slight erythema were observed. By day 7, the tip of his index fingers was erythematous and a large blister developed with swelling on other fingers. On day 10, examination by a physician showed that the lesions had worsened and the fingers and palms were discolored. On day 10, he was admitted to the hospital where hyperbaric oxygen therapy was administered without success. One month after the accident, the patient entered the hospital again with pain, discoloration, and desquamation of his hand. Clinical examination showed decreased circulation in the entire hand, most notably in the index and middle finger. Total white blood count decreased to 3,000/µL (normal range 4,300–10,800/µL). Cytogenic studies of peripheral blood lymphocytes revealed four dicentrics, two rings, and eight chromosomal fragments in the 300 metaphases studied. The estimated whole body dose was reported to be 0.382 Gy (38.2 rad). This dose is a potential LOAEL for acute ionizing radiation and would yield an MRL of 0.004 Sv (0.38 Sv ÷100 [10 for use of LOAEL and 10 for sensitive human population]).

The NRC set a radiation exposure limit of 0.5 rem (50 mSv) for pregnant working women over the full gestational period (USNRC 1991). For the critical gestational period of 8–15 weeks ATSDR believes that the conservative acute MRL of 4 mSv is consistent with the NRC limit and could be applied to either acute (0–14-day) or intermediate (15–365-day) exposure periods.

Calculations:

Given: 0.3 IQ point is a NOAEL. A 1 Sv dose results in a 25 IQ point reduction (range=21–29 points; mean=25) and provides a conversion factor from IQ prediction to radiation dose. Assume that the radiation dose and the subsequent reduction in IQ is a linear relationship.

MRL = NOAEL × CF ÷ UF MRL = 0.3 × 1 / 25 ÷ 3 MRL = 0.004 Sv = 4 mSv ( 400 mrem )

[underlined: Agency Contact (Chemical Manager):] Malcolm Williams, Ph.D.

## Radioactive Cesium Chronic External

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Radioactive Cesium
CAS Number: | Multiple
Date: | March 11, 2004
Profile Status: | Draft 3, Post-Public
Route: | [ ] Inhalation [ ] Oral [X] External
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Species: | Human

[underlined: Minimal Risk Level]: 1 [ ] mg/kg/day [ ] ppm [ ] mg/m^3^ [X] mSv/year (100 mrem/year)

[underlined: Reference]: BEIR V. 1990. Health effects of exposure to low levels of ionizing radiation. Committee on the Biological Effects of Ionizing Radiations, National Research Council. National Academy Press. Washington, DC.

[underlined: Experimental design]: Not applicable

[underlined: Effects noted in study and corresponding doses]: No individual studies were identified that could be used to base a chronic-duration external exposure MRL that did not result in a cancer-producing end point. However, two sources of information were identified that did provide doses of ionizing radiation that have not been reported to be associated with detrimental effects (NOAELs). These sources provide estimates of background levels of primarily natural sources of ionizing radiation that have not been implicated in producing cancerous or noncancerous toxicological endpoints. BEIR V states that the average annual effective dose to the U.S. population is 3.6 mSv/year. A total annual effective dose equivalent of 3.6 mSv (360 mrem)/year to members of the U.S. population is obtained mainly by naturally occurring radiation from external sources, medical uses of radiation, and radiation from consumer products. The largest contribution (82%) is from natural sources, two-thirds of which is from naturally occurring radon and its decay products. Specific sources of this radiation are demonstrated in Table A-1.

The annual dose of 3.6 mSv per year has not been associated with adverse health effects or increases in the incidences of any type of cancers in humans or other animals.

Dose and end point used for MRL derivation: 3.6 mSv/year

[X] NOAEL [ ] LOAEL 3.6 mSv/year

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 1 [ ] 3 [ ] 10 (for use of a NOAEL)
- [X] 1 [ ] 3 [ ] 10 (for extrapolation from animals to humans)
- [ ] 1 [X] 3 [ ] 10 (for human variability)

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose]? No.

Table A-1 Average Annual Effective Dose Equivalent from Ionizing Radiation to a Member of the U.S. Population^a^

| Effective dose equivalent
Source | mSv | Percent of total dose
Natural
Radon^b^ | 2.0 | 55
Cosmic | 0.27 | 8.0
Terrestrial | 0.28 | 8.0
Internal | 0.39 | 11
Total natural | 3.0 | 82
Artificial
Medical
X-ray | 0.39 | 11
Nuclear | 0.14 | 4.0
Consumer products | 0.10 | 3.0
Other
Occupational | <0.01 | <0.3
Nuclear fuel cycle | <0.01 | <0.03
Fallout | <0.01 | <0.03
Miscellaneous^c^ | <0.01 | <0.03
Total artificial | 0.63 | 18
Total natural and artificial | 3.6 | 100

a Adapted from BEIR V, Table 1-3 , page 18.

b Dose equivalent to bronchi from radon daughter products

c DOE facilities, smelter, transportation, etc.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information which lend support to this MRL]: ICRP has developed recommended dose limits for occupational and public exposure to ionizing radiation sources. The ICRP recommends limiting public exposure to 1 mSv/year (100 mrem/year), but does note that values at high altitudes above sea level and in some geological areas can sometimes be twice that value (≥2 mSv). In Annex C of ICRP 60, the commission provides data that suggests increasing the dose from 1 mSv to 5 mSv results in a very small, but detectable, increase in age-specific human mortality rate. ICRP states that the value of 1 mSv/year was chosen over the 5 mSv value because 5 mSv/year (500 mrem/year) causes this increase in age specific mortality rate, and 1 mSv/year (100 mrem/year) is typical of the annual effective dose from background, less radon (ICRP 1991). The 1 mSv estimate may underestimate the annual exposure to external sources of ionizing radiation to the U.S. population, as it does not include radiation from radon. Conversely, the 5 mSv estimate may be high, in that increases in mortality rate been reported. The most useful estimate appears to be the BEIR V estimate of 3.6 mSv, in that it accounts for an annual exposure to radon, is specific to the U.S. population, has not been associated with increases mortality, and it falls short of the 5 mSv value associated with small increases in human mortality.

Calculations:

MRL = NOAEL_( ADJ )_ ÷ UF MRL = 3.6 mSv/year ÷ 3 MRL = 1.20 mSv/year MRL = 1.0 mSv/year = 100 mrem/year above background

[underlined: Agency Contact (Chemical Manager):] Malcolm Williams, Ph.D.