# 9 REFERENCES

* Cited in text

*Abraham P, Wilfred G, Catherine SP, 1999. Oxidative damage to the lipids and proteins of the lungs, testis and kidney of rats during carbon tetrachloride intoxication. Clin Chim Acta 289(1–2):177–179.10636716
*ACGIH. 1986. Documentation of the threshold limit values and biological exposure indices. 5th edition. Cincinnati, OH: American Conference of Government Industrial Hygienists Inc., 109–110.
*ACGIH. 2003. Carbon tetrachloride. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*Acquavella JF, Friedlander BR, Ireland BK. 1994. Interpretation of low to moderate relative risks in environmental epidemiologic studies. Annu Rev Public Health 15:179–201.8054080
*Adams EM, Spencer HC, Rowe VK, 1952. Vapor toxicity of carbon tetrachloride determined by experiments on laboratory animals. AMA Arch Ind Hyg Occup Med 6:50–66.14932528
Adamson DT, Parkin GF. 1999. Biotransformation of mixtures of chlorinated aliphatic hydrocarbons by an acetate-grown methanogenic enrichment culture. Water Res 33:1482–1494.
*Adaramoye OA, Akinloye O. 2000. Possible protective effect of kolaviron on CCl4-induced erythrocyte damage in rats. Biosci Rep 20:4.
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Agarwal AK, Mehendale HM. 1984a. CCl_4_-induced alterations in Ca^++^ homeostasis in chlordecone and phenobarbital pretreated animals. Life Sci 34:141–148.6198578
*Agarwal AK, Mehendale HM. 1984b. Excessive hepatic accumulation of intracellular Ca^2+^ in chlordecone potentiated CCl_4_ toxicity. Toxicology 30:17–24.6199871
*Agarwal AK, Mehendale HM. 1986. Effect of chlordecone on carbon tetrachloride-induced increase in calcium uptake in isolated perfused rat liver. Toxicol Appl Pharmacol 83:342–348.2421457
Agency for Toxic Substances and Disease Registry. 1988. VIEW database. Atlanta, GA: Agency for Toxic Substances and Disease Registry Office of External Affairs, Exposure and Disease Registry Branch, October 1988.
*Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37618–37634.
*Agency for Toxic Substances and Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Agrawal HC, Agrawal D. 1989. Tumor promoters accentuate phosphorylation of PO: Evidence for the presence of protein kinase C in purified PNS myelin. Neurochem Res 14:409–413.2473407
Ahmad FF, Cowan DL, Sun AY. 1987. Detection of free radical formation in various tissues after acute carbon tetrachloride administration in gerbil. Life Sci 40:2469–2475.
Ahmadizadeh M, Echt R, Heusner WW, 1990. Effect of carbon tetrachloride on hamster tracheal epithelial cells. J Toxicol Environ Health 30:273–285.2388299
*Ala-Kokko L, Gunzler V, Hoek JB, 1992. Hepatic fibrosis in rats produced by carbon tetrachloride and dimethylnitrosamine: Observations suggesting immunoassays of serum for the 7S fragment of type IV collagen are a more sensitive index of liver damage than immunoassays for the NH_2_-terminal propeptide of type III procollagen. Hepatology 16:167–172.1618469
Ala-Kokko L, Stenback F, Ryhanen L. 1987. Preventive effect of malotilate on carbon tetrachloride-induced liver damage and collagen accumulation in the rat. Biochem J 246:503–509.2825640
Albano E, Carini R, Parola M, 1989. Effects of carbon tetrachloride on calcium homeostasis. Biochem Pharmacol 38:2719–2725.2764992
*Allis JW, Brown BL, Simmons JE, 1996. Methanol potentiation of carbon tetrachloride hepatotoxicity: The central role of cytochrome P450. Toxicology 112(2):131–140.8814342
*Allis JW, Ward TR, Seely JC, 1990. Assessment of hepatic indicators of subchronic carbon tetrachloride injury and recovery in rats. Fundam Appl Toxicol 15:558–570.2258019
Alric L, Orfila C, Carrere N, 2000. Reactive oxygen intermediates and eicosanoid production by Kupffer cells and infiltrated macrophages in acute and chronic liver injury induced in rats by CCl_4_. Inflamm Res 49:700–707.11211921
*Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol III. 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
*Alumot E, Nachtomi E, Mandel E, 1976. Tolerance and acceptable daily intake of chlorinated fumigants in the rat diet. Food Cosmet Toxicol 14:105–110.1270030
*Amacher DE, Zelljadt I. 1983. The morphological transformation of Syrian hamster embryo cells by chemicals reportedly nonmutagenic to Salmonella typhimurium. Carcinogenesis 4(3):291–296.6339095
*Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3(6):272–290.6376602
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Andersen NJ, Waller CL, Adamovic JB, 1996. A pharmacokinetic model of anaerobic in vitro carbon tetrachloride metabolism. Chem Biol Interact 101:13–31.8665616
*Andervont HB. 1958. Induction of hepatomas in strain C3II mice with 4-o-tolylazo-o-toluidine and carbon tetrachloride. J Natl Cancer Inst 20:431–438.
Andrabi K, Kaul N, Gangly NK, 1989. Altered calcium homeostatis in carbon tetrachloride exposed rat hepatocytes. Biochem International 18:1287–1295.
Aniya Y, Anders MW. 1985. Alteration of hepatic glutathione S-transferases and release into serum after treatment with bromobenzene, carbon tetrachloride, or N-nitrosodimethylamine. Biochem Pharmacol 34:4239–4244.4074384
*Annoni G, Contu L, Tronci MA, 1992. Pyridoxol _L_,2-pyrrolidon-5 carboxylate prevents active fibroplasia in CCl_4_-treated rats. Pharmacol Res 25:87–93.
*Anonymous. 1981. Chemical profile: Carbon tetrachloride. Chem Mark Rep. October 12, 1981.
*Anonymous. 1983. Chemical profile: Carbon tetrachloride. Chem Mark Rep. May 21, 1983.
Anonymous. 1992. Carbon tetrachloride toxicity. Am Fam Phys 46:1199–1207.
*Anonymous. 1995. Chemical profile: Carbon tetrachloride. Chem Mark Rep. February 20, 1995.
*Ansari GA S, Moslen MT, Reynolds ES. 1982. Evidence of in vivo covalent binding of CCl3 derived from CCl4 to cholesterol of rat liver. Biochem Pharmacol 31(21):3509–3510.7150372
Anttinen H, Oikarinen A, Puistola U, 1985. Prevention by zinc of rat lung collagen accumulation in carbon tetrachloride injury. Am Rev Respir Dis 132:536–540.2994529
*AOAC. 1984. Fumigant residues. Volatile fumigants in grain. Gas chromatographic method. Section 29.071. In: Official methods of analysis of The Association of Official Analytical Chemists. 14th ed. Arlington, VA: Association of Official Analytical Chemists Inc., 547–548.
*APHA. 1985. Halogenated methanes and ethanes by purge and trap - method 514. In: Standard methods for the examination of water and wastewater. 16th ed. Washington, DC: American Public Health Association, 591–602.
*APHA. 1992a. Methos 6230A. Volatile halocarbons. In: Standard methods for the examination of water and wastewater. 18th ed. Washington, DC. American Public Health Association, 46–57.
*APHA. 1992b. Methos 6040C. Purge and trap technique. In: Standard methods for the examination of water and wastewater. 18th ed. Washington, DC. American Public Health Association, 17–36.
*Aragno M, Danni O, Ugazio G. 1989. In vivo studies on halogen compound interactions. II. Effects of carbon tetrachloride plus 1,2-dibromomethane on relative liver weight and hepatic steatosis. Res Comm Chem Pathol Pharmacol 66:105–116.
*Aragno M, Tamagno E, Boccuzzi G, 1993. Dehydroepiandrosterone pretreatment protects rats against the pro-oxidant and necrogenic effects of carbon tetrachloride. Biochem Pharmacol 46(10):1689–1694.8250954
*Aragno M, Tamagno E, Danni O, 1992. In vivo studies on halogen compound interactions. III. Effect of carbon tetrachloride plus 1,2-dichloroethane on liver necrosis and fatty accumulation. Res Comm Chem Pathol Pharmacol 76:341–354.
*Araki A, Kamigaito N, Sasaki T, 2004. Mutagenicity of carbon tetrachloride and chloroform in Salmonella typhimurium TA98, TA100, TA1535, and TA1537, and Escherichia coli WP2/pKM101, using a gas exposure method. Environ Mol Mutagen 43:128–133.14991753
*Arezzini B, Lunghi B, Lungarella G, 2003. Iron overload enhances the development of experimental liver cirrhosis in mice. Int J Biochem Cell Biol 35:486–495.12565710
Arii S, Monden K, Itai S, 1990. Depressed function of Kupffer cells in rats with CCl_4_-induced liver cirrhosis. Res Exp Med 190:173–182.
*Ariosto F, Riggio O, Cantafora A, 1989. Carbon tetrachloride-induced experimental cirrhosis in the rat: A reappraisal of the model. Eur Surg Res 21:280–286.2627982
Armendariz-Borunda J, Katai H, Jones CM, 1993. Transforming growth factor β gene expression is transiently enhanced at a critical stage during liver regeneration after CCl_4_ treatment. Lab Invest 69(3):283–294.8377471
Arosio B, Santambrogio D, Gagliano N, 1997. Glutathione pretreatment lessens the acute liver injury induced by carbon tetrachloride. Pharmacol Toxicol 81(4):164–168.9353846
Asakura S, Sawada S, Daimon H, 1994. Effects of dietary restriction on induction of unscheduled DNA synthesis (UDS) and replicative DNA synthesis (RDS) in rat liver. Mutat Res 322:257–264.7523919
*Ashe WF, Sailer S. 1942. Fatal uremia following single exposure to carbon tetrachloride fumes. Ohio State Med J 38:553–555.
*Ashley DL, Bonin MA, Cardinali FL, 1992. Determining volatile organic compounds in human blood from a large sample population by using purge and trap gas chromatography/mass spectrometry. Anal Chem 64:1021–1029.1590585
Ashley DL, Bonin MA, Cardinali FL, 1994. Blood concentrations of volatile organic compounds in a nonoccupationally exposed US population and in groups with suspected exposure. Clin Chem 40(7):1401–1404.8013127
Assmuth TW, Strandberg T. 1993. Groundwater contamination at Finnish landfills. Water Air Soil Pollut 69:179–199.
*ASTM. 1987. Sampling workplace atmospheres to collect organic gases or vapors with activated charcoal diffusional samplers - method D 4597–87. In: 1987 Annual book of ASTM standards. Volume 11.03. Atmospheric analysis; occupational health and safety. Philadelphia, PA: American Society for Testing and Materials, 490–494.
*ASTM. 1988. Low molecular weight halogenated hydrocarbons in water - method D 3973–85. 1988 Annual book of ASTM standards. Volume 11.02. Water and environmental technology. Philadelphia, PA: American Society for Testing Materials, 141–145.
Atkinson R. 1989. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds. J Phys Chem Ref Data Monograph 1:66.
Atucha NM, Cegarra M, Ramirez A, 1993. Pressure diuresis and naturiruresis in cirrhotic rats. Am J Physiol 265(6 pt 1):G1045–1049.8279554
*Austin J. 2003. Day-of-week patterns in toxic air contaminants in southern California. J Air Waste Manage Assoc 53:889–896.
Axelsson G, Rylander R. 1989. Outcome of pregnancy in women engaged in laboratory work at a petrochemical plant. Am J Ind Med 16:539–545.2589330
Ayub-Ayala M, Flores-Alvarado LJ, Bueno Topete MR, 1993. Effect of short-term carbon tetrachloride administration on blood lactic acid levels. Gen Pharmacol 24(3):627–630.8365643
*Azri S, Mata HP, Gandolfi AJ, Brendel K. 1991. CCl_4_-induced cytochrome P-450 loss and lipid peroxidation in rat liver slices. Biol Reactive Intermediates 669–674.
Bachem MG, Meyer D, Melchior R, 1992. Activation of rat liver perisinusoidal lipocytes by transforming growth factors derived from myofibroblastlike cells. J Clin Invest 89:19–27.1729271
Badger DA, Kuester RK, Sauer J-M, 1997. Gadolinum chloride reduces cytochrome P450: Relevance to chemical-induced hepatotoxicity. Toxicology 121:143–153.9230446
Badger DA, Sauer J- M, Hoglen NC, 1996. The role of inflammatory cells and cytochrome P450 in the potentiation of CCl_4_-induced liver injury by a single dose of retinol. Toxicol Appl Pharmacol 141:507–519.8975775
Baehr AL, Stackelberg PE, Baker RJ. 1999. Evaluation of the atmosphere as a source of volatile organic compounds in shallow groundwater. Water Resour Res 35:127–136.
Bagchi D, Bagchi M, Hassoun E, 1993. Carbon-tetrachloride-induced urinary excretion of formaldehyde, malondialdehyde, acetaldehyde and acetone in rats. Pharmacology 47:209–216.
*Bai CL, Canfield PJ, Stacey NH. 1992. Individual serum bile acids as early indicators of carbon tetrachloride- and chloroform-induced liver injury. Toxicology 75:221–234.1455431
Bailey RE. 2001. Global hexachlorobenzene emissions. Chemosphere 43:167–182.11297396
Bakale G, McCreary RD. 1990. Response of the k_e_ test to NCI/NTP-screened chemicals. I. Nongenotoxic carcinogens and genotoxic noncarcinogens. Carcinogenesis 11:1811–1818.2208594
*Baker EL. 1994. A review of recent research on health effects of human occupational exposure to organic solvents. J Occup Med 36(10):1079–1092.7830166
Balint GA. 1998. Possible role of endogenous prostacyclin in the maintenance of hepatic integrity in rat. Exp Toxicol Pathol 50(1):9–11.9570495
Ban M, Hettich D, Bonnet P. 2003. Effect of inhaled industrial chemicals on systemic and local immune response. Toxicology 184:41–50.12505375
Bandi ZL, Ansari GA. 1989. Isolation of hydroxy fatty acids from livers of carbon tetrachloride-treated rats by thin-layer chromatography. J Chromatogr 475:461–466.2777965
Bang S, Myren J, Linnestad P, 1992. Effect of the prostaglandin E2 analogue enprostil on the carbon tetrachloride-induced necrosis of liver cells in mice. APMIS 100(11):936–966.
Barbee GC. 1994. Fate of chlorinated aliphatic hydrocarbons in the vadose zone and ground water. Ground Water Monit Remed 14:129–140.
*Barber ED, Donish WH, Mueller KR. 1981. A procedure for the quantitative measurement of the mutagenicity of volatile liquids in the Ames Salmonella/microsome assay. Mutat Res 90:31–48.7029269
Barber LB, Thurman EM, Takahashi Y, 1992. Comparison of purge and trap GC/MS and purgeable organic chloride analysis for monitoring volatile chlorinated hydrocarbons. Ground Water 30:836–842.
*Barbin A, Bereziat J-C, Bartsch H. 1983. Evaluation of DNA damage by the alkaline elution technique in liver, kidneys and lungs of rats and hamsters treated with N-nitrosodialkylamines. Carcinogenesis 4(5):541–545.6850984
Barkley J, Bunch J, Bursey JT, 1980. Computer analysis of volatile halogenated hydrocarbons in man and his environment -- a multimedia environmental study. Biomed Mass Spectrom 7:139–147.7448328
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Barnes R, Jones RC. 1967. Carbon tetrachloride poisoning. Am Ind Hyg Assoc J 28:557–560.6060012
Barrow L, Tanner MS. 1989. The effect of carbon tetrachloride on the copper-laden rat liver. Br J Exp Pathol 70:9–19.2923791
*Bartosiewicz MJ, Jenkins D, Penn S, 2001. Unique gene expression patterns in liver and kidney associated with exposure to chemical toxicants. J Pharmacol Exp Ther 297(3):895–905.11356909
Bascom R, Bromberg PA, Costa DA, 1996. Health effects of outdoor air pollution. Am J Respir Crit Care Med 153(1):1996.
Bastien M-C, Leblond F, Pichette V, 2000. Differential alteration of cytochrome P450 isoenzymes in two experimental models of cirrhosis. Can J Physiol Pharmacol 78:912–919.11100940
Basu S. 1999. Oxidative injury induced cyclooxygenase activation in experimental hepatotoxicity. Biochem Biophys Res Commun 254(3):764–767.9920815
*Basu S. 2003. Carbon tetrachloride-induced lipid peroxidation: Eicosanoid formation and their regulation by antioxidant nutrients. Toxicology 189:113–127.12821287
Batusic DS, Armbrust T, Saile B, 2004. Induction of Mx-2 in rat liver by toxic injury. J Hepatol 40:446–453.15123359
Baumann M, Berauer M. 1985. Comparative study on the sensitivity of several serum enzymes in detecting hepatic damage in rats. Arch Toxicol 8 (Suppl.):370–372.
Becker E, Messner B, Berndt J. 1987. Two mechanisms of CCl_4_-induced fatty liver: Lipid peroxidation or covalent binding studied in cultured rat hepatocytes. Free Rad Res Commun 3:299–308.
Beckonert O, Bollard ME, Ebbels TM D, 2003. NMR-based metabonomic toxicity classification: Hierarchical cluster analysis and k-nearest-neighbour approaches. Anal Chim Acta 490:3–15.
*Beddowes EJ, Faux SP, Chipman JK. 2003. Chloroform, carbon tetrachloride and glutathione depletion induce secondary genotoxicity in liver cells via oxidative stress. Toxicology 187:101–115.12699900
Bedossa P, Houglum K, Trautwein C, 1994. Stimulation of collagen α_1_ (I) gene expression is associated with lipid peroxidation in hepatocellular injury: A link to tissue fibrosis. Hepatology 19:1262–1271.8175151
Beliveau M, Tardif R, Krishnan K. 2003. Quantitative structure-property relationships for physiologically based pharmacokinetic modeling of volatile organic chemicals in rats. Toxicol Appl Pharmacol 189(3):221–232.12791307
*Bell AN, Mehandale HM. 1985. The effect of dietary exposure to a mirex plus chlordecone combination on CCl_4_ hepatotoxicity. Fundam Appl Toxicol 5:679–687.2412926
*Bell AN, Mehendale HM. 1987. Comparative changes in hepatic DNA, RNA, protein, lipid, and glycogen induced by a subtoxic dose of CCl_4_ in chlordecone, mirex, and phenobarbital pretreated rats. Toxicol Lett 35:191–200.2435023
Bell J, Melcer H, Monteith H, 1993. Stripping of volatile organic compounds at full-scale municipal wastewater treatment plants. Water Environ Res 65:708–716.
*Bellar TA. 1989. Method 502.1. Volatile halogenated organic compounds in water by purge and trap gas chromatography. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development.
*Belyaev ND, Budker VC, Deriy LV, 1992. Liver plasma membrane-associated fibroblast growth: Stimulatory and inhibitory activities during experimental cirrhosis. Hepatology 15:525–531.1544635
Bender AP, Parker DL, Johnson RA, 1989. Minnesota highway maintenance worker study: Cancer mortality. Am J Ind Med 15:545–556.2741960
*Benedetti A, Fulceri R, Ferrali M, 1982. Detection of carbonyl functions in phospholipids of liver microsomes in CCl4- and BrCCl3-posioned rats. Biochim Biophys Acta 712:628–638.7126629
*Bengtsson F, Bugge M, Vagianos C, 1987. Brain serotonin metabolism and behavior in rats with carbon tetrachloride-induced liver cirrhosis. Res Exp Med 187:429–438.
*Benigni R, Andreoli C, Conti L, 1993. Quantitative structure–activity relationship models correctly predict the toxic and aneuploidizing properties of six halogenated methanes in Aspergillus nidulans. Mutagenesis 8(4):301–305.8377647
*Benson JM, Tibbetts BM, Thrall KD, 2001. Uptake, tissue distribution, and fate of inhaled carbon tetrachloride: Comparison of rat, mouse, and hamster. Inhal Toxicol 13:207–217.11295857
*Berck B. 1974. Fumigant residues of carbon tetrachloride, ethylene dichloride, and ethylene dibromide in wheat, flour, bran, middlings, and bread. J Agric Food Chem 22:977–985.4430809
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
Berger ML, Sozen T. 1987. Rapid halogenated hydrocarbon toxicity in isolated hepatocytes is mediated by direct solvent effects. Toxicology 45:319–330.3629614
*Bergman K. 1983. Application and results of whole-body autoradiography in distribution studies of organic solvents. CRC Crit Rev Toxicol 12:59–118.
*Berman E, House DE, Allis JW, 1992. Hepatotoxic interactions of ethanol with allyl alcohol or carbon tetrachloride in rats. J Toxicol Environ Health 37:161–176.1522609
*Bermudez E, Mirsalis JC, Eales HC. 1982. Detection of DNA damage in primary cultures of rat hepatocytes following in vivo and in vitro exposure to genotoxic agents. Environ Mutagen 4:667–679.6819133
Bernacchi AS, Fernandez G, Villarruel MC, 1988. Further studies on the late preventive effects of the anticalmodulin trifluoperazine on carbon tetrachloride-induced liver necrosis. Exp Mol Pathol 48:286–300.3371454
Bertelli A, Giovannini L, Bertelli AA, 1986. Tissue concentrations of coenzyme Q in liver of rats intoxicated by carbon tetrachloride. Int J Tissue React 8:343–346.3744721
Bezerra JA, Laney DW, Degan SJ F. 1994. Increased expression of mRNA for hepatocyte growth factor-like protein during liver regeneration and inflammation. Biochem Biophys Res Commun 203(1):666–673.8074719
*Bhathal PS, Rose NR, Mackay IR, 1983. Strain differences in mice in carbon tetrachloride-induced liver injury. Br J Exp Pathol 64:524–533.6639871
*Bhattacharyya K. 1965. Foetal and neonatal responses to hepatotoxic agents. J Path Bact 90:151–161.5843936
*Bianchi AP, Varney MS, Phillips J. 1991. Analysis of volatile organic compounds in estuarine sediments using dynamic headspace and gas chromatography-mass spectrometry. J Chromatogr 542:413–450.
Biasi F, Albano E, Chiarpotto E, 1991. In vivo and in vitro evidence concerning the role of lipid peroxidation in the mechanism of hepatocyte death due to carbon tetrachloride. Cell Biochem Func 9:111–118.
*Bickel M, Baader E, Brocks DG, 1991. Beneficial effects of inhibitors of prolyl 4-hydroxylase in CCl_4_-induced fibrosis of the liver in rats. J Hepatology 13:S26–S34.
*Biesel KW, Ehrinpreis MN, Bhathal PS, 1984. Genetics of carbon tetrachloride-induced liver injury in mice. II. Multigenic regulation. Br J Exp Pathol 65:125–131.
Blain RB, Reeves R, Ewald KA, 1999. Susceptibility to chlordecone-carbon tetrachloride induced hepatotoxicity and lethality is both age and sex dependent. Toxicol Sci 50:280–286.
Blair A, Decoufle P, Grauman D. 1979. Causes of death among laundry and dry cleaning workers. Am J Public Health 69:508–511.434285
*Blair A, Hartge P, Stewart PA, 1998. Mortality and cancer incidence of aircraft maintenance workers exposed to trichloroethylene and other organic solvents and chemicals: Extended follow up. Occup Environ Med 55:161–171.
*Blair A, Stewart PA, Tolbert PE, 1990. Cancer and other causes of death among a cohort of dry cleaners. Br J Ind Med 47:162–168.2328223
*Blair PC, Thompson MB, Wilson RE, 1991. Correlation of changes in serum analytes and hepatic histopathology in rats exposed to carbon tetrachloride. Toxicol Lett 55:149–159.1998203
Blum DJ W, Speece RE. 1991a. A database of chemical toxicity to environmental bacteria and its use in interspecies comparisons and correlations. Res J Water Pollut Control Fed 63:198–207.
Blum DJ W, Speece RE. 1991b. Quantitative structure-activity relationships for chemical toxicity to environmental bacteria. Ecotoxicol Environ Saf 22:198–224.1769352
Bogen KT. 1990. Risk extrapolation for chlorinated methanes as promoters vs initiators of multistage carcinogenesis. Fundam Appl Toxicol 15:536–557.2258018
*Bogers M, Appelman LM, Feron VJ, 1987. Effects of the exposure profile on the inhalation toxicity of carbon tetrachloride in male rats. J Appl Toxicol 7:185–191.3624777
Boll M, Weber LW D, Becker E, 2001a. Hepatocyte damage induced by carbon tetrachloride: Inhibited lipoprotein secretion and changed lipoprotein composition. Z Naturforsch C 56(3–4):283–290.11371022
Boll M, Weber LW D, Becker E, 2001b. Mechanism of carbon tetrachloride-induced hepatotoxicity. Hepatocellular damage by reactive carbon tetrachloride metabolites. Z Naturforsch C 56:649–659.11531102
Boll M, Weber LW D, Becker E, 2001c. Pathogenesis of carbon tetrachloride-induced hepatocyte injury: Bioactivation of CCL_4_ by cytochrome P450 and effects on lipid homeostasis. Z Naturforsch C 56(1–2):111–121.11302200
*Bond GG, Flores GH, Shellenberger RJ, 1986. Nested case-control study of lung cancer among chemical workers. Am J Epidemiol 124(1):53–66.3717140
Bond GG, McLaren EA, Sabel FL, 1990. Liver and biliary tract cancer among chemical workers. Am J Ind Med 18:19–24.2378367
Borzelleca JF, O'Hara TM, Gennings C, 1990. Interactions of water contaminants. I. Plasma enzyme activity and response surface methodology following gavage administration of CCl_4_ and CHCl_3_ or TCE singly and in combination in the rat. Fundam Appl Toxicol 14:447–490.
Bosch-Marce M, Morales-Ruiz M, Jimenez W, 1998. Increased renal expression of nitric oxide synthase type III in cirrhotic rats with ascites. Hepatology 27(5):1191–1199.9581670
Bosma A, Brouwer A, Seifert WF, 1988. Synergism between ethanol and carbon tetrachloride in the generation of liver fibrosis. J Pathol 156:15–21.3193297
Botta D, Dancelli E, Mantica E. 1994. A case history of contamination by polychloro-1,3-butadiene congeners. Environ Sci Technol 30:453–462.
Boublik T, Fried V, Hala E. 1984. Untitled section. The vapour pressures of pure substances. Selected values of the temperature dependence of the vapour pressure of some pure substances in the normal and low pressure region, Vol. 17. 2nd revised ed. Amsterdam, The Netherlands: Elsevier, 111–112.
Boucquey J-B, Renard P, Amerlynck P, 1995. High-rate continuous biodegradation of concentrated chlorinated aliphatics by a durable enrichment of methanogenic origin carrier-dependent conditions. Biotechnol Bioeng 47(3):298–307.18623405
*Boutelet-Bochan H, Huang Y, Juchau MR. 1997. Expression of CYP2E1 during embryogenesis and fetogenesis in human cephalic tissues: Implications for the fetal alcohol syndrome. Biochem Biophys Res Commun 238(2):443–447.9299528
*Bove FJ, Fulcomer MC, Klotz JB, 1992a. Population-based surveillance and etiological research of adverse reproductive outcomes and toxic wastes. Report on Phase IV-A: Public drinking water contamination and birthweight, fetal deaths, and birth defects. A cross-sectional study. New Jersey Department of Health.
*Bove FJ, Fulcomer MC, Klotz JB, 1992b. Population-based surveillance and etiologic research of adverse reproductive outcomes and toxic wastes. Report on Phase IV-B: Public drinking water contamination and birthweight, fetal deaths, and birth defects. A case-control study. New Jersey Department of Health.
*Bove FJ, Fulcomer MC, Klotz JB, 1995. Public drinking water contamination and birth outcomes. Am J Epidemiol 141(9):850–862.7717362
*Boyd MR, Statham CN, Longo NS. 1980. The pulmonary Clara cell as a target for toxic chemicals requiring metabolic activation; studies with carbon tetrachloride. J Pharmacol Exp Ther 212:109–114.7351618
Bozzelli J, Kebbekus BB. 1982. A study of some aromatic and halocarbon vapors in the ambient atmosphere of New Jersey. J Environ Sci Technol 9:833–838.
Brady JF, Li D, Ishizaki H, 1989. Induction of cytochromes P450IIE1 and P450IIB1 by secondary ketones and the role of P450IIE1 in chloroform metabolism. Toxicol Appl Pharmacol 100:342–349.2781561
*Brady JF, Xiao F, Wang M-H, 1991. Effects of disulfiran on hepatic P450IIE1, other microsomal enzymes, and hepatotoxicity in rats. Toxicol Appl Pharmacol 108:366–373.1850173
*Brambilla G, Carlo P, Finollo R, 1983. Viscometric detection of liver DNA fragmentation in rats treated with minimal doses of chemical carcinogens. Cancer Res 43:202–209.6847769
*Brams A, Buchet JP, Crutzen-Fayt MC, 1987. A comparative study, with 40 chemicals, of the efficiency of the Salmonella assay and the SOS chromotest (kit procedure). Toxicol Lett 38:123–133.3307023
Brandom WF, McGavran L, Bistline RW, 1990. Sister chromatid exchanges and chromosome aberration frequencies in plutonium workers. Int J Radiat Biol 58:195–207.1973437
Brattin WJ, Glende EA Jr., Recknagel RD. 1985. Pathological mechanisms in carbon tetrachloride hepatotoxicity. J Free Radical Biol Med 1:27–38.3915301
Brattin WJ, Pencil SD, Waller RL, 1984. Assessment of the role of calcium ion in halocarbon hepatotoxicity. Environ Health Perspect 57:321–323.6499814
*Brennan RJ, Schiestl RH. 1998. Chloroform and carbon tetrachloride induce intrachromosomal recombination and oxidative free radicals in Saccharomyces cerevisiae. Mutat Res 397:271–278.9541652
Brent JA, Rumack BH. 1993. Role of free radicals in toxic hepatic injury II. Are free radicals the cause of toxin-induced liver injury? Clin Toxicol 31:173–196.
Briggs GG. 1973. A simple relationship between soil adsorption of organic chemicals and their octanol/water partition coefficients. Proceedings of the 7th British Insecticide Fungicide Conference, 83–86.
Brittebo EB, Brandt I. 1989. Metabolic activation of carbon tetrachloride by the cervico-vaginal epithelium in rodents. Pharmacol Toxicol 65:336–342.2516313
*Brittebo EB, Eriksson C, Brandt I. 1990. Metabolic activation of halogenated hydrocarbons in the conjunctival epithelium and excretory ducts of the intraorbital lacrimal gland in mice. New York, NY: Academic Press, 245–252.
*Brodzinski R, Singh HB. 1983. Volatile organic chemicals in the atmosphere: An assessment of available data. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600383027(A).
*Brondeau MT, Bonnet P, Guenier JP, 1983. Short-term inhalation test for evaluating industrial hepatotoxicants in rats. Toxicol Lett 19:139–146.6658818
*Brondeau MT, Coulais C, de Ceaurriz J. 1991. Difference in liver and serum malathion carboxylesterase and glucose-6-phosphatase in detecting carbon tetrachloride-induced liver damage in rats. J Appl Toxicol 11:433–435.1662244
*Brown KW, Donnelly KC. 1988. An estimation of risk associated with the organic constituents of hazardous and municipal waste landfill leachates. Hazardous Waste and Hazardous Materials 5(1):1–30.
Brown SK, Sim MR, Abramson, 1994. Concentrations of volatile organic compounds in indoor air- A review. Indoor Air 4:123–134.
*Bruccoleri A, Gallucci R, Germolec DR, 1997. Induction of early-immediate genes by tumor necrosis factor alpha contribute to liver repair following chemical-induced hepatotoxicity. Hepatology 25(1):133–141.8985279
*Bruckner JV, Kim HJ, Muralidhara S, 1990. Influence of route and pattern exposure on the pharmacokinetics and hepatotoxicity of carbon tetrachloride. In: Gerrity TR, Henry CJ, eds. Principle of route to route extrapolation for risk assessment. New York, NY: Elsevier Science Publishing Co., Inc., 271–284.
*Bruckner JV, Luthra R, Kyle GM, 1984. Influence of time of exposure to carbon tetrachloride on toxic liver injury. Ann Rev Chronopharmacol 1:373–376.
*Bruckner JV, MacKenzie WF, Muralidhara S, 1986. Oral toxicity of carbon tetrachloride: Acute, subacute and subchronic studies in rats. Fundam Appl Toxicol 6:16–34.3710021
Bruckner JV, Ramanathan R, Lee KM, 2002. Mechanisms of circadian rhythmicity of carbon tetrachloride hepatotoxicity. J Pharmacol Exp Ther 300(1):273–281.11752126
Brunke EG, Allen RJ. 1988. Tropospheric background measurements of CFCl_3_, CH_3_CCl_3_, and CCl_4_ at Cape Point, South Africa, and their long-term trends. South African J Sci 84:266–270.
*Brzezinski MR, Boutelet-Bochan H, Person RE, 1999. Catalytic activity and quantitation cytochrome P-450 2E1 in prenatal human brain. J Pharmacol Exp Ther 289:1648–1653.10336564
*Buhler R, Lindros KO, Nordling A, 1992. Zonation of cytochrome P450 isozyme expression and induction in rat liver. Eur J Biochem 204(1):407–412.1740154
Bull RJ, Sasser LB, Lei XC. 2004. Interactions in the tumor-promoting activity of carbon tetrachloride, trichloroacetate, and dichloroacetate in the liver of male B6C3F1 mice. Toxicology 199:169–183.15147791
Bullister JL, Wesegarver DP. 1998. The solubility of carbon tetrachloride in water and seawater. 45:1285–1302.
Burk RF, Reiter R, Lane JM. 1986. Hyperbaric oxygen protection against carbon tetrachloride hepatotoxicity in the rat. Association with altered metabolism. Gastroenterol 90:812–818.
*Burkhart KK, Hall AH, Gerace R, 1991. Hyperbaric oxygen treatment for carbon tetrachloride poisoning. Drug Safety 6:332–338.1930739
Butler TC. 1961. Reduction of carbon tetrachloride in vivo and reduction of carbon tetrachloride and chloroform in vitro by tissues and tissue constituents. J Pharmacol Exper Therap 134:311–319.13875205
*C&EN. 1992. Production by the U.S. Chemical Industry. Chemical and Engineering News, June 29, 1992, 36.
*C&EN. 1993. Production by the U.S. Chemical Industry. Chemical and Engineering News, June 28, 1993.
Cabre M, Camps J, Paternain JL, 2000. Time-course of changes in hepatic lipid peroxidation and glutathione metabolism in rats with carbon tetrachloride-induced cirrhosis. Clin Exp Pharmacol Physiol 27:694–699.10972535
*Cagen SZ, Klaassen CD. 1979. Hepatotoxicity of carbon tetrachloride in developing rats. Toxicol Appl Pharmacol 50:347–354.505463
*Cai Z, Mehendale HM. 1990. Lethal effects of CCl_4_ and its metabolism by Mongolian gerbils pretreated with chlordecone, phenobarbital, or mirex. Toxicol Appl Pharmacol 104:511–520.1696756
*Cai Z, Mehendale HM. 1991a. Hepatotoxicity and lethality of halomethanes in Mongolian gerbils pretreated with chlordecone, phenobarbital or mirex. Arch Toxicol 65:204–212.1711308
*Cai Z, Mehendale HM. 1991b. Prestimulation of hepatocellular regeneration by partial hepatectomy decreases toxicity of carbon tetrachloride in gerbils. Biochem Pharmacol 42:633–644.1859467
*Cai Z, Mehendale HM. 1993. Resiliency to amplification of carbon tetrachloride hepatoxicity by chlordecone during postnatal development in rats. Pediatr Res 33:225–232.7681558
*Calabrese EJ, Baldwin LA, Leonard DA, 1995. Decrease in hepatotoxicity by lead exposure is not explained by its mitogenic response. J Appl Toxicol 15(2):129–132.7782558
*Calabrese EJ, Baldwin LA, Mehendale HM. 1993. Contemporary issues in toxicology. G_2_ subpopulation in rat liver induced into mitosis by low-level exposure to carbon tetrachloride: An adaptive response. Toxicol Appl Pharmacol 121:1–7.7687794
Calleja MC, Geladi P, Persoone G, 1994. Modelling of human acute toxicity from physicochemical properties and non-vertebrate acute toxicity of the 38 organic chemicals of the MEIC priority list by PLS regression and neural network. Food Chem Toxicol 32(10):923–941.7959448
*Callen DF, Wolf CR, Philpot RM. 1980. Cytochrome P-450 mediated genetic activity and cytotoxicity of seven halogenated aliphatic hydrocarbons in Saccharomyces cerevisiae. Mutat Res 77:55–63.6767185
*Cambron-Gros C, Deltour P, Boigegrain R-A, 1986. Radical activation of carbon tetrachloride in foetal and maternal rat liver microsomes. Biochem Pharmacol 35(12):2041–2044.3013208
*Campo GM, Avenoso A, Campo S, 2004. Hyaluronic acid and chondroitin-4-sulphate treatment reduces damage in carbon tetrachloride-induced acute rat liver injury. Life Sci 74:1289–1305.14697411
*Camps J, Bargallo T, Gimenez A, 1992. Relationship between hepatic lipid peroxidation and fibrogenesis in carbon tetrachloride-treated rats: Effect of zinc administration. Clin Sci 83:695–700.
*Cantor KP, Stewart PA, Brinton LA, 1995. Occupational exposures and female breast cancer mortality in the United States. J Occup Environ Med 37(3):336–348.7796202
Capurro PU. 1979. Cancer in a community subject to air pollution by solvent vapors. Clin Toxicol 14:285–294.455919
Carakostas MC, Gossett KA, Church GE, 1986. Evaluating toxin-induced hepatic injury in rats by laboratory results and discriminant analysis. Vet Pathol 23:264–269.3014705
Carlson GP. 1989. Effect of ethanol, carbon tetrachloride, and methyl ethyl ketone on butanol oxidase activity in rat lung and liver. J Toxicol Environ Health 27:255–261.2733061
Carpenter AV, Flanders WD, Frome EL, 1988. Chemical exposures and central nervous system cancers: A case-control study among workers at two nuclear facilities. Am J Ind Med 13:351–362.3354584
*Carpenter SP, Lasker JM, Raucy JL. 1996. Expression, induction, and catalytic activity of the ethanol-inducible cytochrome P450 (CYP2E1) in human fetal liver and hepatocytes. Mol Pharmacol 49:260–268.8632758
Carpenter SP, Savage DD, Schultz ED, 1997. Ethanol-mediated transplantational induction of CYP2E1 in fetal rat liver. J Pharmacol Exp Ther 282:1028–1036.9262372
*Castilla-Cortazar I, Garcia M, Muguerza B, 1997. Hepatoprotective effects of insulin-like growth factor I in rats with carbon tetrachloride-induced cirrhosis. Gastroenterology 113(5):1682–1691.9352873
*Castillo T, Koop DR, Kamimura S, 1992. Role of cytochrome P-450 2E1 in ethanol-, carbon tetrachloride- and iron-dependent microsomal lipid peroxidation. Hepatology 16(4):992–996.1398507
Castro JA, Diaz-Gomez MI. 1972. Studies on the irreversible binding of ^14^C-Carbon tetrachloride to microsomal lipids in rats under varying experimental conditions. Toxicol Appl Pharmacol 23:541–552.4264776
*Castro GD, Diaz Gomez MI, Castro JA. 1989. Species differences in the interaction between CCl4 reactive metabolites and liver DNA or nuclear protein fractions. Carcinogenesis 10(2):289–294.2643484
Castro GD, Diaz-Gomez MI, Castro JA. 1990. Biotransformation of carbon tetrachloride and lipid peroxidation promotion by liver nuclear preparations from different animal species. Cancer Lett 53:9–15.2397486
*Castro GD, Diaz Gomez MI, Castro JA. 1997. DNA bases attack by reactive metabolites produced during carbon tetrachloride biotransformation and promotion of liver microsomal lipid peroxidation. Res Commun Mol Pathol Pharmacol 95(3):253–258.9144833
Castro GD, López AJ, Petricio AR, 1986. Effect of the pretreatment with pyrazole, cystamine or diphenyl-P-phenylenediamine (DPPD) on the CCl_4_-promoted pentane evolution in rats. Res Commun Chem Pathol Pharmacol 52:137–140.3715195
Castro GD, Simpson JT, Castro JA. 1994. Interaction of trichloromethyl free radicals with thymine in a model system: A mass spectrometric study. Chem Biol Interact 90:13–22.8131216
*Castro JA, de Ferreyra EC, de Castro CR, 1973. Studies on the mechanism of cystamine prevention of several liver structural and biochemical alterations caused by carbon tetrachloride. Toxicol Appl Pharmacol 24:1–19.4346916
*CDC/ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary and immune systems. Atlanta, GA: CDC/ATSDR Subcommittee on Biomarkers of Organ Damage and Dysfunction, Centers for Disease Control, Agency for Toxic Substances and Disease Registry. Summary report, August 27, 1990.
CDHS. 1988. Notice of proposed rulemaking. June 23. Sacramento, CA: California Department of Health Services.
*Cedillo A, Mourelle M, Muriel P. 1996. Effect of colchicine and trimethylocolchicinic acid on CCL4-induced cirrhosis in the rat. Pharmacol Toxicol 79(5):241–246.8936557
*CEH. 1985. CEH product review. Chlorinated methanes. Chemical economic handbook-SRI International, 635.2020A-635.2022B.
Cessi C, Colombini C, Mameli L. 1966. The reaction of liver proteins with a metabolite of carbon tetrachloride. Biochem J 101:46c–47c.
Chadwick RW, Copeland MF, Carlson GP, 1988. Comparison of in vivo and in vitro methods for assessing the effects of carbon tetrachloride on the hepatic drug-metabolizing enzyme system. Toxicol Lett 42:309–316.2459810
Chamuleau RA, Creyghton JH, De Nie I, 1988. Is the magnetic resonance imaging proton spin-lattice relaxation time a reliable noninvasive parameter of developing liver fibrosis. Hepatology 8:217–221.3356402
Chamultirat W, Jordan SJ, Mason RP. 1994. Nitric oxide production during endotoxic shock in carbon tetrachloride-treated rats. Mol Pharmacol 46(2):391–397.8078502
*Chandler FA. 1936. The use of carbon tetrachloride in the removal of adhesive tape. Report of a near fatal case. J Am Med Assoc 107:2121.
*Chandler AC, Chopra RN. 1926. Effects of the administration of sugar, magnesium sulfate, sodium citrate and dilute acid on the liver damage done by carbon tetrachloride. Ind J Med Res 14:219–226.
Chang IM. 1998. Liver-protective activities of aucubin derived from traditional oriental medicine. Res Commun Mol Pathol Pharmacol 102(2):189–204.10100510
*Chapman K, Prabhudesai M, Erdman JW. 1992. Effects of ethanol and carbon tetrachloride upon vitamin A status of rats. Alcoholism: Clinical and Experimental Research 16:764–768.1530140
Charbonneau M, Couture J, Plaa GL. 1991. Inhalation versus oral administration of acetone: Effect of the vehicle on the potentiation of CCl_4_-induced liver injury. Toxicol Lett 57:47–54.2048161
*Charbonneau M, Oleskevich S, Brodeur J, 1986. Acetone potentiation of rat liver injury induced by trichloroethylene-carbon tetrachloride mixtures. Fundam Appl Toxicol 6:654–661.3710035
Charbonneau M, Tuchweber B, Plaa GL. 1986. Acetone potentiation of chronic liver injury induced by repetitive administration of carbon tetrachloride. Hepatology 6(4):694–700.3733003
*Chatterjee A. 1966. Testicular degeneration in rats by carbon tetrachloride intoxication. Experientia 226:395–396.
*Chaudhary AK, Nokubo M, Reddy GR, 1994. Detection of endogenous malondialdehyde-deoxyguanosine adducts in human liver. Science 265(5178):1580–1582.8079172
Chaudhury S, Mehendale HM. 1991. Amplification of CCl_4_ toxicity by chlordecone: Destruction of rat hepatic microsomal cytochrome P-450 subpopulation. J Toxicol Environ Health 32:277–294.1705986
*Checkoway H, Wilcosky T, Wolf P, 1984. An evaluation of the associations of leukemia and rubber industry solvent exposures. Am J Ind Med 5(3):239–249.6702828
Chen JD, Wang JD, Jang JP, 1991. Exposure to mixtures of solvents among paint workers and biochemical alterations of liver function. Br J Ind Med 48:696–701.1931729
Chen WJ, Chi EY, Smuckler EA. 1977. Carbon tetrachloride-induced changes in mixed function oxidases and microsomal cytochromes in the rat lung. Lab Invest 36:388–394.15163
*Chiarpotto E, Biasi F, Comoglio A, 1990. CCl_4_-induced increase of hepatocyte free arachiodonate level: Pathogenesis and contribution to cell death. Chem Biol Interact 74:195–206.2108808
*Chiu PY, Tang MH, Mak DH F, 2003. Hepatoprotective mechanism of schisandrin B: Role of mitochondrial glutathione antioxidant status and heat shock proteins. Free Radic Biol Med 35(4):368–380.12899939
Choi-Miura N-H, Otsuyama K, Sano Y, 2001. Hepatic injury-specific conversion of mouse plasma hyaluronan binding protein to the active hetero-dimer form. Biol Pharm Bull 24(8):892–896.11510480
*Cholbi MR, Paya M, Alearaz MJ. 1991. Inhibitory effects of phenolic compounds on CCl_4_-induced microsomal lipid peroxidation. Research Articles 47:195–199.
Christenson WR, Davis ME, Berndt WO. 1989. Effect in the rat of the interaction of dichloromaleic acid and carbon tetrachloride on renal and hepatic function. Fundam Appl Toxicol 13:493–499.2612781
*Chung F-L, Nath RG, Ocando J, 2000. Deoxyguanosine adducts of t-4-hydroxy-2-nonal are endogenous DNA lesions in rodents and humans: Detection and potential sources. Cancer Res 60:1507–1511.10749113
*Clair P, Tua M, Simian H. 1991. Capillary columns in series for GC analysis of volatile organic pollutants in atmospheric and alveolar air. J High Resolut Chromatogr 14:383–387.
Clawson GA. 1989. Mechanisms of carbon tetrachloride hepatotoxicity. Pathol Immunopathol Res 8:104–112.2662164
Clawson GA, Blankenship LJ, Rhame JG, 1992. Nuclear enlargement induced by hepatocarcinogens alters ploidy. Cancer Res 52:1304–1308.1737393
Clawson GA, MacDonald JR, Woo CH. 1987. Early hypomethylation of 2'-O-ribose moieties in hepatocyte cytoplasmic ribosomal RNA underlies the protein synthetic defect produced by CCl_4_. J Cell Biol 105:705–711.3114267
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131 3843496
*Cohen MM. 1957. Central nervous system in carbon tetrachloride intoxication. Neurology 7:238–244.13418960
Cohen MA, Ryan PB, Spengler JD. 1991. Source-receptor study of volatile organic compounds and particulate matter in the Kanawha Valley, WV—II. Analysis of factors contributing to VOC and particle exposures. Atmos Environ 25B:95–107.
Cohen MA, Ryan PB, Yanagisawa Y, 1989. Indoor/outdoor measurements of volatile organic compounds in the Kanawha Valley of West Virginia. JAPCA 39:1086–1093.2795113
Cohen S, Svrjcek A, Durborrow T, 1999. Ground water quality Water quality impacts by golf courses. J Environ Qual 28:798–809.
*Colborn T, Clement C. 1992. Chemically induced alterations in sexual and functional development. The Wildlife/Human Connection. In: Advances in modern environmental toxicology. Volume XXI. Princeton, NJ: Princeton Scientific Publishing Co.
Colby HD, Purcell H, Kominami S, et al. 1994. Adrenal activation of carbon tetrachloride: Role of microsomal P450 isozymes. Toxicology 94:31–40.
Coleman JB, Condie LW, Lamb RG. 1988. The role of CCl_4_ biotransformation in the activation of hepatocyte phospholipase C in vivo and in vitro. Toxicol Appl Pharmacol 95:208–219.3420613
Columbano A, Ledda-Columbano GM, Ennas MG, 1990. Cell proliferation and promotion of rat liver carcinogenesis: Different effect of hepatic regeneration and mitogen induced hyperplasia on the development of enzyme-altered foci. Carcinogenesis 11:771–776.1970763
Columbano A, Rajalakshmi S, Sarma DS R. 1981. Requirement of cell proliferation for the initiation of liver carcinogenesis as assayed by three different procedures. Cancer Res 41:2079–2083.6113048
*Comporti M. 1985. Biology of disease: Lipid peroxidation and cellular damage in toxic liver injury. Lab Invest 53(6):599–623.3906270
Comporti M. 1989. Three models of free radical-induced cell injury. Chem Biol Interact 72:1–56.2684438
*Conaway HB, Hoven F. 1946. Electrocardiographic changes in carbon tetrachloride poisoning. U.S. Navy Med Bull 46:593–595.
*Condie LW, Laurie RD, Mills T, 1986. Effect of gavage vehicle on hepatotoxicity of carbon tetrachloride in CD-l mice:corn oil versus Tween-60 aqueous emulsion. Fundam Appl Toxicol 7:199–206.3758537
Connor HD, Lacagnin LB, Knecht KT, 1989. Reaction of glutathione with a free radical metabolite of carbon tetrachloride. Mol Pharmacol 37:443–451.
Connor HD, Thurman RG, Chen G, 1998. Clarification of the relationship between free radical spin trapping and carbon tetrachloride metabolism in microsomal systems. Free Radic Biol Med 24(9):1364–1368.9641253
*Connor HD, Thurman RG, Galizi MD, 1986. The formation of a novel free radical metabolite from CCl_4_ in the perfused rat liver and in vivo. J Biol Chem 261:4542–4548.3007463
*Cornish HH, Adefuin J. 1966. Ethanol potentiation of halogenated aliphatic solvent toxicity. Am Ind Hyg Assoc J 27:57–61.5920489
*Cornish HH, Ling BP, Barth ML. 1973. Phenobarbital and organic solvent toxicity. Am Ind Hyg Assoc J 34:487–492.4770171
Corsi RL, Chang DP, Schroeder ED, 1987. Emissions of volatile and potentially toxic organic compounds from municipal wastewater treatment plants. Presented at the 80th annual meeting of the APCA. New York, NY: Air Pollution Control Association.
Cotrim HP, Andrade ZA, Parana R, 1999. Nonalcoholic steatohepatitis: A toxic liver disease in industrial workers. Liver 19:299–304.10459628
Cotson R, Williams T. 1982. Headspace chromatographic determination of water pollutants. Anal Chem 54:942.
*Coutino RR. 1979. Analysis of anaphase in cell culture: An adequate test system for the distinction between compounds which selectively alter the chromosome structure or the mitotic apparatus. Environ Health Perspect 31:131–136.387394
*Cox RA, Derwent RG, Eggleton AE J. 1976. Photochemical oxidation of halocarbons in the troposphere. Atmos Environ 10:305–308.
*Craddock VM, Henderson AR. 1978. De novo and repair replication of DNA in liver of carcinogen-treated animals. Cancer Res 38:2135–2143.657145
*Crebelli R, Carere A, Leopardi P, 1999. Evaluation of 10 aliphatic halogenated hydrocarbons in the mouse bone marrow micronucleus test. Mutagenesis 14(2):207–215.10229923
Criddle CS, McCarty PL. 1991. Electrolytic model system for reductive dehalogenation in aqueous environments. Environ Sci Technol 25:973–978.
Criddle CS, DeWitt JT, Grbic-Galic D, 1990. Transformation of carbon tetrachloride by pseudomonas sp. strain KC under denitrification conditions. Appl Environ Microbiol 56:3240–3246.2268146
*CRISP. 1993. Computer Retrieval of Information on Scientific Projects. National Institutes of Health, Division of Research Grants. Bethesda, MD: May 15, 1993.
*Crist HL, Mitchell WJ. 1986. Field audit results with organic gas standards on volatile organic ambient air samplers equipped with Texas GC. Environ Sci Technol 20:1260–1262.
*Croen LA, Shaw GM, Sanbonmatsu L, 1997. Maternal residential proximity to hazardous waste sites and risk for selected congenital malformations. Epidemiology 8:347–354.9209846
*Cruz C, Ibarra-Rubio ME, Pedraza-Chaverri J. 1993. Circulating levels of active, total and inactive renin (prorenin), angiotensin-I and angiotensinogen in carbon tetrachloride-treated rats. Clin Exp Pharmacol Physiol 30:83–88.
Cunnane SC. 1987. Hepatic triacylglycerol accumulation induced by ethanol and carbon tetrachloride: Interactions with essential fatty acids and prostaglandins. Alcoholism Clin Exp Res 11:25–31.
Currier AR, Sabla G, Locaputo S, 2003. Plasminogen directs the pleiotropic effects of uPA in liver injury and repair. Am J Physiol 284:G508–G515.
*Curtis GP, Reinhard M. 1992. Reductive dehalogenation of hexachlorethane, carbon tetrachloride and bromoform by anthrahydroquinone disulfonate and humic acid. Abstr Pap Am Chem Soc 203:91.
*Curtis LR, Williams WL, Mehendale HM. 1979. Potentiation of the hepatotoxicity of carbon tetrachloride following preexposure to chlordecone (kepone) in the male rat. Toxicol Appl Pharmacol 51:283–293.93792
Cutrin C, Menino J, Carballo C, 1994. Nifedipine in rat liver cirrhosis. Vet Hum Toxicol 36(1):13–17.
Cutrin C, Menino MJ, Otero X, 1992. Effect of nifedipine and S-adenosylmethionine in the liver of rats treated with CCl4 and ethanol for one month. Life Sci 51:113–118.1319534
*Czaja MJ, Xu J, Alt E. 1995. Prevention of carbon tetrachloride-induced rat liver injury by soluble tumor necrosis factor receptor. Gastroenterology 108(6):1849–1854.7768392
Dabeva MD, Alpini G, Hurston E, 1993. Models of hepatic progenitor cell activation. Proc Soc Exp Biol Med 204(3):242–252.7694303
*Dai Y, Cederbaum AI. 1995. Inactivation and degradation of human cytochrome P4502E1 by CCl4 in a transfected HepG2 cell line. J Pharmacol Exp Ther 275:1614–1622.8531136
Daft JL. 1989. Determination of fumigants and related chemicals in fatty and nonfatty foods. J Agric Food Chem 37:560–564.
*Daft JL. 1991. Fumigants and related chemicals in foods: Review of residue findings, contamination sources and analytical methods. Sci Total Environ 100:501–518.2063187
Dalu A, Mehendale HM. 1996. Efficient tissue repair underlies the resiliency of postnatally developing rats to chlordecone + CCL4 hepatotoxicity. Toxicology 111(1–3):29–42.8711744
Dalu A, Rao PS, Mehendale HM. 1998. Colchicine antimitosis abolishes resiliency of postnatally developing rats to chlorecone-amplified carbon tetrachloride hepatotoxicity and lethality. Environ Health Perspect 106(9):597–606.9721260
Dalu A, Warbritton A, Bucci TJ, 1995. Age-related suseptibility to chlordecone-potentiated carbon tetrachloride hepatotoxicity and lethality is due to hepatic quiescence. Pediatr Res 38(2):140–148.7478807
*Dambrauskas T, Cornish HH. 1970. Effect of pretreatment of rats with carbon tetrachloride on tolerance development. Toxicol Appl Pharmacol 17:83–97.5456645
*Danni O, Aragno M, Tamagno E, 1992. In vivo studies on halogen compound interactions. IV. Interaction among different halogen derivatives with and without synergistic action on liver toxicity. Res Commun Chem Pathol Pharmacol 76(3):355–366.1636057
Danni O, Aragno M, Ugazio G. 1988. In vivo studies on halogen compound interactions. Res Commun Chem Pathol Pharmacol 61:377–390.3055109
*Dashti HM, Al-Sayer H, Behbehani A, 1992. Liver cirrhosis induced by carbon tetrachloride and the effects of superoxide dismutase and xanthine oxidase inhibitor treatment. J R Coll Surg Edinb 37:23–28.1573602
da Silva Augusto LG, Lieber SR, Ruiz MA, 1997. Micronucleus monitoring to assess human occupational exposure to organochlorides. Environ Mol Mutagen 29:46–52.9020306
*Date M, Matsuzaki K, Matsushita M, 1998. Differential expression of transforming growth factor-beta and its receptors in hepatocytes and nonparenchymal cells of rat liver after CCl4 administration. J Hepatol 28(4):572–581.9566825
*David A, Frantik E, Holusa R, 1981. Role of time and concentration on carbon tetrachloride toxicity in rats. Int Arch Occup Environ Health 48:49–60.7216502
*Davis DD, Schmidt JF, Neeley CM, 1975. Effect of wavelength in the gas-phase photolysis of carbon tetrachloride at 253.7, 184.9, 147, and 106.7 nm. J Phys Chem 79:11–17.
*Dawkins MJ R. 1963. Carbon tetrachloride poisoning in the liver of the new-born rat. J Pathol Bact 85:189–196.14025587
*Day WW, Weiner M. 1991. Short communications: Inhibition of hepatic drug metabolism and carbon tetrachloride toxicity in Fischer-344 rats by exercise. Biochem Pharmacol 42:181–184.2069590
*Dean BJ, Hodson-Walker G. 1979. An in vitro chromosome assay using cultured rat-liver cells. Mutat Res 64:329–337.117353
*de Best JH, Salminen E, Doddema HJ, 1998. Transformation of carbon tetrachloride under sulfate reducing conditions. Biodegradation 8(6):429–436
De Bleser PJ, Scott CD, Niki T, 1996. Insulin-like growth factor II/mannose 6-phosphate-receptor expression in liver and serum during acute CCl_4_ intoxication in the rat. Hepatology 23(6):1530–1537.8675174
De Bleser PJ, Xu G, Rombouts K, 1999. Glutathione levels discriminate between oxidative stress and transforming growth factor-B signaling in activated rat hepatic stellate cells. J Biol Chem 274(48):33881–33887.10567349
*De Castro CR, Bernacchi AS, De Ferreyra EC, 1978. Carbon tetrachloride induced ultrastructural alterations in pancreatic acinar cells and in the hepatocytes. Similarities and differences. Toxicology 11:289–296.734684
DeCicco LA, Rikans LE, Tutor CG, 1998. Serum and liver concentrations of tumor necrosis factor alpha and interleukin-1beta following the administration of carbon tetrachloride to male rats. Toxicol Lett 98(1–2):115–121.9776568
*Deer HM, McJilton CE, Harein PK. 1987. Respiratory exposure to grain inspection workers to carbon tetrachloride fumigant. Am Ind Hyg Assoc J 48:586–593.3618471
*de Ferreyra EC, Castro JA, Diaz Gomez MI. 1974. Prevention and treatment of carbon tetrachloride hepatotoxicity by cysteine: Studies about its mechanism. Toxicol Appl Pharmacol 27:558–568.4137122
*De Flora S. 1981. Study of 106 organic and inorganic compounds in the salmonella/microsome test. Carcinogenesis 2(4):283–298.7023727
*De Flora S, Zanacchi P, Camoirano A, 1984. Genotoxic activity and potency of 135 compounds in the Ames reversion test and in a bacterial DNA-repair test. Mutat Res 133:161–198.6374443
*De Groot H, Haas W. 1980. O_2_-independent damage of cytochrome P450 by CCl_4_-metabolites in hepatic microsomes. FEBS Lett 115(2):253–265.7398883
*De Groot H, Haas W. 1981. Self-catalysed, O_2_-independent inactivation of NADPH- or dithionite-reduced microsomal cytochrome P-450 by carbon tetrachloride. Biochem Pharmacol 30(16):2343–2347.7295345
DeGroot H, Noll T. 1989. Halomethane hepatotoxicity: Induction of lipid peroxidation and inactivation of cytochrome P-450 in rat liver microsomes under low oxygen partial pressures. Toxicol Appl Pharmacol 97:530–537.2609348
Delaney B, Kaminski NE. 1993. Induction of serum-borne immunomodulatory factors in B6C3F1 mice by carbon tetrachloride. I. Carbon tetrachloride-induced suppression of helper T-lymphocyte function is mediated by a serum borne factor. Toxicology 85:67–84.8291070
*Delaney B, Strom SC, Collins S, 1994. Carbon tetrachloride suppresses T-cell-dependent immune responses by induction of transforming growth factor-β1. Toxicol Appl Pharmacol 126:98–107.8184439
DeLeon IR, Overton EB, Raschke CK, 1980. Rapid gas chromatographic method for the determination of volatile and semivolatile organochlorine compounds in soil and chemical waste disposal site samples. J Chromatogr Sci 18:85–88.
Delic JI, Lilly PD, MacDonald AJ, 2000. The utility of PBPK in the safety assessment of chloroform and carbon tetrachloride. Regul Toxicol Pharmacol 32:144–155.11067771
Deliconstantinos G, Mykoniatis M, Papadimitriou D. 1986. Carbon tetrachloride modulates the rat hepatic microsomal UDP-glucuronyl transferase activity and membrane fluidity. Experientia 42:181–183.3081363
*Della Porta GD, Terracini B, Shubik P. 1961. Induction with carbon tetrachloride of liver cell carcinomas in hamsters. J Natl Cancer Inst 26:855–863.13721616
DeLorey DC, Cronn DR, Farmer JC. 1988. Tropospheric latitudinal distributions of CF_2_Cl_2_, CFCl_3_, N_2_O, CH_3_CCl_3_, and CCl_4_ over the remote Pacific Ocean. Atmos Environ 22:1481–1494.
Deng JF, Wang JD, Shih TS, 1987. Outbreak of carbon tetrachloride poisoning in a color printing factory related to the use of isopropyl alcohol and air conditioning systems in Taiwan. Am J Ind Med 12:11–19.3618597
*Dennis KJ, Ichinose T, Miller M. 1993. Gas chromatographic determination of vapor-phase biomarkers formed from rats dosed with CCl4. J Appl Toxicol 13(4):301–303.8376731
*Desaiah D, Pentyala SN, Trottman CH, 1991. Combined effects of carbon tetrachloride and chlordecone on calmodulin activity in gerbil brain. J Toxicol Environ Health 34:219–228.1717700
*De Toranzo EG, Diaz Gomez MI, Castro JA. 1978a. Carbon tetrachloride activation, lipid peroxidation and liver necrosis in different strains of mice. Res Commun Chem Pathol Pharmacol 19:347–352.644126
*De Toranzo EG, Villarruel MC, Castro JA. 1978b. Early destruction of cytochrome P-450 in testis of carbon tetrachloride poisoned rats. Toxicology 10:39–44.675716
DeWulf J, Vanlangenhove H. 1997. Chlorinated c1 and c2-hydrocarbons and monocyclic aromatic hydrocarbons in marine waters: An overview on fate processes, sampling, analysis and measurements. Water Res 31:1825–1838.
de Zwart LL, Hermanns RC A, Meerman JH N, 1998. Evaluation of urinary biomarkers for radical-induced liver damage in rats treated with carbon tetrachloride. Toxicol Appl Pharmacol 148(1):71–82.9465266
*De Zwart LL, Venhorst J, Groot M, 1997. Simultaneous determination of eight lipid peroxidation degradation products in urine of rats treated with carbon tetrachloride using gas chromatography with electron-capture detection. J Chromatogr B Biomed Sci Appl 694(2):277–287.9252041
*Diaz-Gil JJ, Munoz J, Albillos A, 1999. Improvement in liver fibrosis, functionally and hemodynamics in CCL4-cirrhotic rats after injection of the liver growth factor. J Hepatol 30(6):1065–1072.10406185
*Diaz Gomez MI, Castro JA. 1980a. Covalent binding of carbon tetrachloride metabolites to liver nuclear DNA, proteins and lipids. Toxicol Appl Pharmacol 56:199–206.7466819
*Diaz Gomez MI, Castro JA. 1980b. Nuclear activation of carbon tetrachloride and chloroform. Res Commun Chem Pathol Pharmacol 27:191–193.7361000
*Diaz Gomez MI, De Castro CR, D'Acosta N, 1975. Species differences in carbon tetrachloride induced hepatotoxicity: The role of CCl_4_ activation and of lipid peroxidation. Toxicol Appl Pharmacol 34:102–114.1198608
Diaz-Munoz M, Tapia R. 1988. Glutamate decarboxylase inhibition and vitamin B_6_ metabolism in brain of cirrhotic rats chronically treated with carbon tetrachloride. J Neurosci Res 20:376–382.3225873
Dich J, Zahm SH, Hanberg A, 1997. Pesticides and cancer. Cancer Causes Control 8:420–443.9498903
*Dickens BF. 1991. Free radical mechanisms of xenobiotic mammalian cytotoxicities. Washington, DC: The George Washington University Medical Center.
*Dilling WL. 1977. Interphase transfer processes. II. Evaporation of chloromethanes, ethanes, propanes and polypropylenes from dilute aqueous solutions. Comparisons with theoretical predictions. Environ Sci Technol 11:405–409.
*Dilling WL, Tefertiller NB, Kallos GJ. 1975. Evaporation rates and reactivities of methylene chloride, chloroform, 1,1,1-trichloroethane, trichloroethylene, tetrachloroethylene, and other chlorinated compounds in aqueous solutions. Environ Sci Technol 9:833–838.
Dincer S, Ozenirler S, Oz E, 2002. The protective effect of taurine pretreatment on carbon tetrachloride-induced hepatic damage - A light and electron microscopic study. Amino Acids 22:417–426.12107767
*DiRenzo AB, Gandolfi AJ, Sipes IG. 1982. Microsomal bioactivation and covalent binding of aliphatic halides to DNA. Toxicol Lett 11:243–252.7101318
DiSilvestro RA, Carlson GP. 1990. Effects of moderate copper deficiency on carbon tetrachloride-induced hepatotoxicity in rats. Proc Soc Exp Biol Med 197(1): 32–35.
*DiSilvestro RA, Carlson GP. 1994. Effects of mild zinc deficiency, plus or minus acute phase response, on CCl4 hepatotoxicity. Free Radic Biol Med 16:57–61.8299997
*DiSilvestro RA, Medeiros DM. 1992. Low and marginal copper intake by postweaning rats: Effects on copper status and resistance to carbon tetrachloride hepatotoxicity. Metabolism 41:1122–1124.1406298
Dittman EC, Etschenberg E. 1973. Endoanesthetic and narcotic activity of halogenated methane derivatives. Eur J Pharmacol 24:389–398.4766700
*Docherty JF, Burgess E. 1922. The action of carbon tetrachloride on the liver. Br Med J 2:907–908.20770915
*Docherty JF, Nicholls L. 1923. Report of three autopsies following carbon tetrachloride treatment. Br Med J 2:753.20771331
DOE. 1999. Improved risk estimates for carbon tetrachloride. Final Report. New Mexico: U.S. Department of Energy. http://emsp.em.doe.gov/EMSPprojects1996_2003/completed/54940.pdf. February 17, 2005.
Dogterom P, Nagelkerke JF, van Steveninick J, 1988. Inhibition of lipid peroxidation by disulfiram and diethydithiocarbamate does not prevent hepatotoxin-induced cell death in isolated rat hepatocytes. A study with allyl alcohol, tert-butyl hydroperoxide, diethyl maleate, bromoisovalerylurea and carbon tetrachloride. Chem Biol Interact 66:251–265.2840217
Dogukan A, Akpolat N, Ceiler H, 2003. Protective effect of interferon-a on carbon tetrachloride-induced nephotoxicity. J Nephrol 16:81–84.12649538
*Doherty AT, Ellard S, Parry EM, 1996. An investigation into the activation and deactivation of chlorinated hydrocarbons to genotoxins in metabolically competent human cells. Mutagenesis 11(3):247–274.8671747
*Doi K, Kurabe S, Shimazu N, 1991. Systemic histopathology of rats with CCl_4_-induced hepatic cirrhosis. Lab Anim 25:21–25.2010972
Dolak JA, Britton RS, Glende EA, 1987. Chlordecone does not interfere with hepatic repair after carbon tetrachloride or partial hepatectomy. J Biochem Toxicol 2:57–66.2469795
Dolak JA, Waller RL, Glende EA, 1988. Liver cell calcium homeostasis in carbon tetrachloride liver cell injury: New data with Fura2. J Biochem Toxicol 3:329–342.3236338
Dolfing J, van den Wijngaard AJ, Janssen DB. 1993. Microbiological aspects of the removal of chlorinated hydrocarbons from air. Biodegradation 4:261–282 7764923
*Donnelly CA. 1995. The spatial analysis of covariates in a study of environmental epidemiology. Stat Med 14:2393–2409.8711277
Doolittle DJ, Muller G, Scribner HE. 1987. Relationship between hepatotoxicity and induction of replicative DNA synthesis following single or multiple doses of carbon tetrachloride. J Toxicol Environ Health 22:63–78.3612836
*Doong RA, Wu SC. 1992. Reductive dechlorination of chlorinated hydrocarbons in aqueous solutions containing ferrous and sulfide ions. Chemosphere 24:1063–1075.
*Dosemeci M, Cocco P, Chow W-H. 1999. Gender differences in risk of renal cell carcinoma and occupational exposures to chlorinated aliphatic hydrocarbons. Am J Ind Med 36(1):54–59.10361587
Dowty DC, Laseter JL, Storer J. 1975. Halogenated hydrocarbons in New Orleans drinking water and blood plasma. Science 187:75–77.1109227
*Dragiani TA, Manenti G, Porta GD. 1986. Enhancing effects of carbon tetrachloride in mouse hepatocarcinogenesis. Cancer Lett 31:171–179.3697961
*Drill VA, Ivy AC. 1944. Comparative value of bromsulphalein, serum phosphatase, prothrombin time, and intravenous galactose tolerance tests in detecting hepatic damage produced by carbon tetrachloride. J Clin Invest 23:209–216.16695094
*Driscoll TR, Hamdan HH, Wang G, 1992. Concentrations of individual serum or plasma bile acids in workers exposed to chlorinated aliphatic hydrocarbons. Br J Ind Med 49:700–705.1419858
Drotman RB, Lawhorn GT. 1978. Serum enzymes as indicators of chemically induced liver damage. Drug Chem Toxicol 1:163–171.755666
Dufour J-F, Luthi M, Forestier M, 1999. Expression of inositol 1,4,5-trisphosphate receptor isoforms in rat cirrhosis. Hepatology 30:1018–1026.10498655
*Dumas S, Parent ME, Siemiatycki J, 2000. Rectal cancer and occupational risk factors: A hypothesis-generating, exposure-based case-control study. Int J Cancer 87(6):874–879.10956400
*Durden WD Jr., Chipman DW. 1967. Gasoline sniffing complicated by acute carbon tetrachloride poisoning. Arch Intern Med 119:371–374.6022521
Durk H, Klessen C, Frank H. 1987. Tetrachloromethane metabolism in vivo under normoxia and hypoxia: Biochemical and histopathological effects relative to alkane exhalation. Arch Toxicol 60:115–121.3039939
Edgerton SA, Holdren MW, Smith DL, 1989. Inter-urban comparison of ambient volatile organic compound concentrations in U.S. cities. JAPCA 39:729–732.2732765
*Edgren M, Revesz L. 1987. Compatrmentalised depletion of glutathione in cells treated with buthionine suplhoximine. Br J Radiol 60:723–724.3620835
Eduardo S, Limbert B, Betts B. 1994. Biodegradation of trace levels of a complex organic pollutant mixture. Microbios 78(317):237–243.8078413
*Edwards JE. 1941. Hepatomas in mice induced with carbon tetrachloride. J Natl Cancer Inst 2:197–199.
*Edwards JE, Dalton AJ. 1942. Induction of cirrhosis of the liver and of hepatomas in mice with carbon tetrachloride. J Natl Cancer Inst 3:19–41.
Edwards EA, Liang LN, Grbic-Galic D. 1993. Anaerobic microbial transformation of aromatic hydrocarbons and mixtures of aromatic hydrocarbons and halogenated solvents. Stanford, CA: Environmental Engineering and Science program, Department of Civil Engineering.
*Edwards J, Heston WE, Dalton AJ. 1942. Induction of the carbon tetrachloride hepatoma in strain L mice. J Natl Cancer Inst 3:297–301.
Edwards M, Keller BJ, Kauffman FC, 119. The involvement of Kupffer cells in carbon tetrachloride toxicity. Toxicol Appl Pharmacol 119(2):275–279.8480336
Egli C, Tschan T, Scholtz R, 1988. Transformation of tetrachloromethane to dichloromethane and carbon dioxide by Acetobacterium woodii. Appl Environ Microbiol 54:2819–2824.3145712
*Eichelberger JW, Bellar TA, Donnelly JP, 1990. Determination of volatile organics in drinking water with USEPA method 524.2 and the ion trap detector. J Chromatog Sci 28:460–467.2273069
Eisenberg JN S, McKone TE. 1998. Decision tree method for the classification of chemical pollutants: Incorporation of across-chemical pollutants: Incorporation of across-chemical variability and within-chemical uncertainty. Environ Sci Technol 32:3396–3404.
*Elkins HB. 1942. Maximal allowable concentrations. II. Carbon tetrachloride. J Ind Hyg Toxicol 24:233–235.
*Ellenhorn MJ. 1997. Ellenhorn’s medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 1422.
El-Masri HA, Thomas RS, Benjamin SA, 1995. Physiologically based pharmacokinetic/ pharmacodynamic modeling of chemical mixtures and possible applications in risk assessment. Toxicology 105:275–282.8571364
El-Masri HA, Thomas RS, Sabados GR, 1996. Physiologically based pharmacokinetic/ pharmacodynamic modeling of the toxicologic interaction between carbon tetrachloride and kepone. Arch Toxicol 70:704–713.8896716
ElSisi AD, Earnest DL, Sipes IG. 1993a. Vitamin A potentiation of carbon tetrachloride hepatotoxicity: Role of liver macrophages and active oxygen species. Toxicol Appl Pharmacol 119:295–301.8480339
ElSisi AD, Hall P, Sim W-L W, 1993b. Characterization of vitamin A potentiation of carbon tetrachloride-induced liver injury. Toxicol Appl Pharmacol 119:280–288.8480337
*Endou H, Koseki C, Hasmura S, 1982. Renal cytochrome P-450: Its localization along a single nephron and its induction. In: Morel F, ed. Biochemistry of kidney functions. INSERM Symposium No. 21. Elsevier Biomedical Press B.V., 319–327.
EPA. 1975. Preliminary assessment of suspected carcinogens in drinking water: Interim report to the Congress. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1980a. Human exposure to atmospheric concentrations of selected chemicals. Volume I. Carbon tetrachloride. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. PB81–193252.
EPA. 1980b. U.S. Environmental Protection Agency. Fed Regist 45:33084–33133.
EPA. 1980c. U.S. Environmental Protection Agency. Fed Regist 45:79318.
EPA. 1980d. U.S. Environmental Protection Agency. Fed Regist 45:79347–79357.
EPA. 1980e. Volatile organic compounds by purge and trap isotope dilution GC-MS method 1624. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1981a. Carbon tetrachloride. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water. September 11, 1981.
EPA. 1981b. Treatability Manual. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600282001A.
*EPA. 1982a. Test method: Purgeable halocarbons - method 601. Test methods: Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA600482057.
*EPA. 1982b. Test method: Purgeables - method 624. Test methods: Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA600482057.
EPA 1982c. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA440481014. PB87169090.
EPA. 1983. Carbon tetrachloride; occurrence in drinking water, food and air. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water.
*EPA. 1984. Health assessment document for carbon tetrachloride. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA600882001F.
*EPA. 1985a. Assessment of the mutagenic potential of carbon disulfide, carbon tetrachloride, dichloromethane, ethylene dichloride and methyl bromide: A comparative analysis in relation to ethylene dibromide. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600685001.
EPA. 1985b. U.S. Environmental Protection Agency. Fed Regist 50:32621–32627.
EPA. 1985c. U.S Environmental Protection Agency. Part II. Fed Regist 50:13456–13522.
EPA. 1985d. Final draft criteria document for carbon tetrachloride. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water.
EPA. 1985e. U.S. Environmental Protection Agency. Part III. Fed Regist 50:46880–46901.
EPA. 1985f. Survey of carbon tetrachloride emission sources. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. EPA450385018.
*EPA. 1986a. Gas chromatography/mass spectrometry for volatile organics-method-8240. Test methods for evaluating solid waste. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, 8240–1 to 8240–40.
*EPA. 1986b. Halogenated volatile organics-method 8010. Test methods for evaluating solid waste. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, 8010–1 to 8010–13.
EPA. 1986c. U.S. Environmental Protection Agency. Fed Regist 51:41004.
EPA. 1986d. Reference values for risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. ECAO-CIN-477.
*EPA. 1987a. U.S. Environmental Protection Agency. Fed Regist 50:8140.
EPA. 1987b. Health advisory for carbon tetrachloride. Washington DC: U.S. Environmental Protection Agency, Office of Drinking Water. March 31.
EPA. 1987c. U.S. Environmental Protection Agency. Part II. Fed Regist 52:25942–25953.
EPA. 1987d. U.S. Environmental Protection Agency. Part II. Fed Regist 52:25690–25717.
*EPA. 1987e. U.S. Environmental Protection Agency. Part II. Fed Regist 52:47495–47519.
EPA. 1987f. Reference dose (RfD): Description and use in health risk assessments. Volume I, Appendix A: Integrated risk information system supportive documentation. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600886032a.
EPA. 1987g. Household solvent products: A "shelf" survey with laboratory analysis. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPAOTS560587006.
EPA. 1987h. National primary drinking water regulations; synthetic organic chemicals; monitoring for unregulated contaminants. U.S. Environmental Protection Agency: Part II. Fed Regist 52(130):25690–25717. 40 CFR Parts 141 and 142.
EPA. 1988a. Evaluation of the potential carcinogenicity of carbon tetrachloride (56–23-5). Final Report. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. OHEA-C-073–50.
EPA. 1988b. Toxic chemical release reporting: Community right-to-know. Fed Regist 53(30):4500–4554.
*EPA. 1989a. Interim methods for development of inhalation references doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600888066F.
*EPA. 1989b. Health effects assessment for carbon tetrachloride. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, EPA600889088.
*EPA. 1989c. Method 524.1. Measurement of purgeable organic compounds in water by packed column gas chromatography/mass spectrometry. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development.
EPA. 1989d. U.S. Environmental Protection Agency. Fed Regist 54(155):33418, 33453.
EPA. 1990a. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
*EPA. 1990b. Toxics in the community. 1988 National and local perspectives. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances Economics and Technology Division.
EPA. 1991a. In-situ biotransformation of carbon tetrachloride under anoxic conditions. Ada, OK: U.S. Environmental Protection Agency, Robert S. Kerr Environmental Research Laboratory, EPA600290060.
*EPA. 1991b. Toxics in the community. National and local perspectives. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560491014.
EPA. 1993. Reference guide to odor thresholds for hazardous air pollutants listed in the clean air act amendments of 1990. Washington DC: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA600R92047. PB922395163.
*EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
*EPA. 1999. Compendium Method TO-14A: Determination of volatile organic compounds (VOCs) in ambient air using specially prepared canisters with subsequent analysis by gas chromatography. Compendium of methods for the determination of toxic organic compounds in ambient air. Cincinnati, OH: U.S. Environmental Protection Agency, Center for Environmental Research Information, Office of Research and Development. EPA625R96010b. http://www.epa.gov/ttn/amtic/files/ambient/airtox/to-14ar.pdf. January 06, 2005.
*EPA 2001. Exploration of perinatal pharmacokinetic issues. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R-01004. http://cfpub.epa.gov/ncea/raf/ recordisplay.cfm?deid=29420. May 2001.
*EPA. 2002. 2002 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822R02038. http://www.epa.gov/waterscience. June 6, 2003.
*EPA. 2003a. Criteria for municipal solid waste landfills. List of hazardous inorganic and organic constituents. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 258, Appendix II. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003b. Designation, reportable quantities, and notification. Designation of hazardous substance. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 302.4. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003c. Effluent guidelines and standards. General provisions. Toxic pollutants. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 401.15. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003d. Identification and listing of hazardous waste. Toxicity characteristic. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 261.24. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003e. National emission standards for hazardous air pollutants. List of pollutants. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 61.01. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003f. National primary drinking water regulations. Maximum contaminant level goals for organic contaminants. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 141.50. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003g. National primary drinking water regulations. Maximum contaminant levels for organic contaminants. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 141.61. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003h. Protection of stratospheric ozone. Listing of ozone-depleting chemicals. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 82, Subpart A, Appendix F. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003i. Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 117.3. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003j. Standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 266, Appendix V. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003k. Standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities. Health-based limits for exclusion of waste-derived residues. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 266, Appendix VII. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003l. Standards for owners and operators of hazardous waste treatment, storage, and disposal facilities. Ground-water monitoring list. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 264, Appendix IX. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003m. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 372.65. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003n. Water programs. Designation of hazardous substances. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 116.4. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*EPA. 2003o. Water quality guidance for the Great Lakes system. Pollutants of initial focus in the Great Lakes water quality initiative. Washington, DC: U.S. Environmental Protection Agency. 40 CFR 132, Table 6. http://www.epa.gov/epahome/cfr40.htm. June 6, 2003.
*Eschenbrenner AB, Miller E. 1944. Studies on hepatomas -- Size and spacing of multiple doses in the induction of carbon tetrachloride hepatomas. J Natl Cancer Inst 4:385–388.
*Eschenbrenner AB, Miller E. 1946. Liver necrosis and the induction of carbon tetrachloride hepatomas in strain A mice. J Natl Cancer Inst 6:325–341.20993719
Esparza RJ, Mahmood RJ, Sedman RM. 1991. Hazardous waste incineration: A correlation of operating parameters with risk and emission rates. Waste Management 11:163–170.
Esterbauer H, Schaur RJ, Zollner H. 1991. Chemistry and biochemistry of 4-hydroxynonenal, malonaldehyde and related aldehydes. Free Radic Biol Med 11:81–128.1937131
Evans MV, Simmons JE. 1996. Physiologically based pharmacokinetic estimated metabolic constatnts and hepatotoxicity of carbon tetrachloride after mathanol pretreatment in rats. Toxicol Appl Pharmacol 140(2):245–253.8887440
*Evans GF, Lumpkin TA, Smith DL, 1992. Measurements of VOCs from the Tams network. J Air Waste Manage Assoc 42:1319–1323.
Evans MV, Crank WD, Yang H-M, 1994. Applications of sensitivity analysis to a physiologically based pharmacokinetic model for carbon tetrachloride in rats. Toxicol Appl Pharmacol 128:36–44.8079352
*Ezquerro I-J, Lasarte J-J, Dotor J, 2003. A synthetic peptide from transforming growth factor beta type III receptor inhibits liver fibrogenesis in rats with carbon tetrachloride liver injury. Cytokine 22:12–20.12946101
Fanelli SL, Castro JA. 1995. Covalent binding of carbon tetrachloride reactive metabolites to liver microsomal and nuclear lipid and phospholipid classes from Sprague Dawley and Osborne Mendel male rats. Teratog Carcinog Mutagen 15:155–166.8838630
Fanelli SL, Castro GD, Castro JA, 1995. Cholesterol interaction with free radicals. Chem Biol Interact 98(3):223–236.8548861
Fanelli SL, Castro GD, de Toranzo EG D, 1998. Mechanisms of the preventive properties of some garlic components in the carbon tetrachloride-promoted oxidative stress. Diallyl sulfide; diallyl disulfide; allyl mercaptan and allyl methyl sulfide. Res Commun Mol Pathol Pharmacol 102(2):163–174.10100508
*Farazi PA, Glickman J, Jiang S, 2003. Differential impact of telomere dysfunction on initiation and progression of hepatocellular carcinoma. Cancer Res 63:5021–5027.12941829
Farber JL. 1981. Minireview: The role of calcium in cell death. Life Sci 29:1289–1295.7026953
Farghali H, Martinek J, Kamenikova L, 1996. Amelioriation of chemically induced hepatocyte injury by cyclosporine A. Pharmacol Res 34(5–6):211–218.9076845
*Farrell CL, Senseman LA. 1944. Carbon tetrachloride polyneuritis. A case report. RI Med J 27:334, 346.
FDA. 1970. Food and Drug Administration. Part 191-Hazardous substances: Definitions and procedural and interpretive regulations. Carbon tetrachloride: Findings of fact and conclusions and final order regarding classification as banned hazardous substance. Fed Regist 35:13198–13205.
*FDA. 2003a. Beverages. Bottled water. Washington, DC: U.S. Food and Drug Administration. 21 CFR 165.110. http://www.access.gpo.gov/cgi-bin/cfrassemble.cgi?title=200321. June 6, 2003.
*FDA. 2003b. Indirect food additives: Adhesives and components of coatings. Washington, DC: U.S. Food and Drug Administration. 21 CFR 175.105(c)(5). http://www.access.gpo.gov/cgi-bin/cfrassemble.cgi?title=200321. June 6, 2003.
*FDA. 2003c. Indirect food additives: Paper and paperboard components. Anti-offset substances. Washington, DC: U.S. Food and Drug Administration. 21 CFR 176.130(c). http://www.access.gpo.gov/cgi-bin/cfrassemble.cgi?title=200321. June 6, 2003.
*FDA. 2003d. Indirect food additives: Paper and paperboard components. Components of paper and paperboard in contact with dry food. Washington, DC: U.S. Food and Drug Administration. 21 CFR 176.180(b)(2). http://www.access.gpo.gov/cgi-bin/cfrassemble.cgi?title=200321. June 6, 2003.
*FDA. 2003e. Labeling. Medical devices; warning statements for devices containing or manufactured with chlorofluorocarbons and other class I ozone-depleting substances. Washington, DC: U.S. Food and Drug Administration. 21 CFR 801.63. http://www.access.gpo.gov/cgi-bin/cfrassemble.cgi?title=200321. June 6, 2003.
*FDA. 2003f. Labeling. Warning statements for prescription and restricted device products containing or manufactured with chlorofluorocarbons or other ozone-depleting substances. Washington, DC: U.S. Food and Drug Administration. 21 CFR 801.433. http://www.access.gpo.gov/cgi-bin/cfrassemble.cgi?title=200321. June 6, 2003.
*FEDRIP. 2004. Carbon Tetrachloride. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
*Fernandez G, Villarruel MC, de Toranzo EG D, 1982. Covalent binding of carbon tetrachloride metabolites to the heme moiety of cytochrome P-450 and its degradation products. Res Commun Chem Pathol Pharmacol 35(2):283–290.7071415
*Fischer-Nielsen A, Poulsen HE, Hansen BA, 1991. CCl4 cirrhosis in rats: Irreversible histological changes and differentiated functional impairment. J Hepatol 12:110–117.2007767
Fiserova-Bergerova V, Pierce JT, Droz PO. 1990. Dermal absorption potential of industrial chemicals: Criteria for skin notation. Am J Ind Med 17:617–635.2337085
Fisher J, Lumpkin M, Boyd D, 2004. PBPK modeling of the metabolic interactions of carbon tetrachloride and tetrachloroethylene in B6C3F1 mice. Environ Toxicol Pharmacol 16:93–105.21782696
*Fisher J, Mahle D, Bankston L, 1997. Lactational transfer of volatile chemicals in breast milk. Am Ind Hyg Assoc J 58(6):425–431.9183837
*Folland DS, Schaffner W, Ginn EH, 1976. Carbon tetrachloride toxicity potentiated by isopropyl alcohol. J Am Med Assoc 236:1853–1856.
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant.” In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
*Forbes JR. 1944. Carbon tetrachloride nephrosis. Lancet 247:590–592.
*Fort J, Pilette C, Veal N, 1998. Effects of long-term administration of interferon alpha in two models of liver fibrosis in rats. J Hepatol 29:263–270.9722208
Foster P, Laffond M, Bausasnd P, 1991. Measurements of volatile organic compounds (VOC) in the Grenoble area and study of benzaldehyde behavior in a simulation chamber. Pollut Atmos 19:175–191.
Fountoulakis M, de Vera M-C, Crameri F, 2002. Modulation of gene and protein expression by carbon tetrachloride in the rat liver. Toxicol Appl Pharmacol 183:71–80.12217644
*Foureman P, Mason JM, Valencia R, 1994. Chemical mutagenesis testing in Drosophila. X. Results of 70 coded chemicals tested for the national toxicology program. Environ Mol Mutagen 23(3):208–227.8162896
*Fowler JS L. 1969. Carbon tetrachloride metabolism in the rabbit. Br J Pharmacol 37:733–737.5348474
Foxell AW H. 1951. Three cases of carbon tetrachloride poisoning with one fatality. Br Med J 1:397.14821426
Frank H, Frank W. 1988. Quantitative determination of airborne C_1_- and C_2_-halocarbons by GC/ECD. J J High Resolut Chromatogr Chromatogr Comm 11:51–56.
*Frantik R, Hornychova M, Horvath M. 1994. Relative acute neurotoxicity of solvents: Isoeffective air concentrations of 48 compounds evaluated in rats and mice. Environ Res 66:173–185.8055839
Frezza EE, Gerunda GE, Farinati F, 1994. CCl4-induced liver cirrhosis and hepatocellular carcinoma in rats: Relationship to plasma zinc, copper and estradiol. Hepatogastroenterology 41:367–369.7959573
FSTRAC. 1990. Summary of state and federal drinking water standards and guidelines. Federal-State Toxicology and Regulatory Alliance Committee. March, 1988.
*Fujii K. 1996. Stimulatory effect of anesthetics on dechlorination of carbon tetrachloride in guinea-pig liver microsomes. Toxicology 114(2):147–153.8947613
*Fujii K. 1997. Preventive effect of isoflurane on destruction of cytochrome P450 during reductive dehalogenation of carbon tetrachloride in guinea-pig liver microsomes. Drug Metabol Drug Interract 14(2):99–107.
*Fujii K, Rahman M, Yuge O, 1996. Isoflurane enhances dechlorination of carbon tetrachloride in guinea-pig liver microsomes. J Appl Toxicol 16(3):249–253.8818866
Fukai F, Nishizawa S, Kurano M, 1989. Carbon tetrachloride-induced alteration of glutathione S-transferase in rat liver cytosol and plasma. J Clin Biochem Nutr 6:175–185.
Fukao T, Hosano T, Misawa S, 2004. The effects of allyl sulfides on the induction of phase II detoxification enzymes and liver injury by carbon tetrachloride. Food Chem Toxicol 42:743–749.15046820
Gagliano N, Arosio B, Grizzi F, 2002. Acute liver CCl4 intoxication causes low HSP70 gene expression and a delayed transition through the cell cycle in aged rats. Exp Gerontol 37:791–801.12175479
*Galbally IE. 1976. Man-made carbon tetrachloride in the atmosphere. Science 193:573–576.17759586
Galelli ME, Castro JA. 1998. Effect of trichloromethyl and trichloromethyl peroxyl free radicals on protein sulfhydryl content studies in model and enzymatic carbon tetrachloride activation systems. Res Commun Mol Pathol Pharmacol 100(2):227–238.9667076
Galelli M, Gomez D, Castro JA. 1994. Decreased incorporation of 14 C-leucine in different liver nuclear protein factions at early stages of carbon tetrachloride poisoning in the rat. Arch Toxicol 68(3):206–209.8024469
*Galli A, Schiestl RH. 1995. Salmonella test positive and negative carcinogens show different effects of intrachromosomal recombination in G2 cell cycle arrested yeast cells. Carcinogenesis 16(3):659–663.7697829
*Galli A, Schiestl RH. 1996. Effects of Salmonella assay negative and positive carcinogens on intrachromosomal recombination in G1-arrested yeast cells. Mutat Res 370:209–221.8917668
*Galli A, Schiestl RH. 1998. Effect of Salmonella assay negative and positive carcinogens on intrachromosomal recombination in S-phase arrested yeast cells. Mutat Res 419:53–68.9804892
Galli R, McCarty PL. 1989. Biotransformation of 1,1,1-trichloroethane, trichloromethane, and tetrachloromethane by a Clostridium sp. Appl Environ Microbiol 55:837–844.2729985
Gallo JM, Cheung LL, Kim JJ, 1993. A physiological and system analysis hybrid pharmacokinetic model to characterize carbon tetrachloride blood concentrations following administration in different oral vehicles. J Pharmacokinet Biopharm 21(5):551–567.8145131
Gandhi CR, Sproat LA, Subbotin VM. 1996. Increased hepatic endothelin-1 levels and endothelin receptor density in cirrhotic rats. Life Sci 58(1):55–62.8628111
Gans JH, Korson R. 1984. Livere nuclear DNA synthesis in mice following carbon tetrachloride administration or partial hepatectomy. Proc Soc Exp Biol Med 175:237–242.6694979
Gao L, Zackert WE, Hasford JJ, 2003. Formation of prostaglandins E2 and D2 via the isoprostane pathway: A mechanism for the generation of bioactive prostaglandis independent of cyclooxygenase. J Biol Chem 278(31):28479–28489.12746435
Garcia C, Tiedra G, Ruano A, 1992. Evaluation of the liquid-liquid extraction technique and application to the determination of volatile halo-organic compounds in chlorinated water. J Chromatogr 605:251–255.
Garcia L, Hernandez I, Sandoval A, 2002. Pirfenidone effectively reverses experimental liver fibrosis. J Hepatol 37:797–805.12445421
*Gardner GH, Gove RC, Gustafson RK, 1925. Studies on the pathological histology of experimental carbon tetrachloride poisoning. Bulletin of Johns Hopkins Hospital 36:107–133.
*Gargas ML, Andersen ME, Clewell III HJ. 1986. A physiologically based simulation approach for determining metabolic constants from gas uptake data. Toxicol Appl Pharmacol 86:341–352.3787629
Gargas ML, Burgess RJ, Voisard DE, 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98:87–99.2929023
*Garner RC, McLean AE M. 1969. Increased susceptibility to carbon tetrachloride poisoning in the rat after pretreatment with oral phenobarbitone. Biochem Pharmacol 18:645–650.5772594
*Garry VF, Nelson RL, Griffith J, 1990. Preparation for human study of pesticide applicators: Sister chromatid exchanges and chromosome aberrations in cultured human lymphocytes exposed to selected fumigants. Teratog Carcinog Mutagen 10:21–29.1971966
*Gasso M, Rubio M, Varela G, 1996. Effects of S-adenosylmethionine on lipid peroxidation and liver fibrogenesis in carbon tetrachloride-induced cirrhosis. J Hepatol 25:200–205.8878782
Gee DL, Bechtold MM, Tappel AL. 1981. Carbon tetrachloride-induced lipid peroxidation: Simultaneous in vivo measurements of pentane and chloroform exhaled by the rat. Toxicology 8:299–306.
*Geier A, Dietrich CG, Voigt S, 2003. Effects of proinflammatory cytokines on rat organic anion transporters during toxic liver injury and cholestasis. Hepatology 38(2):345–354.12883478
Genoni GP. 1997. Influence of the energy relationships of organic compounds on their specificity toward aquatic organisms. Ecotoxicol Environ Saf 36:99–108.9126426
Germolec DR, Yang RS, Ackermann MF, 1989. Toxicology studies of a chemical mixture of 25 groundwater contaminants. II. Immunosuppression in B6C3F_1_ mice. Fundam Appl Toxicol 13:377–387.2515087
Giffen PS, Turton J, Andrews CM, 2003. Markers of experimental acute inflammation in the Wistar Han rat with particular reference to haptoglobin and C-reactive protein. Arch Toxicol 77:392–402.12669191
*Gillespie WR, Cheung LL, Kim HJ, 1990. Application of system analysis to toxicology: Characterization of carbon tetrachloride oral absorption kinetics. In: Gentry TR, Henry CJ, eds. Principles of route-to-route extrapolations for risk assessment. New York, NY: Elsevier Science Publishing Company.
*Gilman MR. 1971. A preliminary study of the teratogenic effects of inhaled carbon tetrachloride and ethyl alcohol consumption in the rat. Dissertation. Philadelphia, PA: Drexel University.
*Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
*Glende EA. 1972. Carbon tetrachloride-induced protection against carbon tetrachloride toxicity. The role of the liver microsomal drug-metabolizing system. Biochem Pharmacol 21:1697–1702.4405417
Glende EA, Pushpendran CK. 1986. Activation of phospholipase A2 by carbon tetrachloride in isolated rat hepatocytes. Biochem Pharmacol 35:3301–3307.3094537
*Glende EA, Recknagel RO. 1991. An indirect method demonstrating that CCl_4_-dependent hepatocyte injury is linked to a rise in intracellular calcium ion concentration. Res Commun Chem Pathol Pharmacol 73:41–52.1882126
*Glende EA, Recknagel RO. 1992. Phospholipase A_2_ activation and cell injury in isolated rat hepatocytes exposed to bromotrichloromethane, chloroform, and 1,1-dichloroethylene as compared to effects of carbon tetrachloride. Toxicol Appl Pharmacol 113:159–162.1553751
*Glende EA Jr., Hruszkewycz AM, Recknagel RO. 1976. Critical role of lipid peroxidation in carbon tetrachloride-induced loss of aminopyrine demethylase, cytochrome P-450 and glucose 6-phosphatase. Biochem Pharmacol 25:2163–2170.9947
Goerz G, Vizethum W, Bolsen K, 1978. [Hexachlorobenzene (HCB) induced porphyria in rats. Influence of HCB-metabolites on the biosynthesis of heme.] Arch Dermatol Res 263:189–196. (German)736603
Golderman L, Gellert J, Teschke R. 1983. Methods and Devices. Quantitative assessment of carbon tetrachloride levels in human blood by head-space gas chromatography: Application in a case of suicidal carbon tetrachloride intoxication. Intensive Care Medicine 9:131–135.6863723
Goldsmith LB, Friberg SE, Wahlberg JE. 1988. The effect of solvent extraction on the lipids of the stratum corneum in relation to observed immediate whitening of the skin. Contact Dermatitis 19:348–350.3233954
Gomez MR, Cocco P, Dosemeci M, 1994. Occupational exposure to chlorinated aliphatic hydrocarbons: Job exposure matrix. Am J Ind Med 26(2):171–183.7977394
*Gordis E. 1969. Lipid metabolites of carbon tetrachloride. J Clin Invest 48:203–209.5765023
*Gordon AJ. 1944. Uremia following inhalation of carbon tetrachloride. J Mt Sinai Hosp NY 10:792–795.
*Gorla N, de Ferreyra EC, Villarruel MC, 1983. Studies on the mechanism of glutathione prevention of carbon tetrachloride-induced liver injury. Br J Exp Pathol 64:388–395.6615708
*Gosselin RE, Hodge HC, Smith RP, 1976. Clinical toxicology of commercial products. Acute poisoning. 4th ed., Baltimore, MD: The Williams and Wilkins Co., 13, 92–97, 110.
Gotoh M, Sikitani Y, Aramaki T, 1992. Pollution due to volatile halocarbon compound in biota. Bull Environ Contam Toxicol 49:186–191.1611238
*Gould VE, Smuckler EA. 1971. Alveolar injury in acute carbon tetrachloride intoxication. Arch Intern Med 128:109–117.5088407
Grant WB, Kagann RH, McClenny WA. 1992. Optical remote measurement of toxic gases. J Air Waste Manage Assoc 42:18–30.1575966
*Gray I. 1947. Carbon tetrachloride poisoning -- Report of seven cases with two deaths. NY State J Med 47:2311–2315.
*Gribble GW. 1994. The natural production of chlorinated compounds. Environ Sci Technol 28(7):310A–319A.
Gruebele A, Zawaski K, Kaplan D. 1996. Effects on signal transduction as demonstrated by altered immediate-early (c-Fos and c-Jun) gene expression and nuclear AP-1 and NK-kB transcription factor levels. Drug Metab Dispos 24(1):15–22.8825185
*Gryder-Boutlet DE, Kennish JM. 1988. Using headspace sampling with capillary column GC-MS to analyze trace volatile organics in water and wastewater. J Am Water Works Assoc 80:52–55.
*Gualandi G. 1984. Genotoxicity of the free-radical producers of CCl4 and lipoperoxide in Aspergillus nidulans. Mutat Res 136:109–114.6371516
Gubskii IuI, Kurskii MD, Zadorina OV, 1990. Calcium transport in endoplasmic reticulum of the rat liver during lipid peroxidation. Biokhimiia 55(1):12–22.2140518
Guengerich FP, Kim DH, Iwasaki M. 1991. Role of human cytochrome P-450 IIE1 in the oxidation of many low molecular weight cancer suspects. Chem Res Toxicol 5:168–179.
*Guido DM, McKenna R, Mathews WR. 1993. Quantitation of hydroperoxy-eicosatetraenoic acids and hydroxy-eicosatetraenoic acids as indicators of lipid peroxidation using gas chromatography-mass spectrometry. Anal Biochem 209:123–129.8465944
Guidotti M, Onorati B, Lucarelli E, 2001. Determination of chlorinated solvents in exhaled air, urine, and blood of subjects exposed in the workplace using SPME and GC-MS. Am Clin Lab 20(4):23–26.
*Guild WR, Young JV, Merrill JP. 1958. Anuria due to carbon tetrachloride intoxication. Ann Intern Med 48:1221–1227.13545713
*Guo TL, McCay JA, Brown RD, 2000. Carbon tetrachloride is immunosuppressive and decreases host resistance to Listeria monocytogenes and Streptococcus pneumoniae in female B6C3F1 mice. Toxicology 154:85–101.11118673
Gupta TK, Toruner M, Chung MK, 1998. Endothelial dysfunction and decreased production of nitric oxide in the intrahepatic microcirculation of cirrhotic rats. Hepatology 28:926–931.9755227
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
*Haag WR, Yao CC D. 1992. Rate constants for reaction of hydroxyl radicals with several drinking water contaminants. Environ Sci Technol 26:1005–1013.
*Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia, PA: W.B. Saunders Company, 1218–1219, 1257–1259.
*Haehner BD, Gorski JC, Vandenbranden M, 1996. Bimodal distribution of renal cytochrome P450 3A activity in humans. Mol Pharmacol 50:52–59.8700118
*Hafeman DG, Hoekstra WG. 1977. Protection against carbon tetrachloride-induced lipid peroxidation in the rat by dietary vitamin E, selenium and methionine as measured by ethane evolution. J Nutr 107:656–665.845700
*Hakkola J, Raunio H, Purkunen R, 1996. Detection of cytochrome P450 gene expression in human placenta in first trimester of pregnancy. Biochem Pharmacol 52(2):379–383.8694864
*Hall MC. 1921. The use of carbon tetrachloride for the removal of hookworms. J Am Med Assoc 77:1641–1643.
*Hall P de la M, Plummer JL, Ilsley AH, 1990. Hepatic fibrosis and cirrhosis after chronic administration of alcohol and "low-dose" carbon tetrachloride vapor in the rat. Hepatology 13:815–819.
*Hamlin GP, Kholkute SD, Dukelow WR. 1993. Toxicology of maternally ingested carbon tetrachloride (CCl4) on embroyonal and fetal development and in vitro fertilization in mice. Zoolog Sci 10:111–116.
Hammock BD, Gee SJ, Cheung PY K, 1987. Utility of immunoassay in pesticide trace analysis. In: Greenhalgh R, Roberts TR, eds. Pesticide science and biotechnology. New York, NY: Blackwell Scientific Publications.
*Hanasono GK, Cote MG, Plaa GL. 1975. Potentiation of carbon tetrachloride-induced hepatotoxicity in alloxan- or streptozotoxin-diabetic rats. J Pharmacol Exp Therap 192:592–604.164533
Hansch C, Leo A. 1979. Substituent constants for correlation analysis in chemistry and biology. New York, NY: John Wiley & Sons, 25–26, 171–180.
Hansen H, De Rosa CT, Pohl H, 1998. Public health challenges posed by chemical mixtures. Environ Health Perspect 106(Suppl. 6):1271–1280.9860881
Hanst PL. 1978. Part II: Halogenated pollutants. Noxious trace gases in the air. Chemistry 51:6–12.
Happell JD, Wallace DW R. 1998. Removal of atmospheric CC14 under bulk aerobic conditions in groundwater and soils. Environ Sci Technol 32:1244–1252.
Hardell L. Eriksson M, Lenner P, 1981. Malignant lymphoma and exposure to chemicals especially organic solvents, chlorophenols and phenoxy acids: A case-control study. Br J Cancer 43:169–176.7470379
*Hardin BL. 1954. Carbon tetrachloride poisoning. A review. Ind Med Surg 23:93–105.13142679
Harms MS, Peterson RE, Fujimoto JM, 1976. Increased "bile duct--pancreatic fluid" flow in chlorinated hydrocarbon-treated rats. Toxicol Appl Pharmacol 35:41–49.1258058
*Harris RN, Anders MW. 1980. Effect of fasting, diethyl maleate and alcohols on carbon tetrachloride-induced heptotoxicity. Toxicol Appl Pharmacol 56:191–198.7466818
Harris L, Morris LE, Farber E. 1989. Protective value of a liver initiation-promotion regimen against the lethal effect of carbon tetrachloride in rats. Lab Invest 61:467–470.2796292
Harris RN, Ratnayake JH, Garry VF, 1982. Interactive hepatotoxicity of chloroform and carbon tetrachloride. Toxicol Appl Pharmacol 63:281–291.7089978
Hartley DP, Kolaja KL, Reichard J, 1999. 4-Hydroxynonenal and malondialdehyde hepatic protein adducts in rats treated with carbon tetrachloride: Immunochemical detection and lobular localization. Toxicol Appl Pharmacol 161:23–33.10558920
*Hartwell TD, Perritt RL, Pelizzari ED, 1992. Results from the 1987 total exposure assessment methodology (team) study in Southern California. Atmos Environ 26a:1519–1527.
Harvey PJ, Gready JE, Hickey HM, 1999. 31P and 1H NMR spectroscopic studies of liver extracts of carbon tetrachloride-treated rats. NMR Biomed 12(6):395–401.10516622
*Harvey PJ, Gready JE, Yin Z, 2000. Acute oxygen supplementation restores markers of hepatocyte energy status and hypoxia in cirrhotic rats. J Pharmacol Exp Ther 293(2):641–645.10773039
Haselmann KF, Laturnus F, Sevensmark B, 2000. Formation of chloroform in spruce forest soil results from laboratory incubation studies. Chemosphere 41:1769–1774.11057617
Hatch GE, Santrock J, Slade R, 1988. Detection of CCl_4_-induced oxidation of hepatic tissue in vivo by oxygen-18 tracing. Toxicol Appl Pharmacol 93:81–88.3127945
*Hawthorne SB. 1988. Workshop on supercritical fluid chromatography. Am Lab 88:6–8.
*Hayes JR, Condie LW, Borzelleca JF. 1986. Acute, 14-day repeated dosing, and 90-day subchronic toxicity studies of carbon tetrachloride in CD-l mice. Fundam Appl Toxicol 7:454–463.3781135
*HazDat. 2005. Atlanta, GA: Agency for Toxic Substances and Disease Registry (ATSDR). April 28, 2005.
Hazle JD, Narayana PA, Dunsford HA. 1991. In vivo NMR, biochemical, and histologic evaluation of alcohol-induced fatty liver in rat and a comparison with CCl_4_ hepatotoxicity. Magn Reson Med 19:124–135.2046527
*Heimann H, Ford CA. 1941. Low concentration of carbon tetrachloride capable of causing mild narcosis. Ind Bull 20, July-August.
*Heineman EF, Cocco P, Gomez MR, 1994. Occupational exposure to chlorinated aliphatic hydrocarbons and risk of astrocytic brain cancer. Am J Ind Med 26:155–169.7977393
Hellemans K, Rombouts K, Quartier E, 2003. PPARbeta regulates vitamin A metabolism-related gene expression in hepatic stellate cells undergoing activation. J Lipid Res 44(2):280–295.12576510
Hellerbrand C, Stefanovic B, Giordano F, 1999. The role of TGFBeta1 in initiating hepatic stellate cell activation in vivo. J Hepatol 30:77087.
*Hellmer L, Bolcsfoldi G. 1992. An evaluation of the E. coli K-12 uvrB/recA DNA repair host-mediated assay. I. In vitro sensitivity of the bacteria to 61 compounds. Mutat Res 272:145–160.1383747
Helmig D, Arey J. 1992. Organic chemicals in the air at Whitaker's Forest/Sierra Nevada Mountains, California. Sci Total Environ 112:233–250.1566045
Hemmings SJ, Pulga VB, Tran ST 2002. Differential inhibitory effects of carbon tetrachloride on the hepatic plasma membrane, mitochondrial and endoplasmic reticular calcium transport systems: Implications to hepatoxicity. Cell Biochem Funct 20:47–59 11835270
Hendler AH, Crow WL. 1992. Preliminary results of the Chemical Manufacturers Association urban baseline VOC measurement program. Proc Annu Meet Air Waste Manage Assoc 2b:1–17.
Henschler D, Elsasser H, Romen W, 1984. Carcinogenicity study of trichloroethylene with and without epoxide stabilizers, in mice. J Cancer Res Clin Oncol 107:149–156.6736101
Herbarth O, Rehwagen M, Ronco AE. 1997. The influence of localized emittants on the concentration of volatile organic compounds in the ambient air measured close to ground level. Environ Toxicol Water Qual 12:31–37.
*Hernandez-Munoz R, Diaz-Munoz M, Chagoya de Sanchez V. 1992. Effects of adenosine adiministration on the function and membrane composition of liver mitochondria in carbon tetrachloride-induced cirrhosis. Arch Biochem Biophys 294:160–167.1312801
Hernberg S, Kauppinen T, Riala R, 1988. Increased risk for primary liver cancer among women exposed to solvents. Scand J Work Environ Health 14:356–365.3212412
Herzfeld D, van der Gun K, Louw R. 1988. Quantitative determination of volatile organochlorine compounds in water by GC-headspace analysis with dibromomethane as an internal standard. Chemosphere 14(8):1425–1430.
*Ho JS. 1989. Method 502.2. Volatile organic compounds in water by purge and trap capillary column gas chromatography with photoionization and electrolytic conductivity detectors in series. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development.
Hocher B, Zart R, Diekmann F, 1995a. Protective effects of the mixed endothelin receptor antagonist bosentan in rats with CCL4-induced liver injury. J Cardiovasc Pharmacol 26(Suppl. 3):S130–131.8587341
Hocher B, Zart R, Diekmann F, 1995b. Role of the paracrine liver endothelin system in the pathogenesis of CCl4-induced liver injury. Eur J Pharmacol 293(4):361–368.8748689
*Hocher B, Zart R, Diekmann F, 1996. Paracrine renal endothelin system in rats with liver cirrhosis. Br J Pharmacol 118:220–227.8735618
Hoekstra EJ, Deleer EW B, Brinkman UA T. 2001. Findings supporting the natural formation of trichloracetic acid in soil. Chemosphere 38:2875–2883.
Hoekstra EJ, Duyzer JH, Deleer EW B, 2001. Chloroform-concentration gradients in soil air and atmospheric air and emission fluxes from soil. Atmos Environ 35:61–70.
*Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
*Holbrook HT. 1991. Carbon tetrachloride. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol 5. 4^th^ edition. New York: John Wiley & Sons, 1062–1072.
Holden PR, James NH, Brooks AN. 2000. Identification of a possible association between carbon tetrachloride-induced hepatotoxicity and interleukin-8 expression. J Biochem Mol Toxicol 14(5):283–290.10970000
Holecek M, Skalska H, Mraz J. 1999. Plasma amino acid levels after carbon tetrachloride induced acute liver damage. A dose-response and time-response study in rats. Amino Acids 16:1–11.10078329
Holecek M, Tilser I, Skopec F, 1996. Leucine metabolism in rats with cirrhosis. J Hepatol 24(2):209–216.8907575
*Hollinger MA. 1982. Biochemical evidence for pulmonary endothelial cell injury after carbon tetrachloride administration in mice. J Pharmacol Exp Therap 222:641–644.6286928
Hooper K, LaDou J, Rosenbaum JS, 1992. Regulation of priority carcinogens and reproductive or development toxicants. Am J Ind Med 22:793–808.1463026
*Hooser SB, Rosengren RJ, Hill DA. 1994. Vitamin A modulation of xenobiotic-induced hepatotoxicity in rodents. Environ Health Perspect 102(Suppl 9):39–43.
*Horn TL, O'Brein TD, Schook LB, 2000. Acute hepatotoxicant exposure induces TNFR-mediated hepatic injury and cytokin/apoptotic gene expression. Toxicol Sci 54:262–273.10746953
Horvath AL. 1982. Tabulated data. Halogenated hydrocarbons: Solubility–miscibility with water. New York, NY: Marcel Dekker, Inc., 484–572.
Hosoda A, Yamada S, Kawasaki H, 1993. Effects of carbon tetrachloride-induced chronic liver damage on glutathione-dependent enzymes in rat gastric mucosa. Res Commun Chem Pathol Pharmacol 81(2):209–220.8210699
Hotz P. 1994. Occupational hydrocarbon exposure and chronic nephropathy. Toxicology 90:163–283.8029821
*Howard PH, ed. 1990. Handbook of environmental fate and exposure data. Vol II. Chelsea, MI: Lewis Publishers, Inc., 85–91.
*Howard PH, Boethling RS, Jarvis WF, , eds. 1991. Handbook of environmental degradation rates. Chelsea, MI: Lewis Publishers, Inc., 34–35.
*HSDB. 2004. Carbon tetrachloride. Environmental standards and regulations. Bethesda, MD: Hazardous Substances Data Bank. http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSDB.htm. December 30, 2004.
Huang YS, Deng JF, Wang JD, 1987. [Clinical manifestations and laboratory findings of cases in an outbreak of carbon tetrachloride-induced hepatic injury at a printing factory.] [Abstract] 86:743–749. (Japanese)
Huang Z-H, Murakami T, Okochi A, 2001. Expression and function of p-glycoprotein in rats with carbon tetrachloride-induced acute hepatic failure. J Pharm Pharmacol 53:873–881.11428664
Huber M, Estermann G, Bonn G. 1988. Analysis of volatile halogenated hydrocarbons on the ppq scale. Fresenius Z Anal Chem 331:486–489.
*Hughes CS. 1985. Chlorinated methanes. In: Chemical economics handbook. Menlo Park, CA: SRI International.
*Hughes HM, George IM, Evans JC, 1991. The role of the liver in the production of free radicals during halothane anaesthesia in the rat. Biochem J 277:795–800.1651704
*IARC. 1979. Evaluation of the carcinogenic risk of chemicals to humans. Lyon, France: International Agency for Research on Cancer, October 1979, 20:371–399.
*IARC. 1987. IARC Monographs on the evaluation of carcinogenic risks to humans. Overall evaluations of carcinogenicity: An updating of IARC Monographs volumes 1 to 42, Supplement 7. Lyon, France: International Agency for Research on Cancer.
*IARC. 1999. IARC monographs programme on the evaluation of carcinogenic risks to humans. Carbon tetrachloride. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/. June 6, 2003.
Ichinose T, Miller MG, Shibamoto T. 1994. Determination of free malonaldehyde formed in liver microsomes upon CCL4 oxidation. J Appl Toxicol 14(6):453–455.7884151
Ideura T, Yoshimura A, Shirai M, 1993. Endotoxin-induced acute tubular necrosis in cirrhotic rats. Scand J Urol Nephrol 27:433–439.8159914
*Ikatsu H, Nakajima T. 1992. Hepatotoxic interaction between carbon tetrachloride and chloroform in ethanol treated rats. Arch Toxicol 66:580–586.1463393
*Ikatsu H, Okino T, Nakajima T. 1991. Ethanol and food deprivation induced enhancement of hepatotoxicity in rats given carbon tetrachloride at low concentration. Br J Ind Med 48:636–642.1911407
Ikemoto M, Tsunekawa S, Toda Y, 2001. Liver-type arginase in a highly sensitive marker for hepatocellular damage in rats. Clin Chem 47(5):946–948.11325904
Inagaki Y, Nemoto T, Kushida M, 2003. Interferon alfa down-regulates collagen gene transcription and supresses experimental hepatic fibrosis in mice. Hepatology 38(4):890–899.14512876
*Inder RE, Bray BJ, Sipes IG, 1999. Role of cytochrome P4502E1in retinol's attenuation of carbon tetrachloride-induced hepatotoxicity in the Swiss Webster mouse. Toxicol Sci 52(1):130–139.10568706
Infante FI, Marlow PB. 1980. Evidence for the carcinogenicity of selected halogenated hydrocarbons included ethylene dichloride. Banbury Rep 5:287–308.
Ingall A, Lott KA K, Slater TF. 1978. Metabolic activation of carbon tetrachloride to a free-radical product study using a spin trap. Biochem Soc Trans 6:962–964.744357
Iredale JP, Benyon RC, McCullen M, 1998. Mechanisms of spontaneous resolution of rat liver fibrosis. J Clin Invest 102(3):538–549.9691091
*IRIS. 2003. Carbon tetrachloride. Washington, DC: Integrated Risk Information System. http://www.epa.gov/iris/. June 6, 2003.
Ishigami T, Fujita T, Simbula G, 2001. Regulatory effects of senescence marker protein 30 on the proliferation of hepatocytes. Pathol Int 51(7):491–497.11472560
Ishikawa K, Michida S, Mashiba S, 1999. Expressions of vascular endothelial growth factor in nonparenchymal as well as perenchymal cells in rat liver after necrosis. Biochem Biophys Res Commun 254:587–593.9920783
*Ishiki Y, Ohnishi H, Muto Y, 1992. Direct evidence that hepatocyte growth factor is a hepatotrophic factor for liver regeneration and has a potent antihepatitis effect in vivo. Hepatology 16:1227–1235.1427661
Ishiyama H, Sato M, Matsumura K, 1995. Proliferation of hepatocytes and attenuation from carbon tetrachloride hepatotoxicity by gadolinium chloride in rats. Pharmacol Toxicol 77(4):293–298.8577643
Isono M, Soda M, Inoue A, 2003. Reverse transformation of hepatic myofibroblast-like cells by TGFβ1/LAP. Biochem Biophys Res Commun 311:959–965.14623275
Itoh H, Koyata H, Takahara T, 1992. Prostacyclin administration suppresses the increase in hepatic levels of COL1A(I) and glyceraldehyde-3-phosphate dehydrogenase mRNAs in the rat treated with carbon tetrachloride. Biochem Biophys Res Commun 185(3):981–986.1627149
*Itoh S, Yamaba Y, Matsuo S, 1985. Early changes in the levels of serum triiodothyronine (T3), thyroxine (T4), T3/T4 ratio and microsomal carboxylesterase activity in rats following treatment with CCl_4_. Res Commun Chem Pathol Pharmacol 49:447–450.4059658
Iwai S, Karim R, Kitano M, 2002. Role of oxidative DNA damage caused by carbon tetrachloride-induced liver injury -enhancement of MeIQ-induced glutathione S-transferase placental form-positive foci in rats. Cancer Lett 179:15–24.11880177
Iwamoto K, Watanaba J, Araki K, 1985. Reduced hepatic clearance of propranolol induced by chronic carbon tetrachloride treatment in rats. J Pharmacol Exp Ther 234:470–475.4020680
*Jaeger RJ, Conolly RB, Murphy SD. 1975. Short-term inhalation toxicity of halogenated hydrocarbons. Arch Environ Health 30:26–31.1109268
Jaeschke H, Gores GJ, Cederbaum AI, 2002. Mechanisms of hepatotoxicity. Toxicol Sci 65:166–176.11812920
*Jakobson I, Wahlberg JE, Holmberg B, 1982. Uptake via the blood and elimination of 10 organic solvents following epicutaneous exposure of anesthetized guinea pigs. Toxicol Appl Pharmacol 63:181–187.7089968
James KJ, Stack MA. 1997. The impact of leachate collection on air quality in landfills. Chemosphere 34:1713–1721.
Janakat S, Al-Merie H. 2002. Optimization of the dose and route of injection, and characterisation of the time course of carbon tetrachloride-induced hepatotoxicity in the rat. J Pharmacol Toxicol Methods 48:41–44.12750040
Janbaz KH, Gilani AH. 1999. Potentiation of paracetamol and carbon tetrachloride-induced hepatotoxicity in rodents by the food additive vanillin. Food Chem Toxicol 37(6):603–607.10478828
*Janbaz KH, Saeed SA, Gilani AH, 1998. An assessment of the potential of protopine to inhibit microsomal drug metabolising enzymes and prevent chemical-induced hepatoxicity in rodents. Pharmacol Res 38(3):215–219.9782072
Janzen EG, Poyer JL, West MS, 1994. Study of reproducibility of spin trapping results in the use of C phenyl-N-tert-butyl nitrone (PBN) for trichloromethyl radical detection in CCl4 metabolism by rat liver microsomal dispersions Biological spin trapping I. J Biochem Biophys Meth 29:189–205.7699199
Janzen EG, Towner RA, Brauer M. 1988. Factors influencing the formation of the carbon dioxide radical anion (CO_2_-) spin adduct of PBN in the rat liver metabolism of halocarbons. Free Radic Res Commun 4:359–369.2854105
Janzen EG, Towner RA, Haire DL. 1987. Detection of free radicals generated from the in vitro metabolism of carbon tetrachloride using improved EPR spin trapping techniques. Free Radic Res Commun 3:357–364.2854531
*Japan Bioassay Research Center. 1998. Subchronic inhalation toxicity and carcinogenicity studies of carbon tetrachloride in F344 rats and BDF1 mice (Studies Nos. 0020, 0021, 0043, and 0044). Kanagawa, Japan Industrial Safety and Health Association, Japan Bioassay Research Center (Unpublished report to the Ministry of Labor). Hirasawa Hadano Kanagawa, 257 Japan.
Javier Perez A, Courel M, Sobrado J, 1987. Acute renal failure after topical application of carbon tetrachloride. Lancet 515–516.
Jeffers PM, Ward LM, Woytowitch LM, 1989. Homogeneous hydrolysis rate constants for selected chlorinated methanes, ethanes, ethenes, and propanes. Environ Sci Technol 23:965–969.
*Jennings RB. 1955. Fatal fulminant acute carbon tetrachloride poisoning. Arch Pathol 59:269–284.
Jennings RB, Kearns WM. 1953. Necronizing nephrosis in the rat following administration of carbon tetrachloride. Arch Pathol 56:348–359.
Jeon TI, Hwang SG, Park NG, 2003. Antioxidative effects of chitosan on chronic carbon tetrachloride induced hepatic injury in rats. Toxicology 187:67–73.12679053
Jeon YJ, Han SH, Yang KH, 1997. Induction of liver-associated transforming growth factor beta1 (TGF-beta1) mRNA expression by carbon tetrachloride leads to the inhibition of T helper 2 cell-associated lymphokines. Toxicol Appl Pharmacol 144:27–35.9169066
*Jeong HG. 1999. Inhibition of cytochrome P450 2E1 expression by oleanolic acid hepatoprotective effects against carbon tetrachloride induced hepatic injury. Toxicol Lett 105(3):215–222.10355542
*Jeong HG, Park HY. 1998. The prevention of carbon tetrachloride-induced hepatotoxicity in mice by alpha-hederin: Inhibition of cytochrome P450 2E1 expression. Biochem Mol Biol Int 45(1):163–170.9635140
Jeong W-I, Lee C-S, Park S-J, 2002. Kinetics of macrophages, myofibroblasts and mast cells in carbon tetrachloride-induced rat liver cirrhosis. Anticancer Res 2A:869–877.
*Jiang Y, Liu J, Waalkes M, 2004. Changes in the gene expression associated with carbon tetrachloride-induced liver fibrosis persist after cessation of dosing in mice. Toxicol Sci 79:404–410.15056808
*Jiang Z, You Dy, Chen XC, 1992. Monitoring of serum markers for fibrosis during CCl4-induced liver damage. J Hepatol 16:282–289.1487604
Jimenez-Jativa S, Nunez de Castro I, Morata P, 1992. Rat serum fructose 1,6 biphosphatase: Modifications in different experimental conditions. Biochem Int 27(5):923–929.1329753
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johns R. 1976. Air pollution assessment of carbon tetrachloride. Mitre Technical Report No. MTR-7144, McLean, VA: Mitre Corp.
*Johnson SJ, Hines JE, Burt AD. 1992. Macrophage and perisinusoidal cell kinetics in acute liver injury. J Pathol 166:351–358.1517890
Johnston DE, Kroening C. 1998. Mechanism of early carbon tetrachloride toxicity in cultured rat hepatocytes. Pharmacol Toxicol 83:231–239.9868740
*Johnstone RT. 1948. Occupational medicine and industrial hygiene. St. Louis, MO: CV Mosby Co., 148–158.
*Joly JG, Villeneuve JP, Marier P. 1977. Chronic ethanol administration induced a form of cytochrome P-450 with specific spectral and catalytic properties. Alcoholism 1:17–25.337820
Jordan A, Harnisch J, Borchers R, 2000. Volcanogenic halocarbons. Environ Sci Technol 34:1122–1124.
*Jorgenson TA, Meierhenry EF, Rushbrook CJ, 1985. Carcinogenicity of chloroform in drinking water to male Osborne-Mendel rats and female B6C3F1 mice. Fundam Appl Toxicol 5:760–769.4043598
Joron GE, Hollenberg CH, Bensley EH. 1957. Carbon tetrachloride -- an underrated hazard. Can Med Assoc J 763:173–175.
Junnila M, Rahko T, Sukura A, 2000. Reduction of carbon tetrachloride-induced hepatotoxic effects by oral administration of betaine in male Han-Wistar rats: A morphometric histological study. Vet Pathol 37:231–238.10810987
Kaido T, Yamaoka S, Seto S-Funaki N, 1997. Continous hepatocyte growth factor supply prevents lipopolysaccharide-induced liver injury in rats. FEBS Lett 411:378–382.9271240
Kajiwara K, Okuno M, Kobayashi T, 1998. Oral supplementation with branched-chain amino acids improves survival rate of rats with carbon tetrachloride-induced liver cirrhosis. Dig Dis Sci 43(7):1572–1579.9690397
Kalf GF, Post GB, Snyder R. 1987. Solvent toxicology: Recent advances in the toxicology of benzene, the glycol ethers and carbon tetrachloride. Ann Rev Pharmacol Toxicol 27:399–427.3555320
*Kalla NR, Bansal MP. 1975. Effect of carbon tetrachloride on gonadal physiology in male rats. Acta Anat 91:380–385.1155002
*Kamada Y, Tamura S, Kiso S, 2003. Enhanced carbon tetrachloride-induced liver fibrosis in mice lacking adiponectin. Gastroenterology 125:1796–1807.14724832
*Kaminski NE, Stevens WD. 1992. The role of metabolism in carbon tetrachloride-mediated immunosuppression. In vitro studies. Toxicology 75:175–188.1462354
*Kaminski NE, Barnes DW, Jordan SD, 1990. The role of metabolism in carbon tetrachloride-mediated immunosuppression: In vivo studies. Toxicol Appl Pharmacol 102:9–20.2296774
*Kaminski NE, Jordan SD, Holsapple MP. 1989. Suppression of humoral and cell-mediated immune responses by carbon tetrachloride. Fundam Appl Toxicol 12:117–128.2925010
Kanada M, Miyagawa M, Sato M, 1994. Neurochemical profile of effects of 28 neurotoxic chemicals on the central nervous system in rats. Effects of oral administration on brain contents of biogenic amines and metabolites. Ind Health 32:145–164.7698903
Kanno K, Tazuma S, Chayama K. 2003. AT1A-deficient mice show less severe progression of liver fibrosis induced by CCl4. Biochem Biophys Res Commun 308:177–183.12890498
Kanta J, Kvasnickova E, Bartos F. 1992. Prolonged reduction of hepatocyte proliferative ability in rats after a single treatment with carbon tetrachloride. Int J Exp Path 73:21–26.1576074
Kaphalia BS, Ansari GA. 1989. Covalent modification of hepatic microsomal lipids of rats by carbon tetrachloride. Mol Toxicol 2:199–213.2487757
*Katami T, Nisikawa H, Yasuhara A. 1992. Emission of chlorinated compounds by combustion of waste dry-cleaning materials. Chemosphere 24:343–349.
Kato H, Nakazawa Y. 1987. The effect of carbon tetrachloride on the enzymatic hydrolysis of cellular triacylglycerol in adult rat hepatocytes in primary monolayer culture. Biochem Pharmacol 36:1807–1814.3555504
Kato K, Kawai T, Fujii M, 1985. Enhancing effect of preadministration of carbon tetrachloride on methylazoxymethanol acetate-induced intestinal carcinogenesis. J Toxicol Sci 10:289–293.3007771
Kato T, Miyamoto M, Date T, 2003. Repeated hepatocyte injury promotes hepatic tumorigenesis in hepatatis C virus transgenic mice. Cancer Sci 94(8):679–85.12901792
Katz RM, Jowett D. 1981. Female laundry and dry cleaning workers in Wisconsin: A mortality analysis. Am J Public Health 71:305–307.7468868
Kauppinen T, Partanen T, Degerth R, 1995. Pancreatic cancer and occupational exposures. Epidemiology 6(5):498–502.8562625
*Kauppinen T, Pukkala E, Saalo A, 2003. Exposure to chemical carcinogens and risk of cancer among Finnish laboratory workers. Am J Ind Med 44:343–350.14502761
Kauschke SG, Knorr A, Heke M. 1999. Two assays for measuring fibrosis: Reverse transcriptase-polymerase chain reaction of collagen alph1 (III) mRNA is an early predictor of subsequent collagen deposition while a novel serum N-terminal procollagen (III) propeptide assay reflects manifest fibrosis in carbon tetrachloride-treated rats. Anal Biochem 275(2):131–140.10552896
*Kazantzis G, Bomford RR. 1960. Dyspepsia due to inhalation of carbon tetrachloride vapor. Lancet, February 13, 360–362.14405040
Kefalas V, Stacey NH. 1989. Potentiation of carbon tetrachloride-induced lipid peroxidation by trichloroethylene in isolated rat hepatocytes: No role in enhanced toxicity. Toxicol Appl Pharmacol 101:158–169.2799814
Kefalas V, Stacey NH. 1991. Potentiating effects of chlorinated hydrocarbons on carbon tetrachloride toxicity in isolated rat hepatocytes and plasma membranes. Toxicol Appl Pharmaol 109:171–179.
*Kelly TJ, Mukund R, Spicer CW, 1994. Concentrations and transformations of hazardous air pollutants. Environ Sci Technol 28:378–387.
*Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Safety 4:26–38.7379718
Kenel MF, Kulkarni AP. 1985a. Ethanol potentiation of carbon tetrachloride hepatotoxicity: Possible role for the in vivo inhibition of aldehyde dehydrogenase. Gen Pharmacol 16:355–360.4043713
Kenel MF, Kulkarni AP. 1985b. Inhibition of hepatic aldehyde dehydrogenase by carbon tetrachloride: An in vitro study. Int J Biochem 17:605–610.3928415
Kennedy GL, Graepel GJ. 1991. Acute toxicity in the rat following either oral or inhalation exposure. Toxicol Lett 56:317–326.2035177
*Kerfoot HB. 1990. Soil-gas surveys for detection and delineation of groundwater contamination. Trends Anal Chem 9:157–163.
*Kernan GJ, Ji B-T, Dosemeci M, 1999. Occupational risk factors for pancreatic cancer: A case-control study based on death certificates from 24 U.S. states. Am J Ind Med 36:260–270.10398934
*Kier LD, Neft R, Tang L, 2004. Applications of microarrays with toxicology relevant genes (tox genes) for the evaluation of chemical toxicants in Sprague Dawley rats in vivo and human hepatocytes in vitro. Mutat Res 549:101–113.15120965
*Kim YC. 1997. Dichloromethane potentiation of carbon tetrachloride hepatotoxicity in rats. Fundam Appl Toxicol 35:138–141.9024681
Kim YK. 1988. Hypogonadism in hepatic failure. Nishinihon J Urology 50:1–6.
*Kim HJ, Bruckner JV, Dallas CE, 1990a. Effect of dosing vehicles on the pharmacokinetics of orally administered carbon tetrachloride in rats. Toxicol Appl Pharmacol 102:50–60.2296771
*Kim HJ, Odendhal S, Bruckner JV. 1990b. Effect of oral dosing vehicles on the acute hepatotoxicity of carbon tetrachloride in rats. Toxicol Appl Pharmacol 102:34–49.2296770
Kim JY, Park JK, Emmons B, 1995. Survey of volatile organic compounds at a municipal solid waste cocomposing facility. Water Environ Res 67(7):1044–1051.
*Kim ND, Kwak MK, Kim SG. 1997. Inhibition of cytochrome P450 2E1 expression by 2-(allylthio)pyrazine, a potential chemoprotective agent: Hepatoprotective effects. Biochem Pharmacol 53(3):261–269.9065729
*Kim SG, Chung HC, Cho JY. 1996. Molecular mechanism for alkyl sulfide-modulated carbon tetrachloride-induced hepatotoxicity: The role of cytochrome P450 2E1, P450 2B and glutathione S-transferase expression. J Pharmacol Exp Ther 277(2):1058–1066.8627517
Kiplinger GF, Kensler CJ. 1963. Failure of phenoxybenzamine to prevent formation of hepatomas after chronic carbon tetrachloride administration. J Natl Cancer Inst 30:837–843.14032946
Kirman CR, Sweeney LM, Meek ME, 2003. Assessing the dose-dependency of allometric scaling performance using physiologically based pharmacokinetic modeling. Regul Toxicol Pharmacol 38:345–367.14623485
*Kirtland BC, Aelion CM, Stone PA, 2003. Isotopic and geochemical assessment of in situ biodegradation of chlorinated hydrocarbons. Environ Sci Technol 37:4205–4212.14524454
*Kittleson KD, Borden CW. 1956. Acute renal failure due to carbon tetrachloride poisoning. Northwestern University Medical School Magazine 30:117–123.
Klaassen CD, Liu J. 1998. Induction of metallothionein as an adaptive mechanism affecting the magnitude and progression of toxicological injury. Environ Health Perspect 106(Suppl 1):297–300.9539022
Klaassen CD, Plaa GL. 1966. Relative effects of various chlorinated hydrocarbons on liver and kidney function in mice. Toxicol Appl Pharmacol 9:139–151.5967557
Klaassen CD, Plaa GL. 1967. Relative effects of various chlorinated hydrocarbons on liver and kidney function in dogs. Toxicol Appl Pharmacol 10:119–131.6031921
Klaunig JE, Ruch RJ, Pereira MA. 1986. Carcinogenicity of chlorinated methane and ethane compounds administered in drinking water to mice. Environ Health Perspect 69:89–95.3816740
Kliest J, Fast T, Boley JS. 1989. The relationship between soil contaminated with volatile organic compounds and indoor air pollution. Environ Int 15:419–425.
*Kluwe WM. 1981. The nephrotoxicity of low molecular weight halogenated alkane solvents, pesticides and chemical intermediates. Toxicol Kidney 179–226.
*Kluwe WM, Herrmann CL, Hook JB. 1979. Effects of dietary polychlorinated biphenyls and polybrominated biphenyls on the renal and hepatic toxicities of several chlorinated hydrocarbon solvents in mice. J Toxicol Environ Health 5:605–615.226724
Knecht KT, Mason RP. 1988. In vivo radical trapping and biliary secretion of radical adducts of carbon tetrachloride-derived free radical metabolites. Drug Metab Dispos 16:813–817.2907458
*Knecht KT, Mason RP. 1991. The detection of halocarbon-derived radical adducts in bile and liver of rats. Drug Metab Dispos 19:325–331.1676631
*Kniepert E, Siegemund A, Gorisch V. 1990. Influence of ethanol pretreatment of differing duration on toxic effects of carbon tetrachloride in rats. Biomed Biochim Acta 49:1097–1102.2080908
*Kniepert E, Siegemund A, Rosenkranz M, 1991. Toxic effects of carbon tetrachloride during short and long term ethanol intake in rats. Arch Toxicol Suppl 14:263–265.1805745
Kobayashi K, Mutai M, Goto K, 1997. Effects of carbon tetrachloride administration on initiation of liver cell foci by the non-hepatocarcinogens N-methyl-N'-nitro-N-nitrosoguanidine (MNNG) and benzo(a)pyrene (B(a)P). Cancer Lett 118:55–60.9310260
*Koch I, Weil R, Wolbold R, 2002. Interindividual variability and tissue-specificity in the expression of cytochrome P450 3A mRNA. Drug Metab Dispos 30(10):1108–1114.12228187
Kodavanti PR, Joshi UM, Mehendale HM. 1989a. Chlordecone (kepone)-potentiated carbon tetrachloride hepatotoxicity in partially hepatectomized rats—a histomorphometric study. J Appl Toxicol 9:367–375.2482307
Kodavanti PR, Joshi UM, Young RA, 1989b. Protection of hepatotoxic and lethal effects of CCl_4_ by partial hepatectomy. Toxicol Pathol 17:494–505.2814225
Kodavanti PR, Joshi UM, Young RA, 1989c. Role of hepatocellular regeneration in chlordecone potentiated hepatotoxicity of carbon tetrachloride. Arch Toxicol 63:367–375.2479360
Kodavanti PR, Kodavanti UP, Faroon OM, 1992. Pivotal role of hepatocellular regeneration in the ultimate hepatotoxicity of CCl_4_ in chlordecone-, mirex, or phenobarbital-pretreated rats. Toxicol Pathol 20:556–569.1284994
Kodavanti PR, Kodavanti UP, Mehendale HM. 1990a. Altered hepatic energy status in chlordecone (Kepone)-potentiated CCl_4_ hepatotoxicity. Biochem Pharmacol 40:859–866.1696822
*Kodavanti PR, Kodavanti UP, Mehendale HM. 1990b. Carbon tetrachloride-induced alterations of hepatic calmondulin and free calcium levels in rats pretreated with chlordecone. Hepatology 9:230–238.
*Kodavanti PR, Rao VC, Mehendale HM. 1993. Loss of calcium homeostatis leads to progressive phase of chlordecone-potentiated carbon tetrachloride hepatotoxicity. Toxicol Appl Pharmacol 122:77–87.7690997
*Kohno H, Hoshino Y, Katoh S, 1992. Effect of retinoic acid on liver transglutaminase activity and carbon tetrachloride-induced liver damage in mice. Experientia 48:386–388.1349864
*Kolpin DW, Squillace PJ, Zogorski JS, 1997. Pesticides and volatile organic compounds in shallow urban groundwater of the United States. In: Groundwater urban environment proceedings, IAH Congress, 27^th^. Chilton J, ed. Balkema: Rotterdam, Netherlands, 69–74.
*Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
*Koporec KP, Kim HJ, MacKenzie WF, 1995. Effect of oral dosing vehicles on the subchronic hepatotoxicity of carbon tetrachloride in the rat. J Toxicol Environ Health 44:13–27.7823328
Koptagel E, Bulut HE. 1998. Effects of short-term hydrocarbon inhalation on rat tracheal mucosa. Okajimas Fol Anat Jpn 75(2–3):71–86.
*Korsrud GO, Grice HC, McLaughlan JM. 1972. Sensitivity of several serum enzymes in detecting carbon tetrachloride-induced liver damage in rats. Toxicol Appl Pharmacol 22:474–483.5041376
*Kostyuk VA, Potapovich AI. 1991. Damage of rat liver microsomal mixed function oxidase system by carbon tetrachloride in vivo study with selective inhibitor of lipid peroxidation. Biochem Int 25:349–353.1789798
Kourounakis PN. 1994. Effect of spironolactone on dimethyl mercury toxicity: A possible molecular mechanism. Arzneim Forsch 44(10):1150–1153.7818591
Kovalovich K, DeAngelis RA, Li W. 2000. Increased toxin-induced liver injury and fibrosis in interleukin-6-deficient mice. Hepatology 31:149–159.10613740
Krähenbühl L, Ledermann M, Lang C, 2000. Relationship between hepatic mitochondrial functions in vivo and in vitro in rats with carbon tetrachloride-induced liver cirrhosis. J Hepatol 33:216–223.10952239
Krapotkina MA. 1981. Clinical and experimental estimation of toxic effects of and derivation of maximum permissable concentration for adipic acid in the air of a work environment. Gig Tr Prof Zabol 0(5):46–47.
Kravetz D, Bosch J, Arderiu M, 1989. Hemodynamic effects of blood volume restitution following a hemorrhage in rats with portal hypertension due to cirrhosis of the liver: Influence of the extent of portal-systemic shunting. Hepatology 9:808–814.2714733
*Kriegman-King MR, Reinhard M. 1991. Abiotic transformation of carbon tetrachloride in the presence of sulfide and mineral surfaces. Amer Chem Soc, Div Environ Chem. Preprint, 203rd ACS National Meeting 32:495–498.
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Anderson ME, Clewell HJ II I, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. Toxicology of Chemical Mixtures 399–437.
Kristensen DB, Kawada K, Imamura K, 2000. Proteome analysis of rat hepatic stellate cells. Hepatology 32(2):268–277.10915733
Kroneld R, Reunanen M. 1990. Determination of volatile pollutants in human and animal milk by GC-MS. Bull Environ Contam Toxicol 44:917–923.2354270
*Kronevi T, Wahlberg J, Holmberg B. 1979. Histopathology of skin, liver, and kidney after epicutaneous administration of five industrial solvents to guinea pigs. Environ Res 19:56–69.510271
Kubic VL, Anders MW. 1980. Metabolism of carbon tetrachloride to phosgene. Life Sci 26:2151–2155.7401914
Kulcsar-Gergely J, Kulcsar A. 1992. Metoprolol and propranolol treatment in carbon tetrachloride-induced hepatic injury. Arzneim Forsch 42(10):1192–1195.1472140
*Kwon YH, Jovanovic A, Serfas MS, 2004. The Cdk inhibitor p21 is required for necrosis, but it inhibits apoptosis following toxin-induced liver injury. J Biol Chem 278(32):30348–30355.
LaCagnin LB, Connor HD, Mason RP, 1987. The carbon dioxide anion radical adduct in the perfused rat liver: Relationship to halocarbon-induced toxicity. Mol Pharmacol 33:351–257.
Lachnit V, Pietschmann H. 1960. Activity of serum glutamic-oxaloacetic transaminase and aldolase in workers exposed to halogenated hydrocarbons. Ind Med Surg 29:523–526.13758077
*Lai EK, McCay PB, Noguchi T, 1979. In vivo spin-trapping of trichloromethyl radicals formed from carbon tetrachloride. Biochem Pharmacol 28:2231–2235.227403
*Lam RH F, Brown JP, Fan AM. 1994. Chemicals in California drinking water: Source of contamination, risk assessment, and drinking water standards. In: Wang RGM, ed. Water contamination and health. New York, NY: Marcel Dekker, Inc., 15–44.
Lamb RG, Borzelleca JF, Condie LW, 1989. Toxic interactions between carbon tetrachloride and chloroform in cultured rat hepatocytes. Toxicol Appl Pharmacol 101:106–113.2799811
*Lamson PD, Minot AS, Robbins BH. 1928. The prevention and treatment of carbon tetrachloride intoxication. J Am Med Assoc 90:345–346.
*Landsberg L, Young JB 1998. Pheochromocytoma. In: Fauci AS, Martin JB, Braunwald E, , eds. Harrison's principles of internal medicine,14th ed. New York: McGraw-Hill, 2057–2060.
*LaRegina J, Bozzelli JW, Harkov R, 1986. Volatile organic compounds at hazardous waste sites and a sanitary landfill in New Jersey. Environmental Progress 5:18–27.
*Larsen T, Kjeldsen P, Christensen TH. 1992. Sorption of hydrophobic hydrocarbons on three aquifer materials in a flow through system. Chemosphere 24:439–451.
Lasierra J, Barrao F, Cena G, 1992. Changes in the frinbrinolytic sytem in liver dysfunction: Role of portal hypertension. Thromb Res 67(1):15–21.1440512
*Leach CN. 1922. Carbon tetrachloride in the treatment of hookworm disease. J Am Med Assoc 78:1789–1790.
*Leclercq IA, Field J, Farrell GC. 2003. Leptin-specific mechanisms for impaired liver regeneration in ob/ob mice after toxic injury. Gastroenterology 124:1451–1464.12730884
Ledda-Columbano GM, Columbano A, Coni P, 1987. Liver cell proliferation induced by the mitogen ethylene dibromide, unlike compensatory cell proliferation, does not achieve initiation of rat liver carcinogenesis by diethylnitrosamine. Cancer Lett 36:247–252.2888528
Lee SY, Ku YS. 2000. Pharmacokinetics and hepatoprotective effects of 2-methylaminoethyl-4,4'-dimethoxy-5,6,5',6'-dimethylenedioxybiphenyl-2-carboxylic acid -2'-carboxylate monohydrochloride in rats with CCl4-induced acute hepatic failure. J Pharm Pharmacol 52:1099–1103.11045890
Lee KJ, Woo E-R, Choi CY, 2004. Protective effect of acteoside on carbon tetrachloride-induced hepatotoxicity. Life Sci 74:1051–1064.14672760
*Lee PY, McCay PB, Hornbrook KR. 1982. Evidence for carbon tetrachloride-induced lipid peroxidation in mouse liver. Biochem Pharmacol 31(3):405–409.7073767
*Lee VM, Cameron RG, Archer MC. 1998. Zonal location of compensatory hepatocyte proliferation following chemically induced hepatotoxicity in rats and humans. Toxicol Pathol 26(5):621–627.9789948
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
*Lehmann KB, Schmidt-Kehl L. 1936. The thirteen most important chlorinated aliphatic hydrocarbons from the standpoint of industrial hygiene. Arch Hygiene 116:132–200.
Leighton DT Jr, Calo JM. 1981. Distribution coefficients of chlorinated hydrocarbons in dilute air-water systems for groundwater contamination applications. J Chem Eng Data 26:382–385.
LeSage GD, Glaser SS, Marucci L, 1999. Acute carbon tetrachloride feeding induces damage of large but not small cholangiocytes from BDL rat liver. Am J Physiol 39:G1289–G1302.
*Letkiewicz F. 1983. Occurrence of carbon tetrachloride in drinking water, food and air. McLean, Virginia: JRB Associates, Inc. PB95183174.
Leung HW. 1991. Development and utilization of physiologically based pharmacokinetic models for toxicological applications. J Toxicol Environ Health 32:247–267.2002511
*Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Levine D, Rockey DC, Milner TA, 2000. Expression of the integrin α8β1 during pulmonary and hepatic fibrosis. Am J Pathol 156(6):1927–1935.10854216
Levy BS B, Meyer CB. 1977. Health hazard evaluation determination report number 76–1-388, Bohn Aluminum & Brass Corporation, Danville, Illinois. Cincinnati, OH: National Insitute for Occupational Safety and Health. PB273733.
Lide DR. 1993. CRC handbook of chemistry and physics. 73rd ed. CRC Press, Inc.
*Lillian D, Singh HB, Appleby A, 1975. Atmospheric fates of halogenated compounds. Environ Sci Technol 9:1042–1048.
*Limaye PB, Apte UM, Shankar K, 2003. Calpain released from dying hepatocytes mediates progression of acute liver injury induced by model hepatotoxicants. Toxicol Appl Pharmacol 191:211–226.13678654
*Lindros KO, Cai Y, Penttila KE. 1990. Role of ethanol-inducible cytochrome P-450 IIE1 in carbon tetrachloride–induced damage to centrilobular hepatocytes from ethanol-treated rats. Hepatology 12(5):1092–1097.2227805
Lindroos PM, Zarnegar R, Michalopoulos GK. 1990. Hepatocyte growth factor (hepatopoietin A) rapidly increases in plasma before DNA synthesis and liver regeneration stimulated by partial hepatectomy and carbon tetrachloride administration. Hepatology 13:743–750.
*Link B, Durk H, Thiel D, 1984. Binding of trichloromethyl radicals to lipids of the hepatic endoplasmic reticulum during tetrachloromethane metabolism. Biochem J 223:577–586.6508732
*Litchfield MH, Gartland CJ. 1974. Plasma enzyme activity and hepatocellular changes in the Beagle dog after single or repeated administration of carbon tetrachloride. Toxicol Appl Pharmacol 30:117–128.
Litterst CL, Farber TM, Van Loon EJ. 1973. Potentiation of carbon tetrachloride-induced hepatotoxicity in the dog by chronic exposure to phenobarbital. Toxicol Appl Pharmacol 24:354–362.
Liu P, Kawada N, Mizoguchi Y, 1992. Arachidonate metabolism in D-galactosamine or CCl4-induced acute and chronic liver injuries in rats. Gastroenterol Jpn 27(5):624–632.1330797
Liu S-L, Esposti SD, Yao T, 1995. Vitamin E therapy of acute CCl_4_-induced hepatic injury in mice is associated with inhibition of nuclear factor kappa B binding. Hepatology 22:1474–1481.7590666
Liu Y, Hartley DP, Liu J. 1998. Protection against carbon tetrachloride hepatoxicity by oleanolic acid is not mediated through metallothionein. Toxicol Lett 95:77–85.9635410
*Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Lloyd SA, Franklin MR. 1991. Modulation of carbon tetrachloride hepatoxicity and xenobiotic-metabolizing enzymes by corticosterone pretreatment, adrenalectomy and sham surgery. Toxicol Lett 55:65–75.1998198
Lombardi B, Ove P, Reddy TV. 1985. Endogenous hepatic growth-modulating factors and effects of a choline-devoid diet and of phenobarbital on hepatocarcinogensis in the rat. Nutr Cancer 7:145–154.4080564
*Long RM, Moore L. 1986a. Elevated cytosolic calcium in rat hepatocytes exposed to carbon tetrachloride. J Pharmacol Exp Ther 238:186–191.3014115
*Long RM, Moore L. 1986b. Inhibition of liver endoplasmic reticulum calcium pump by CCl_4_ and release of a sequestered calcium pool. Biochem Pharmacol 35:4131–4137.2431691
Long RM, Moore L. 1987. Cytosolic calcium after carbon tetrachloride, 1,l-dichloroethylene, and phenylephrine exposure. Studies in rat hepatocytes with phosphorylase and quin2. Biochem Pharmacol 36:1215–1221.3593411
Long RM, Moore L. 1988. Biochemical evaluation of rat hepatocyte primary cultures as a model for carbon tetrachloride in rats based on arterial blood: Inhaled air concentration ratios. Toxicol Appl Pharmacol 92:295–306.2963407
*Long RM, Moore L, Schoenberg DR. 1989. Halocarbon hepatotoxicity is not initiated by Ca^2^+ stimulated endonuclease activation. Toxicol Appl Pharmacol 97:350–359.2538008
Lopez del Pino V, Bolt HM. 1977. [Effects of hepatotoxic agents on hepatic microsomal metabolism of estrogens in the rat.] Drug Res 27:2117–2120. (German)
Lopez-Lirola A, Gonzalez-Reimers E, Olivera RM, 2003. Protein deficiency and muscle damage in carbon tetrachloride induced liver cirrhosis. Food Chem Toxicol 41:1789–1797.14563404
*Louis H, Van Laethem J-L, Wu W, 1998. Interleukin-10 controls neutrophilic infiltration, hepatocyte proliferation, and liver fibrosis induced by carbon tetrachloride in mice. Hepatology 28(6):1607–1615.9828225
*Loureiro-Silva MR, Cadelina GW, Iwakiri Y, 2003. A liver-specific nitric oxide donor improves the intra-hepatic vascular response to both portal blood flow increase and methoxamine in cirrhotic rats. J Hepatol 39:940–946.14642609
*Loveday KS, Anderson BE, Resnick MA, 1990. Chromosome aberration and sister chromatid exchange tests in Chinese hamster ovary cells in vitro. V: Results with 46 chemicals. Environ Mol Mutagen 16:272–303.2253606
*Lovelock JE, Maggs RJ, Wade WJ. 1973. Halogenated hydrocarbons in and over the Atlantic. Nature 241:194–196.
Lowrey K, Glende EA, Recknagel RO. 1981a. Destruction of liver microsomal calcium pump activity by carbon tetrachloride and bromotrichloromethane. Biochem Pharmacol 30:135–140.7236302
Lowrey K, Glende EA, Recknagel RO. 1981b. Rapid depression of rat liver microsomal calcium pump activity after administration of carbon tetrachloride or bromotrichloromethane and lack of effect after ethanol. Toxicol Appl Pharmacol 59:389–394.7256776
Loyke HF. 1986. Hematological and blood pressure studies in cell treated rats. J Environ Pathol Toxicol Oncol 7:1–8.3795007
Loyke HF, Maksem JA. 1992. Hepatocellular injury induced by chronic low-dose CCl_4_ in spontaneous and renal hypertensive rats: A correlation to the reversal of experimental rat hypertensive models. J Environ Pathol Toxicol Oncol 11:38–42.1740767
Lu PC. 1992. A health hazard assessment in school arts and crafts. J Environ Pathol Toxicol Oncol 11:12–17.1740762
*Luckey SW, Petersen DR. 2001. Activation of Kupffer cells during the course of carbon tetrachloride-induced liver injury and fibrosis in rats. Exp Mol Pathol 71:226–240.11733948
Lukita-Atmadja W, Sato T, Wake K. 1993. Granuloma formation in the liver of Balb/c mice intoxicated with carbon tetrachloride. Virchows Arch B 64(4):247–257.8287121
Lundh HA B. 1964. Sequence comparison between kidney and liver lesions in the rat following carbon tetrachloride poisoning. J Occup Med 6:123–128.14130684
*Luster MI, Munson AE, Thomas PT, 1988. Development of a testing battery to assess chemical-induced immunotoxicity: National Toxicology Program's guidelines for immunotoxicity evaluation in mice. Fundam Appl Toxicol 10:2–19.3280374
Luster MI, Simeonova PP, Gallucci RM, 2000. The role of tumor necrosis factor α in chemical-induced hepatotoxicity. Ann N Y Acad Sci 919:214–220.11083111
*Lutz RW, Shires TK. 1978. Polysomal changes in rats treated with lethal doses of carbon tetrachloride. Toxicol Appl Pharmacol 45:653–663.725921
Lynge E, Anttila A, Hemminki K, 1997. Organic solvents and cancer. Cancer Causes Control 8(3):406–419.9498902
*Lynn GE, Vorhes FA. 1957. Residues in foods and feeds resulting from fumigation of grains with the commoner liquid formulations of carbon disulfide, carbon tetrachloride, ethylene dichloride and ethylene dibromide. J Assoc Off Agric Chem 40:163–165.
Ma LY, LaCagnin LB, Bowman L, 1989. Carbon tetrachloride inhibits synthesis of pulmonary surfactant disaturated phosphatidylcholines and ATP production in alveolar type II cells. Acta Biochem Biophys 1003:136–144.
Ma X, Zhao J, Lieber CS. 1996. Polyenylphosphosplatidylcholine attenuates non-alcoholic hepatic fibrosis and accelerates its regression. J Hepatol 24(5):604–613.8773917
*Mabey W, Mill T. 1978. Critical review of hydrolysis or organic compounds in water under environmental conditions. J Phys Chem 7:383–415.
*Mackay DM, Freyberg DL, Goltz MN, 1983. A field experiment of ground water transport of halogenated organic solutes (Preprint Extended Abstract). American Chemical Society 196th National Meeting of Division of Environmental Chemists 23:368–371.
*MacMahon HE, Weiss S. 1929. Carbon tetrachloride poisoning with microscopic fat in the pulmonary artery. Am J Pathol 5:623–630.19969878
*Magos L, Snowden R, White IN H, 1982. Isotoxic oral and inhalation exposure of carbon tetrachloride in Porton-Wistar and Fischer rats. J Appl Toxicol 2(5):238–240.7184944
Manautou JE, Silva VM, Henning GE, 1998. Repeated dosing with the peroxisome proliferator clofibrate decreases the toxicity of model hepatotoxic agents in male mice. Toxicology 127:1–10.9699788
*Mannering GJ. 1985. Drug metabolism in the newborn. Fed Proc 44:2302–2308.3156766
*Manno M, deMatteis F, King LJ. 1988. The mechanism of the suicidal, reductive inactivation of microsomal cytochrome P-450 by carbon tetrachloride. Biochem Pharmacol 37:1981–1990.3377806
*Manno M, Ferrara R, Cazzaro S, 1992. Suicidal inactivation of human cytochrome P-450 by carbon tetrachloride and halothane in vitro. Pharmacol Toxicol 70:13–18.1594531
Manno M, Rezzadore M, Cazzaro S. 1991. Suicidal inactivation of cytochrome P-450 by halothane and carbon tetrachloride. Padova, Italy: Institut Occup Med, 329–331.
*Manno M, Rezzadore M, Grossi M, 1996. Potentiation of occupational carbon tetrachloride toxicity by ethanol abuse. Hum Exp Toxicol 15:294–300.8845218
Manno M, Tolando R, Ferrara R, 1995. Suicidal inactivation of haemoproteins by reductive metabolites of halomethanes: A structure-activity relationship study. Toxicology 100:175–183.7624875
Marathe GK, Harrison KA, Roberts LJ, 2001. Identification of platelet-activating factor as the inflammatory lipid mediator in CCl_4_-metabolizing rat liver. J Lipid Res 42:587–596.11290831
*Marchand C, McLean S, Plaa GL. 1970. The effect of SKF 525A on the distribution of carbon tetrachloride in rats. J Pharmacol Exp Therap 714:232–238.
*Markham TN. 1967. Renal failure due to carbon tetrachloride. J Occup Med 9:16–17.6015866
*Martin C, Dutertre-Catella H, Radionoff M, 2003. Effect of age and photoperiodic conditions on metabolism and oxidative stress related markers at different circadian stages in rat liver and kidney. Life Sci 73(3):327–335.12757840
Martin CJ, Le CX C, Guidotti TL, 1999. Zinc exposure in Chinese foundry workers. Am J Ind Med 35:574–580.10332510
*Martinez M, Mourelle M, Muriel P. 1995. Protective effect of colchicine on acute liver damage induced by CCl4. Role of cytochrome P-450. J Appl Toxicol 15(1):49–52.7745225
Masuda Y, Nakamura Y. 1990. Effects of oxygen deficiency and calcium omission on carbon tetrachloride hepatotoxicity in isolated perfused livers from phenobarbital-pretreated rats. Biochem Pharmacol 40:1865–1876.2242020
Mathur AK, Gupta BN. 1998. Dermal toxicity of linear alkylbenzene sulfonate, chromium, and nickel in guinea pigs. J Toxicol Cutaneous Ocul Toxicol 17(4):191–196.
Matkovics B, Novak R, Szabo L, 1978. Effect of acute carbon tetrachloride intoxication on the lipid peroxidation and the enzymes of the perioxide metabolism of rat tissues. Gen Pharmacol 9:329–332.700352
*Matsubara T, Mori S, Touchi A, 1983. Carbon tetrachloride-induced hepatotoxicity in rats: Evidence for different susceptibilities of rat liver lobes. Japan J Pharmacol 33:435–445.6887648
Matwichuk C, Daniel G, DeNovo R 2000. Evaluation of plasma time-activity curves of technetium-99m-mebrofenin for measurement of hepatic function in dogs. Vet Radiol Ultrasound 41(1):78–84.10695885
*Mayama J, Kumano T, Hayakari M, 2003. Polymorphic glutathione S-transferase subunit 3 of rat liver exhibits different susceptibilities to carbon tetrachloride: Differences in their interactions with heat-shock protein 90. Biochem J 372:611–616.12611589
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
*McCann J, Choi E, Yamasaki E, 1975. Detection of carcinogens as mutagens in the Salmonella/microsome test: Assay of 300 chemicals. Proc Nat Acad Sci 72:5135–5139.1061098
*McCarty PL. 1996. Biotic and abiotic transformations of chlorinated solvents in ground water. EPA540r96509. Symp. Nat. Atten. Chlorin. Org. Groundwater. Washington, DC: U.S. Environmental Proteciton Agency, Office of Resource Development, 5–9.
*McCarty PL, Reinhard M. 1993. Biological and chemical transformations of halogenated aliphatic compounds in aquatic and terrestrial environments. In: Oremland RS, ed. The biochemistry of global change: Radiative trace gases. New York, NY: Chapman & Hall, 839–852.
*McCarty PL, Semprini L. 1994. Ground-water treatment for chlorinated solvents. In: Norris RD, , eds. Handbook of bioremediation. Boca Raton, FL: Lewis Publishers, 87–116.
McCarty LP, Flannagan DC, Randall SA, 1992. Acute toxicity in rats of chlorinated hydrocarbons given via the intratracheal route. Human Exp Toxicol 11:173–177.
*McCarty PL, Goltz MN, Hopkins GD, 1996. In-situ biodegradtion of chlorinated solvent contaminants in groundwater. In: Proc-WEFTEC. Annual Conference Expo., 69th, Vol. 3, 217–223.
McClenny WA, Pleil JD, Lumpkin TA, 1987. Toxic monitoring with canister-based systems. Proceedings of the APCA Annual Meeting 80:87/62.3.
*McCollister DD, Beamer WH, Atchison GJ, 1951. The absorption, distribution and elimination of radioactive carbon tetrachloride by monkeys upon exposure to low vapor concentrations. J Pharmacol Exp Therap 102:112–124.14841595
*McConnell G, Ferguson DM, Peason CR. 1975. Chlorinated hydrocarbons and the environment. Endeavour 34:13–18.54249
*McDermott WV, Hardy HL. 1963. Cirrhosis of the liver following chronic exposure to carbon tetrachloride. J Occup Med 5:249–251.
McGregor D, Lang M. 1996. Carbon tetrachloride: Genetic effects and other modes of action. Mutat Res 366:181–195.9033667
*McGuire LW. 1932. Carbon tetrachloride poisoning. J Am Med Assoc 99:988–989.
McKinney JD, Maurer RR, Hass JR, 1975. Possible factors in the drinking water of laboratory animals causing reproductive failure. In: Keith LH, ed. Identification and analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Science Publishers Inc., 417–432.
*McKone TE. 1987. Human exposure to volatile organic compounds in household tap water: The indoor inhalation pathway. Environ Sci Technol 21:1194–1201.
McKone TE. 1989. Household exposure models. Toxicol Lett 49:321–339.2690408
*McLean AE M, McLean EK. 1966. The effect of diet and l,l,l-trichloro-2,2-bis-(p-chlorophenyl)ethane (DDT) on microsomal hydroxylating enzymes and on sensitivity of rats to carbon tetrachloride poisoning. Biochem J 100:564–571.16742407
*McMahon BM. 1971. Analysis of commercially fumigated grains for residues of organic fumigants. J Assoc Off Anal Chem 51:964–965.
*Mehendale HM. 1990. Potentiation of halomethane hepatotoxicity by chlordecone: A hypothesis for the mechanism. Med Hypotheses 33:289–299.1708849
*Mehendale HM. 1991. Commentary: Role of hepatocellular regeneration and hepatolobular healing in the final outcome of liver injury. A two-stage model of toxicity. Biochem Pharmacol 42:1155–1162.1716097
*Mehendale HM. 1992. Biochemical mechanisms of biphasic dose-response relationships: Role of hormesis. In: Calabrese EJ, ed. Biological effects of low level exposures to chemicals and radiation. Chelsea, MI: Lewis Publishers, 59–94.
Mehendale HM. 1994. Amplified interactive toxicity of chemicals at nontoxic levels: Mechanistic considerations and implications to public health. Environ Health Perspect 102(Suppl. 9):139–149.
*Mehendale HM, Klingensmith JS. 1988. In vitro metabolism of carbon tetrachloride by rats pretreated with chlordecone, mirex, or phenobarbital. Toxicol Appl Pharmacol 93:247–256.2451866
*Mehendale HM, Ray SD, Cai Z. 1991. Paradoxical toxicity of CCl_4_ in isolated hepatocytes from chlordecone, phenobarbital and mirex pretreated rats. In Vitro Toxicol 4:187–196.
Melin A-M, Perromat A, Deleris G. 2001. The in vivo toxicity of carbon tetrachloride and carrageenan on heart microsomes: Analysis by fourier transform infrared spectroscopy. Can J Physiol Pharmacol 79(9):799–804.11599781
Michael LC, Pellizzari ED, Perritt RL, 1990. Comparison of indoor, backyard, and centralized air monitoring strategies for assessing personal exposure to volatile organic compounds. Environ Sci Technol 24:996–1003.
*Michael LC, Pellizzari ED, Wiseman RW. 1988. Development and evaluation of a procedure for determining volatile organics in water. Environ Sci Technol 22:565–570.22195629
*Mico BA, Pohl LR. 1983. Reductive oxygenation of carbon tetrachloride: Trichloromethylperoxyl radical as a possible intermediate in the conversion of carbon tetrachloride to electrophilic chlorine. Arch Biochem Biophys 225:596–609.6625601
Mikhail TH, Awadallah R, El-Dessoukey EA. 1978. Effect of AMP on serum minerals in carbon-tetrachloride hepatotoxicity. Z Ernahrungswiss 17:47–51.654351
*Milanovich FP. 1986. Detecting chloroorganics in groundwater. Environ Sci Technol 20:441–442.19994926
*Mirpuri E, Garcia-Trevijano ER, Castilla-Cortazar, 2002. Altered liver gene expression in CCl_4_-cirrhotic rats is partially normalized by insulin-like growth factor-I. Int J Biochem Cell Biol 34(3):242–252.11849991
*Mirsalis JC, Butterworth BE. 1980. Detection of unscheduled DNA synthesis in hepatocytes isolated from rats treated with genotoxic agents: An in vivo-in vitro assay for potential carcinogens and mutagens. Carcinogenesis 1:621–625.11219838
Mirsalis JC, Steinmetz KL. 1990. The role of hyperplasia in liver carcinogenesis. In: Mouse liver carcinogenesis: Mechanisms and species comparisons. Alan R. Liss, Inc., 149–161.
*Mirsalis JC, Tyson CK, Butterworth BE. 1982. Detection of genotoxic carcinogens in the in vivo-in vitro hepatocyte DNA repair assay. Environ Mutagen 4:553–562.7140674
*Mizuguchi H, Yamazaki Y, Shikamoto Y, 2002. Prothrombin activation during carbon tetrachloride-induced acute liver injury in mice. Thromb Res 106:257–261.12297134
Mizumoto M, Arii S, Furutani M, 1997. NO as an indicator of portal hemodynamics and the role of iNOS in increased NO production in CCL_4_-induced liver cirrhosis. J Surg Res 70:124–133.9245560
Moghaddam AP, Eggers JS, Calabrese EJ. 1998. Evaluation of sex difference in tissue repair following acute carbon tetrachloride toxicity in male and female Sprague-Dawley rats. Toxicology 130(2–2):95–105.9865477
*Mohamed MF, Kang D, Aneja VP. 2002. Volatile organic compounds in some urban locations in United States. Chemosphere 47:863–882.12079081
Mokuda O, Ubukata E, Sakamoto Y. 1995. Impaired glucose uptake and intact gluconeogenesis in perfused rat liver after carbon tetrachloride injury. Biochem Mol Med 54(1):38–42.7551815
*Molina MJ, Rowland FS. 1974. Predicted present stratospheric abundances of chlorine species from photodissociation of carbon tetrachloride. Geophys Res Lett 1:309–312.
Montalto de Mecca M, Castro GD, Diaz Gomez MI. 1995. Dithiothreitol inhibitory effects on carbon tetrachloride-promoted naph-dependent lipid peroxidation in liver microsomal suspensions. Res Commun Mol Pathol Pharmacol 88(28):205–213.7670852
*Moody DA. 1992. Effect of phenobarbital treatment on carbon tetrachloride-mediated cytochrome P-450 loss and diene conjugate formation. Toxicol Lett 61:213–224.1641868
Moody DE, James JL, Smuckler EA. 1990. Phenobarbital pretreatment alters the localization of CCl4-induced changes in rat liver microsomal fatty acids. Toxicol Appl Pharmacol 103:16–27.2315927
*Moore L. 1980. Inhibition of liver-microsome calcium pump by in vivo administration of CCl4, CHCl3, and 1,1-dichloroethylene (vinylidene chloride). Biochem Pharmacol 29:2505–2511.6252901
*Moore L, Davenport GR, Landon EJ. 1976. Calcium uptake of a rat liver microsomal subcellular fraction in response to in vivo administration of carbon tetrachloride. J Biol Chem 251(4):1197–1201.1249072
Moore L, Schoenberg DR, Long RM. 1990. Impact of halogenated compounds on calcium homeostasis in hepatocytes. Environ Health Perspect 84:149–153.2190809
*Morgan A, Black A, Belcher DR. 1970. The excretion in breath of some aliphatic halogenated hydrocarbons following administration by inhalation. Ann Occup Hyg 13:219–233.5509094
*Morgan DL, Copper SW, Carlock DL, 1991. Dermal absorption of neat and aqueous volatile organic chemicals in the Fischer 344 rat. Environ Res 55:51–63.1855490
Morio LA, Chiu H, Sprowles KA, 2001. Distinct roles of tumor necrosis factor-a and nitric oxide in acute liver injury induced by carbon tetrachloride in mice. Toxicol Appl Pharmacol 172:44–51.11264022
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
*Mourelle M, Franco MT. 1991. Erythrocyte defects precede the onset of CCl4-induced liver cirrhosis protection by silymarin. Life Sci 48:1083–1090.1847733
Mourelle M, Meza M. 1990. CCl_4_-induced lipoperoxidation triggers a lethal defect in the liver plasma membranes. J Appl Toxicol 10:23–27.2139883
Murakami T, Nagamura Y, Hirano K. 1998. The effect of ethanolamine on acute carbon tetrachloride intoxication. Biol Pharm Bull 21(1):84–86.9477176
Muriel P. 1993. S-adenosyl-L-methionine prevents and reverses erythrocyte membrane alterations in cirrhosis. J Appl Toxicol 13(3):179–182 8392094
*Muriel P. 1998. Nitric oxide protection of rat liver from lipid peroxidation, collagen accumulation, and liver damage induced by carbon tetrachloride. Biochem Pharmacol 56:773–779.9751083
*Muriel P, Escobar Y. 2003. Kupffer cells are responsible for liver cirrhosis induced by carbon tetrachloride. J Appl Toxicol 23:103–108.12666154
Muriel P, Mourelle M. 1990. Prevention by Silymarin of membrane alterations in acute CCl_4_ liver damage. J Appl Toxicol 10:275–279.1975258
*Muriel P, Alba N, Perez-Alvarez VM, 2001. Kupffer cells inhibition prevents hepatic lipid peroxidation and damage induced by carbon tetrachloride. Comp Biochem Physiol C 130:219–226.
*Muro H, Shirasawa H, Kosugi I, 1990. Defect of sinusoidal Fc receptors and immune complex uptake in CCl_4_-induced liver cirrhosis in rats. Gastroenterology 99:200–210.2344926
Murphy SD, Malley S. 1969. Effect of carbon tetrachloride on induction of liver enzymes by acute stress or corticosterone. Toxicol Appl Pharmacol 15:117–130.4389676
Murray M, Farrell GC. 1984. Different effects of carbon tetrachloride toxicity and cirrhosis on substrate binding to rat hepatic microsomal cytochrome P-450. Biochem Pharmacol 33:687–689.6704188
Murray M, Zaluzny L, Farrell GC. 1987. Impaired androgen 16 α-hydroxylation in hepatic microsomes from carbon tetrachloride-cirrhotic male rats. Gastroenterology 93:141–147.3582901
Nagai H, Shimazawa T, Yakuo I, 1989a. Role of peptide-leukotrienes in liver injury in mice. Inflammation 13:673–680.2575600
Nagai H, Shimazawa T, Yakuo I, 1989b. The role of thromboxane A_2_ [TxA_2_] in liver injury in mice. Prostaglandins 38:439–446.2813811
Nagano K, Katagiri T, Aiso S, 1997. Spontaneous lesions of nasal cavity in aging F344 rats and BDF1 mice. Exp Toxicol Pathol 49:97–104.9085083
*Nagano K, Nishizawa T, Yamamoto S, 1998. Inhalation carcinogenesis studies of six halogenated hydrocarbons in rats and mice. In: Chiyotani K, Hosoda Y, Aizawa Y, eds. Advances in the prevention of occupational respiratory diseases. Elsevier Science B.V., 741–746.
Nakahira K, Takahashi T, Shimizu H, 2003. Protective role of heme oxygenase-1 induction in carbon tetrachloride-induced hepatotoxicity. Biochem Pharmacol 66:1091–1105.12963497
*Nakajima T, Sato A. 1979. Enhanced activity of liver drug-metabolizing enzymes for aromatic and chlorinated hydrocarbons following food deprivation. Toxicol Appl Pharmacol 50:549–556.516066
*Nakamura S, Oda Y, Shimada T, 1987. SOS-inducing activity of chemical carcinogens and mutagens in Salmonella typhimurium TA1535/pSK1002: Examination with 151 chemicals. Mutat Res 192:239–246.3317033
Nakamura T, Arii S, Monden K, 1998. Expression of the Na+/Ca2+ exchanger emerges in hepatic stellate cells after activation in association with liver fibrosis. Proc Natl Acad Sci U S A 95(9):5389–5394.9560286
*Nakata R, Tsukamoto I, Miyoshi M, 1975. Liver regeneration after carbon tetrachloride intoxication in the rat. Biochem Pharmacol 34:586–588.
Nardacci R, Lacono OL, Ciccosanti F, 2003. Transglutaminase type II plays a protective role in hepatic injury. Am J Pathol 162(4):1293–1303.12651621
Narotsky MG, Kavlock RJ. 1995. A multidisciplinary approach to toxicological screening: II. Developmental toxicity. J Toxicol Environ Health 45:145–171.7783251
*Narotsky MG, Brownie CF, Kavlock RJ, 1997a. Critical period of carbon tetrachloride-induced pregnancy loss in Fischer-344 rats, with insights into the detection of resorption sites by ammonium sulfide staining. Teratology 56(4):252–261.9408976
Narotsky MG, Hamby BT, Best DS, 1995. Carbon tetrachloride (CCl_4_)-induced pregnancy loss in F-344 rats: Leutenizing hormone (LH) levels and rescue by human chorionic gonadotropin (hCG). Biol Reprod 52:172.
Narotsky MG, Hamby BT, Mitchell DS, 1992. Full-litter resorptions caused by low molecular weight halocarbons in F-344 rats. Teratology Society Abstracts, 472–473.
Narotsky MG, Hamby BT, Mitchell DS, 1994. Effect of vehicle on the developmental toxicity of bromodichloromethane (BDCM) and carbon tetrachloride. Teratology 49(5):395.
*Narotsky MG, Pegram RA, Kavlock RJ. 1997b. Effect of dosing vehicle on the developmental toxicity of bromodichloromethane and carbon tetrachloride in rats. Fundam Appl Toxicol 40:30–36.9398485
NAS. 1977. Drinking water and health. Washington, DC: National Academy of Sciences, 703–707.
*NAS. 1978. Chloroform, carbon tetrachloride, and other halomethanes: An environmental assessment. Washington, DC: National Academy of Sciences.
NAS. 1980. Drinking water and health, Volume 3. Washington, DC: National Academy of Sciences.
NAS. 1984. Causes and effects of changes in stratospheric ozone: Update 1983. Washington DC: National Academy of Sciences.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
Nath RG, Li D, Randerath K. 1990. Acute and long-term effects of carbon tetrachloride on DNA modifications (I-compounds) in male mouse liver. Chem Biol Interactions 76:343–357.
NATICH. 1991. NATICH data base report on state, local and EPA air toxics activities. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. National Air Toxics Information Clearinghouse.
*NCI. 1976a. Report on carcinogenesis bioassay of chloroform. Bethesda, MD: National Cancer Institute, March 1, 1976.
*NCI. 1976b. Carcinogenesis bioassay of trichloroethylene. National Cancer Institute Technical Report Series, No. 2. Bethesda, MD: National Cancer Institute. PB264122. NCICGTR2.
*NCI. 1977. Bioassay of 1,1,1-trichloroethane for possible carcinogenicity. National Cancer Institute Carcinogenesis Technical Report Series No. 3. U.S. Department of Health, Education, and Welfare. PB265082.
*Neely WB. 1977. Material balance analysis of trichlorofluoromethane and carbon tetrachloride in the atmosphere. Sci Total Environ 8:267–274.918654
*Neely WB, Branson DR, Blau GE. 1974. Partition coefficient to measure bioconcentrations potential of organic chemicals in fish. Environ Sci Technol 8:1113–1115.
Nelson ED P, Shikiya D, Liu CS. 1987. Multiple air toxics exposure and risk assessment in the South Coast Air Basin. Proceedings of the APCA Annual Meeting 89:87/97.4.
Neubauer K, Knittel T, Aurisch S, 1996. Glial fibrillary acidic protein -a cell type specific marker for Ito cells in vivo and in vitro. J Hepatol 24(6):719–730.8835748
*New PS, Lubash GD, Scherr L, 1962. Acute renal failure associated with carbon tetrachloride intoxication. J Am Med Assoc 181:903–906.
Nhongsaeng J, Toskulkao C, Glinsukon T. 1990. Potentiation of the mechanism of carbon tetrachloride induced hepatotoxicity by thinner inhalation. Res Commun Subst Abuse 11:73–76.
*Niederberger M, Gines P, Martin P-Y, 1998. Increased renal and vascular cytosolic phospholipase A2 activity in rats with cirrhosis and ascites. Hepatology 27(1):42–47.9425915
Nielsen VK, Larsen J. 1965. Acute renal failure due to carbon tetrachloride poisoning. Acta Med Scand 178:363.5829110
NIOSH. 1975. Occupational exposure to carbon tetrachloride. Washington, DC: National Institute for Occupational Safety and Health, Department of Health, Education, and Welfare.
*NIOSH. 1984. Hydrocarbons, halogenated-method 1003. NIOSH Manual of Analytical Methods. 3rd ed. (2nd supplement). Cincinnati, OH: National Institute for Occupational Safety and Health, 1003–1 to 1003–9.
NIOSH. 1986. NIOSH recommendations for occupational safety and health standards. Atlanta, GA: U.S. Department of Health and Human Services, National Institute for Occupation Safety and Health, September, 1986.
NIOSH. 1992. Recommendation for occupational safety, health, compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, Centers for Disease Control.
*NIOSH. 2003. NIOSH pocket guide to chemical hazards. Carbon tetrachloride. Washington, DC: National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npg.html. June 6, 2003.
*Nirmalakhandan NN, Speece RE. 1988. Prediction of aqueous solubility of organic chemicals based on molecular structure. Environ Sci Technol 22:328–338.22288868
Nishida K, Ohta Y, Ishiguro I. 1998a. Glutamylcysteinethyl ester attenuates progression of carbon tetrachloride-induced acute liver injury in mice. Toxicology 126:55–63.9585092
Nishida K, Ohta Y, Ishiguro I. 1998b. Preventive effect of y-glutamylcysteinylethyl ester on carbon tetrachloride-induced hepatic triglyceride accumulation in mice. Toxicol Lett 95:141–146.9635418
Nishida K, Ohta Y, Kongo M, 1996. Response of endogenous reduced glutathione through hepatic glutathione redox cycle to enhancement of hepatic lipid peroxidation with the development of acute liver injury in mice intoxicated with carbon tetrachloride. Res Commun Mol Pathol Pharmacol 93(2):198–218.8884991
NJDEP. 1988. STAL for carbon tetrachloride. Trenton, NJ: New Jersey Department of Environmental Protection.
*NLM. 1988. CAS registry. National Library of Medicine.
Noda T, Morita S, Baba A. 1994. Enhanced teratogenic activity of di-n-butyltin diacetate by carbon tetrachloride pretreatment in rats. Food Chem Toxicol 32(4):321–327.8206427
*Noguchi T, Fong K-L, Lai EK, 1982a. Specificity of a phenobarbital-induced cytochrome P-450 for metabolism of carbon tetrachloride to the trichloromethyl radical. Biochem Pharmacol 31:615–624.7082331
*Noguchi T, Fong K-L, Lai EK, 1982b. Selective early loss of polypeptides in liver microsomes of CCl_4_-treated rats. Relationship to cytochrome P-450 content. Biochem Pharmacol 31:609–614.7082330
Noll T, Hugo-Wisseman D, Littauer A, 1987. The decisive pO_2_-levels in haloalkane-mediated liver cell injury. Free Radic Res Commun 3:293–298.3508440
*Norwood WD, Fuqua PA, Scudder BC. 1950. Carbon tetrachloride poisoning. Arch Ind Hyg Occup Med 1:90–100.15419860
*NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy Press.
NTP. 1985. Fourth annual report on carcinogens (summary). Washington, DC: U.S. Department of Health and Human Services, NTP 85–002, 50–2.
NTP. 1990. Sixth annual report on carcinogens. Summary report to the National Institute of Environmental Health Sciences, Research Triangle Park, NC, by Technical Resources, Inc., Rockville, MD.
*NTP. 2002. Report on carcinogens. Research Triangle Park, NC: National Toxicology Program. http://eph.niehs.nih.gov/roc/tox10.html. June 6, 2003.
Oakley F, Trim N, Constandinou CM, 2003. Hepatocytes express nerve growth factor during liver injury: Evidence for paracrine regulation of hepatic stellate cell apoptosis. Am J Pathol 163(5):1849–1858.14578185
Ochi Y, Yumori Y, Morioka A, 1990. Effect of α-blockade on liver regeneration after carbon tetrachloride intoxication in the rat. Biochem Pharmacol 39:2065–2066.2353947
Ogawa M, Mori T, Mori Y, 1992. Study on chronic renal injuries induced by carbon tetrachloride: Selective inhibition of the nephrotoxicity by irradiation. Nephron 60:68–73.1738417
O'Hara TM, Sheppard MA, Clarke EC, 1991. A CCl_4_/CHCl_3_ interaction study in isolated hepatocytes: Non-induced and phenobarbital-pretreated cells. J Appl Toxicol 11:147–154.2061553
*Ohta Y, Sahashi D, Sasaki E, 1999. Alleviation of carbon tetrachloride-induced chronic liver injury and related dysfunction by L-tryptophan in rats. Ann Clin Biochem 36:504–510.10456214
Okada K, Ueshima S, Imano M, 2004. The regulation of liver regeneration by the plasmin/α2-antiplasmin system. J Hepatol 40:110–116.14672621
Omura M, Katsumata T, Misawa H, 1999. Decrease in protein kinase and phosphatase activities in the liver nuclei of rats exposed to carbon tetrachloride. Toxicol Appl Pharmacol 160:192–197.10527918
O'Neil MJ, Smith A, Heckelman PE, , eds. 2001. Carbon tetrachloride. The Merck index. An encyclopedia of chemicals, drugs, and biologicals. 13th ed. Whitehouse Station, NJ: Merck & Co., Inc., 305–306.
*Onfelt A. 1987. Spindle disturbances in mammalian cells. III. Toxicity, c-mitosis and aneuploidy with 22 different compounds. Specific and unspecific mechanisms. Mutat Res 182(3):135–154.3587257
Onori P, Morini S, Franchitto A, 2000. Hepatic microvascular features in experimental cirrhosis: A structural and morphometrical study in CCl_4_-treated rats. J Hepatol 33(4):555–563.11059860
*Oraumbo IF, Van Duuren BL. 1987. Time-related binding of the hepatocarcingon carbon tetrachloride to hepatic chromatin proteins in vitro. Carcinogenesis 8:855–856.3608085
Oraumbo IF, Van Duuren BL. 1989. Evidence for the covalent interaction of carbon tetrachloride with mouse liver chromatin DNA in vitro. Laboratory of Organic Chemistry and Carcinogensis, Report No. L231.13–18.
Orfila C, Lepert JC, Alric L, 1999. Expression of TNF-alpha and immunohistochemical distribution of hepatic macrophage surface markers in carbon tetrachloride-induced chronic liver injury in rats. Histochem J 31:677–685.10576417
*OSHA. 1989. Occupational Safety and Health Administration. Part III. Fed Regist 2679–2681.
OSHA. 1993. Occupational Safety and Health Administration: Part V. Fed Regist 58:35338–35351.
*OSHA. 2003a. Occupational safety and health standards for shipyard employment. Air contaminants. Washington, DC: Occupational Safety and Health Administration. 29 CFR 1915.1000. http://www.osha.gov/comp-links.html. June 6, 2003.
OSHA. 2003b. Occupational safety and health standards. Health hazards definitions. Washington, DC: Occupational Safety and Health Administration. 29 CFR 1910.1200, Appendix A. http://www.osha.gov/comp-links.html. June 6, 2003.
*OSHA. 2003c. Occupational safety and health standards. Limits for air contaminants. Washington, DC: Occupational Safety and Health Administration. 29 CFR 1910.1000, Table Z-1. http://www.osha.gov/comp-links.html. June 6, 2003.
OSHA. 2003d. Occupational safety and health standards. National Research Council recommendations concerning chemical hygiene in laboratories. Washington, DC: Occupational Safety and Health Administration. 29 CFR 1910.1450, Appendix A. http://www.osha.gov/comp-links.html. June 6, 2003.
*OSHA. 2003e. Occupational safety and health standards. Toxic and hazardous substances. Washington, DC: Occupational Safety and Health Administration. 29 CFR 1910.1000, Table Z-2. http://www.osha.gov/comp-links.html. June 6, 2003.
*OSHA. 2003f. Safety and health regulations for construction. Gases, vapors, fumes, dusts, and mists. Washington, DC: Occupational Safety and Health Administration. 29 CFR 1926.55, Appendix A. http://www.osha.gov/comp-links.html. June 6, 2003.
*OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment, U.S. Congress. OTA-BA-436.
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Ozturk F, Ucar M, Ozturk IC, 2003. Carbon tetrachloride-induced nephrotoxicity and protective effect of betaine in Sprague-Dawley rats. Urology 62(2):353–356.12893363
Paakko P, Anttila S, Sormunen R, 1996. Biochemical and morphological characterization of carbon tetrachloride-induced lung fibrosis in rats. Arch Toxicol 70:540–552.8831904
*Packer JE, Slater TF, Willson RL. 1978. Reactions of the carbon tetrachloride-related peroxy free radical (CCL3O2) with amino acids: Pulse radiolysis evidence. Life Sci 23:2617–2620.739842
Paddle GM. 1983. Incidence of liver cancer and trichloroethylene manufacture: Joint study by industry and a cancer registry. Br Med J 286:846.6403111
Page DA, Carlson GP. 1993. The role of the intestinal tract in the elimination of carbon tetrachloride. Toxicol Appl Pharmacol 124(2):268–274.
Paradis V, Dargere D, Vidaud M, 1999. Expression of connective tissue growth factor in experimental rat and human liver fibrosis. Hepatology 30:968–976.10498649
Parker KJ, Tuthil TA. 1986. Carbon tetrachloride- induced changes in ultrasonic properties of liver. IEEE Trans Biomed Eng 33:453–460.3514434
*Parola M, Leonarduzzi G, Biasi F, 1992. Vitamin E dietary supplementation protects against carbon tetrachloride-induced chronic liver damage and cirrhosis. Hepatology 16:1014–1021.1398481
Paronetto F, Popper H. 1964. Enhanced antibody formation in experimental acute and chronic liver injury produced by carbon tetrachloride or allyl alcohol. Proc Soc Exp Bio Med 116:1060–1064.14230344
*Past MR, Cook DE. 1982. Effect of diabetes on rat liver cytochrome P-450: Evidence for a unique diabetes-dependent rat liver cytochrome P-450. Biochem Pharmacol 31:3329–3334.7150359
*Patki KC, von Moltke LL, Harmatz JS, 2004. Effect of age on in vitro triazolam biotransformation in male human liver microsomes. J Pharmacol Exp Ther 308(3):874–879.14634046
*Paul BB, Rubinstein D. 1963. Metabolism of carbon tetrachloride and chloroform by the rat. J Pharmacol Exp Ther 141:141–148.14057905
*Paustenbach DJ, Carlson GP, Christian JE, 1986a. A comparative study of the pharmacokinetics of carbon tetrachloride in the rat following repeated inhalation exposures of eight and 11.5 hr/day. Fundam Appl Toxicol 6:484–497.3084329
*Paustenbach DJ, Christian JE, Carlson GP, 1986b. The effect of an 11.5-hr/day exposure schedule on the distribution and toxicity of inhaled carbon tetrachloride in the rat. Fundam Appl Toxicol 6:472–483.3699332
Paustenbach DJ, Clewell HJ III, Gargas ML, 1987. Development of a physiologically based pharmacokinetic model for mulitday inhalation of carbon tetrachloride. Pharmacokinetics in risk assessment. Washington DC: National Academy Press, 312–326.
*Paustenbach DJ, Clewell HJ, Gargas ML, 1988. A physiologically based pharmacokinetic model for inhaled carbon tetrachloride. Toxicol Appl Pharmacol 96:191–211.3143166
Pavanato A, Tunon MJ, Sanchez-Campos S, 2003. Effects of quercetin on liver damage in rats with carbon tetrachloride-induced cirrhosis. Dig Dis Sci 48(4):824–829.12741479
*Pawa S, Ali S. 2004. Liver necrosis and fulminant hepatic failure in rats: Protection by oxyanionic form of tungsten. Biochim Biophys Acta 1688:210–222.15062871
*Pearson CR, McConnell G. 1975. Chlorinated Cl and C2 hydrocarbons in the marine environment. Proc R Soc Lond [Biol] 189:305–332.238199
*Pellizzari ED, Sheldon LS, Bursey JT, 1985a. Master scheme for the analysis of organic compounds in water, state-of-the-art review of analytical operations. Washington, DC: U.S. Environmental Protection Agency.
Pellizzari ED, Sheldon LS, Bursey JT. 1985b. GC/MS determination of volatile halocarbons in blood and tissue. In: Fishbein L, O'Neill IK, eds. Environmental carcinogens selected methods of analysis. Vol. 7. International Agency for Research on Cancer, 435–444.
Pellizzari ED, Zweidinger RA, Sheldon LS. 1985c. GC/MS determination of volatile hydrocarbons in breath samples. In: Fishbein L, O'Neill IK, eds. Environmental carcinogens selected methods of analysis. Vol. 7. International Agency for Research on Cancer, 413–431.
*Pentz R, Strubelt O. 1983. Fasting increases the concentrations of carbon tetrachloride and of its metabolite chloroform in the liver of mice. Toxicol Lett 16:231–234.6857718
*Peoples AJ, Pfaffenberger CD, Shafik TM, 1979. Determination of volatile purgeable halogenated hydrocarbons in human adipose tissue and blood serum. Bull Environ Contam Toxicol 23:244–249.497433
*Perez AJ, Courel M, Sobrado J, 1987. Acute renal failure after topical application of carbon tetrachloride. Letter to editor. Lancet: February: 515–516.
Permutt TJ, Moezzi M, Hudischewskyj AB, 1987. Statistical analysis of concentrations of toxic air pollutants in California and Louisiana. Proceedings of the APCA Annual Meeting 80:87/66.1.
*Perocco P, Prodi G. 1981. DNA damage by haloalkanes in human lymphocytes cultured in vitro. Cancer Lett 13:213–218.6457684
*Pessayre D, Colbert B, Descatoire V, 1982. Hepatotoxicity of trichloroethylene-carbon tetrachloride mixtures in rats. Gastroenterology 83:761–772.7106507
*Peters HA, Levine RL, Matthews CG, 1987. Synergistic neurotoxicity of carbon tetrachloride/carbon disulfide (80/20 fumigants) and other pesticides in grain storage workers. Acta Pharmacol Toxicol (Copenhagen) 59:535–546.
Peterson RE, Fujimoto JM. 1976. Increased "bile duct-pancreatic fluid" flow in rats pretreated with carbon tetrachloride. Toxicol Appl Pharmacol 35:29–39.1258057
*Phelps BM, Hu CH. 1924. Carbon tetrachloride poisoning. Report of two fatal cases and a series of animal experiments. J Am Med Assoc 82:1254–1256.
*Pilon D, Brodeur J, Plaa GL. 1986. 1,3-Butanediol-induced increases in ketone bodies and potentiation of CCl_4_ hepatotoxicity. Toxicology 40:165–180.3726892
Pilon D, Brodeur J, Plaa GL. 1988. Potentiation of CCl_4_-induced liver injury by ketonic and ketogenic compounds: Role of the CCl_4_ dose. Toxicol Appl Pharmacol 94:183–190.3388417
Piscaglia F, Knittel T, Kobold D, 1999. Cellular localization of hepatic cytochrome 1B1 expression and its regulation by aromatic hydrocarbons and inflammatory cytokines. Biochem Pharmacol 58:157–165.10403529
Plaa GL. 1997. A four-decade adventure in experimental liver injury. Drug Metab Rev 29(1&2):1–37.9187509
Plaa GL. 2000. Chlorinated methanes and liver injury: Highlights of the past 50 years. Annu Rev Pharmacol Toxicol 40:43–65.
Plaa GL, Larson RE. 1964. Relative nephrotoxic properties of chlorinated methane, ethane and ethylene derivatives in mice. Toxicol Appl Pharmacol 7:37–44.
*Plaa GL, Traiger GJ. 1972. Mechanism of potentiation of CCl_4_-induced hepatotoxicity. Proceedings of the 5th International Congress of Pharmacologists 2:100–113.
Pleil JD, Oliver KD, McClenny WA. 1988. Ambient air analyses using nonspecific flame ionization and electron capture detection compared to specific detection by mass spectroscopy. JAPCA 38:1006–1010.3221253
*Plumb RH. 1991. The occurrence of appendix IX organic constituents in disposal site ground water. Ground Water Monitoring Review XI:157–164.
*Plumb RH Jr. 1992. The importance of volatile organic compounds as a disposal site monitoring parameter. Environ Sci Pollut Control Ser., 4(Groundwater contamination and analysis at hazardous waste sites):173–197.
*Plummer JL, de la M Hall P, Ilsley AH, 1990. Influence of enzyme induction and exposure profile on liver injury due to chlorinated hydrocarbon inhalation. Pharmacol Toxicol 67:329–335.2077526
*Plummer JL, de la M Hall P, Ilsley AH, 1994. Dose-response relationships in hepatic injury produced by alcohol and carbon tetrachloride. Alcohol Clin Exp Res 18(6):1523–1526.7695054
*Podolsky DK, Isselbacher KJ. 1998. Derangements of hepatic metabolism. In: Fauci SS, Martin JB, Braunwald E, , eds. Harrison's principles of internal medicine, 14th ed., 1667–1672.
*Pohl LR, Schulick RD, Highet RJ, 1984. Reductive-oxygenation mechanism of metabolism of carbon tetrachloride to phosgene by cytochrome P-450. Mol Pharmacol 25:318–321.6700577
Poli G, Cheeseman KH, Biasi F, 1989. Promethazine inhibits the formation of aldehydic products of lipid peroxidation but not covalent binding resulting from the exposure of rat liver fractions to CCl_4_. Biochem J 264:527–532.2604730
*Poon MK T, Chiu P-Y, Mak DH F, 2003. Metformin protects against carbon tetrachloride hepatotoxicity in mice. J Pharm Sci 93:501–504.
*Pound AW, Horn L, Lawson TA. 1973. Decreased toxicity of dimethylnitrosamine in rats after treatment with carbon tetrachloride. Pathology 5:233–242.4748059
*Poyer JL, Floyd RA, McCay PB, 1978. Spin-trapping of the trichloromethyl radical produced during enzymic NADPH oxidation in the presence of carbon tetrachloride or bromotrichloromethane. Biochim Biophys Acta 539:402–409.24480
*Poyer JL, McCay PB, Lai EK, 1980. Confirmation of assignment of the trichloromethyl radical spin adduct detected by spin trapping during 13C-carbon tetrachloride metabolism in vitro and in vivo. Biochem Biophys Res Commun 94(4):1154–1160.6249300
Pratt GC, McCourtney M, Wu CY, 1998. Measurement and source apportionment of human exposures to toxic air pollutants in the Minneapolis-St. Paul metropolitan area. Measurement of toxic and related air pollutants. Sewickley, PA: Air and Waste Management Association, 64–72.
*Pratt GC, Palmer K, Wu CY, 2000. An assessment of air toxics in Minnesota. Environ Health Perspect 108:815–825.11017885
*Prendergast JA, Jones RA, Jenkins LJ, 1967. Effects on experimental animals of long-term inhalation of trichloroethylene, carbon tetrachloride, l,l,l-trichloroethane, dichlorofluoromethane, and l,l-dichloroethylene. Toxicol Appl Pharmacol 10:270–289.4962252
Pronzato MA, Domenicotti C, Biasi F, 1990. Inactivation of hepatocyte protein kinase C by carbon tetrachloride: Involvement of drug's metabolic activation and prooxidant effect. Biochem Biophys Res Commun 171:1353–1360.2222449
Ptacek CJ, Gillham RW. 1992. Laboratory and field measurements of nonequilibrium transport in the Borden aquifer, Ontario, Canada. J Contam Hydrol 10:119–158.
Ramkumar KN, Rajesh MR, Anuradha CV. 2003. Food restriction attenuates blood lipid peroxidation in carbon tetrachloride-intoxicated rats. Nutrition 19:358–362.12679172
*Rams JM, Pilgrim M, Rauth S, 1979. Level II materials balance: Carbon tetrachloride (draft report). Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
Ramsey JC, Andersen ME. 1984. A physiologically based description of the inhalation pharmacokinetics of styrene in rats and humans. Toxicol Appl Pharmacol 73:159–175.6710512
*Rao KS, Recknagel RO. 1968. Early onset of lipoperoxidation in rat liver after carbon tetrachloride administration. Exp Mol Pathol 9:271–278.4952076
*Rao KS, Recknagel RO. 1969. Early incorporation of carbon-labeled carbon tetrachloride into rat liver particulate lipids and proteins. Exp Mol Pathol 10:219–228.5777798
*Rao SB, Mehendale HM. 1989. Protective role of fructose 1,6-bisphosphate during carbon tetrachloride hepatoxicity in rats. Biochem J 262:721–725.2590162
*Rao VC, Mehendale HM. 1991. Colchincine antimitosis abolishes CCl_4_ autoprotection. Toxicol Pathol 19:179–606.
*Rao VC, Mehendale HM. 1993. Effect of antimitotic agent colchine on carbon tetrachloride toxicity. Arch Toxicol 67:392–400.8215908
*Rao PS, Dalu A, Kulkarni SG, 1996. Stimulated tissue repair prevents lethality in isopropanol-induced potentiation of carbon tetrachloride hepatotoxicity. Toxicol Appl Pharmacol 140:235–244.8887439
Rao PS, Mangipudy RS, Mehendale HM. 1997. Tissue injury and repair as parallel and opposing responses to CCl4 hepatotoxicity: A novel dose-response. Toxicology 118:181–193.9129172
Rao SB, Young RA, Mehendale HM. 1990. Perturbations in polyamines and related enzymes following chlordecone-potentiated bromotrichloromethane hepatotoxicity. J Biochem Toxicol 5:23–32.1698228
*Rasheed A, Hines RN, McCarver-May DG. 1997. Variation in induction of human placental CYP2E1: Possible role in susceptibility to fetal alcohol syndrome? Toxicol Appl Pharmacol 144:396–400.9194424
*Raucy JL, Kraner JC, Lasker JM. 1993. Bioactivation of halogenated hydrocarbons by cytochrome P4502E1. Crit Rev Toxicol 23(1):1–20.8471158
Ray P, Moore L. 1986. Carbon tetrachloride-induced release of calcium from isolated hepatocytes. Toxicology 41:205–212.3764942
*Ray SD, Mehendale HM. 1990. Potentiation of CCl_4_ and CHCl_3_ hepatotoxicity and lethality by various alcohols. Fundam Appl Toxicol 15:429–440.2258008
Raymer JH, Thomas KW, Cooper SD, 1990. A device for sampling of human alveolar breath for the measurement of expired volatile organic compounds. J Anal Toxicol 14:337–344.2128356
Raymond P, Plaa G. 1995a. Ketone potentiation of haloalkane-induced hepato- and nephrotoxicity. II. Implication of monooxygenases. J Toxicol Environ Health 46:317–328.7473860
*Raymond P, Plaa GL. 1995b. Ketone potentiation of haloalkane-induced hepato- and nephrotoxicity. I Dose-response relationships. J Toxicol Environ Health 45:465–480.7643433
Raymond P, Plaa GL. 1997. Effect of dosing vehicle on the hepatotoxicity of CCl4 and hepatotoxicity of CHCl3 in rats. J Toxicol Environ Health 51(5):463–476.9233380
*Recknagel RO. 1967. Carbon tetrachloride hepatotoxicity. Pharmacol Rev 19:145–208.4859860
*Recknagel RO, Ghoshal AK. 1966. Lipoperoxidation as a vector in carbon tetrachloride hepatotoxicity. Lab Invest 15:132–145.5951738
*Recknagel RO, Glende EA. 1973. Carbon tetrachloride hepatotoxicity: An example of lethal cleavage. CRC Crit Rev Toxicol 2:263–297.4357489
Recknagel RO, Glende EA, Dolak JA, 1989. Mechanisms of carbon tetrachloride toxicity. Pharmacol Ther 43:139–154.2675128
*Recknagel RO, Glende EA, Hriszkewycz AM. 1977. Chemical mechanisms in carbon tetrachloride toxicity. In: Pryor WA, ed. Free radicals in biology. Volume III. New York, NY: Academic Press, Inc.:97–132.
*Reinhardt CF, Azer A, Maxfield ME, 1971. Cardiac arrhythmias and aerosol sniffing. Arch Environ Health 22:265–279.5099701
*Reinke LA, Janzen EG. 1991. Detection of spin adducts in blood after administration of carbon tetrachloride to rats. Chem Biol Interact 78:155–165.1645621
*Reinke LA, Lai EK, McCay PB. 1988. Ethanol feeding stimulates trichloromethyl radical formation from carbon tetrachloride in liver. Xenobiotica 18(11):1311–1318.3245227
*Reinke LA, Towner RA, Janzen EG. 1992. Spin trapping of free radical metabolites of carbon tetrachloride in vitro and in vivo: Effect of acute ethanol administration. Toxicol Appl Pharmacol 112:17–23.1310168
Reiter R, Burk RF. 1988. Formation of glutathione adducts of carbon tetrachloride metabolites in a rat liver microsomal incubation system. Biochem Pharmacol 37:327–331.3342089
Reitz RH, Gargas ML, Mendrala AL, 1996. In vivo and in vitro studies of perchloroethylene metabolism for physiologically based pharmacokinetic modeling in rats, mice, and humans. Toxicol Appl Pharmacol 136:289–306.8619237
Reuber MD, Glover EL. 1967a. Cholangiofibrosis in the liver of buffalo strain rats injected with carbon tetrachloride. Br J Exp Pathol 48(3):319–322.6026971
*Reuber MD, Glover EL. 1967b. Hyperplastic and early neoplastic lesions of the liver in buffalo strain rats of various ages given subcutaneous carbon tetrachloride. J Natl Cancer Inst 38:891–899.6026105
*Reuber MD, Glover EL. 1970. Cirrhosis and carcinoma of the liver in male rats given subcutaneous carbon tetrachloride. J Natl Cancer Inst 44:419–427.11515084
Reviere R, Schneider S, Woolbright K. 1995. Associations between disease and occupation: Hypothesis generated from the national mortality followback survey. Am J Ind Med 27(2):195–205.7755010
Reynolds ES. 1967. Liver parenchymal cell injury. IV. Pattern of incorporation of carbon and chlorine from carbon tetrachloride into chemical constituents of liver in vivo. J Pharmacol Exp Therap 155:117–126.6017333
*Reynolds ES, Yee AG. 1968. Liver parenchymal cell injury. Part VI. Significance of early glucose-6-phosphatase suppression and transient calcium influx following poisoning. Lab Invest 19:273–281.
*Reynolds ES, Treinen RJ, Farrish HH. 1984. Metabolism of [^14^C]carbon tetrachloride to exhaled, excreted and bound metabolites. Biochem Pharmacol 33:3363–3374.6437407
*Rhoderick GC, Miller WR. 1990. Multipoint calibration of a gas chromatograph using cryogenic preconcentration of a single gas standard containing volatile organic compounds. Anal Chem 62:810–815.
*Rhodes VL, Kriek G, Lazear N, 2002. Development of emission factors for polycarbonate processing. J Air Waste Manage Assoc 52:781–788.
*RIDOH. 1989. Rhode Island Department of Health. Letter with accompanying data, from Bela T. Matyas (Chief, Office of Environmental Health Risk Assessment) to James Gibson (ATSDR), dated 3 March, 1989.
Rikans LE, DeCicco LA, Hornbrook KR, 1999. Effect of age and carbon tetrachloride on cytokine concentrations in rat liver. Mech Ageing Dev 108:173–182.10400310
Rinkus SJ, Legator MS. 1979. Chemical characterization of 465 known or suspected carcinogens and their correlation with mutagenic activity in the Salmonella typhimurium system. Cancer Res 39:3289–3318.383284
Rivera CA, Bradford BU, Hunt KJ, 2001. Attenuation of CCl_4_-induced hepatic fibrosis by GdCl_3_ treatment or dietary glycine. Am J Physiol Gastrointest Liver Physiol 281(1):G200–207.11408273
*Roberts SM, Harbison RD, James RC, 1994. Methamphetamine potentiation of carbon tetrachloride hepatotoxicity in mice. J Pharmacol Exp Ther 271(2):1051–1057.7965767
*Roberts SM, Harbison RD, James RC, 1995. Mechanistic studies on the potentiation of carbon tetrachloride hepatotoxicity by methamphetamine. Toxicology 97(1–3):49–57.7716792
*Robertson DG, Reily MD, Sigler RE, 2000. Metabonomics: Evaluation of nuclear magnetic resonance (NMR) and pattern recognition technology for rapid in vivo screening of liver and kidney toxicants. Toxicol Sci 57(2):326–337.11006362
*Rocchi P, Prodi G, Grilli S, 1973. In vivo and in vitro binding of carbon tetrachloride with nucleic acids and proteins in rat and mouse liver. Int J Cancer 11:419–425.4790700
Rockey DC, Chung JJ. 1997. Regulation of inducible nitric oxide synthase and nitric oxide during hepatic injury and fibrogenesis. Am J Physiol 273(1):G124–130.9252518
Rockey DC, Weisiger RA. 1996. Endothelin induced contractility of stellate cells from normal and cirrhotic rat liver: Implications for regulation of portal pressure and resistance. Hepatology 24:233–240.8707268
Roghani M, Da Silva C, Castagna M. 1987. Tumor promoter chloroform is a potent protein kinase C activator. Biochem Biophys Res Commun 142:738–744.3827900
*Roldan-Arjona T, Garcia-Pedrajas MD, Luque-Romero FL, 1991. An association between mutagenicity of the Ara test of Salmonella typhimurium and carcinogenicity in rodents for 16 halogenated aliphatic hydrocarbons. Mutagenesis 6:199–205.1881351
Rood AS, McGavran PD, Aanenson JW, 2001. Stochastic estimates of exposure and cancer risk from carbon tetrachloride released to the air from the Rocky Flats Plant. Risk Anal 21(4):675–695.11726020
Rosengren RJ, Sauer J-M, Hooser SB, 1995. The interactions between retinol and five different hepatotoxicants in the Swiss Webster Mouse. Fundam Appl Toxicol 25(281–292)
*Roudabush RL, Terhaar CJ, Fassett DW, 1965. Comparative acute effects of some chemicals on the skin of rabbits and guinea pigs. Toxicol Appl Pharmacol 7:559–565.5839391
*Rubin E, Lieber CS. 1968. Hepatic microsomal enzymes in man and rat: Induction and inhibition by ethanol. Science 162:690–691.5687818
*Rungby J, Ernst E. 1992. Experimentally induced lipid peroxidation after exposure to chromium, mercury or silver: Interactions with carbon tetrachloride. Pharmacol Toxicol 70:205–207.1579547
*Ruprah M, Mant TG K, Flanagan RJ. 1985. Acute carbon tetrachloride poisoning in 19 patients: Implications for diagnosis and treatment. Lancet I:1027:1029.
*Rush B, Merritt MV, Kaluzny M, 1986. Studies on the mechanism of the protective action of 16,16-dimethyl PGE2 in carbon tetrachloride induced acute hepatic injury in the rat. Prostaglandins 32:439–455.3786805
*Ruth JH. 1986. Odor thresholds and irritation levels of several chemical substances: A review. Am Ind Hyg Assoc J 47:142–151.
*Rutherford DW, Chiou CT. 1992. Effect of water saturation in soil organic matter on the partition of organic compounds. Environ Sci Tecnol 965–970.
*Rutherford DW, Chiou CT, Kile DE. 1992. Influence of soil organic matter composition on the partition of organic compounds. Environ Sci Technol 26:336–340.
*Sack TM, Steele DH, Hammerstrom K, 1992. A survey of household products for volatile organic compounds. Atmos Environ 6:1063–1070.
Saez JC, Bennett VL, Spray DC. 1987. Carbon tetrachloride at hepatotoxic levels blocks reversibly gap junctions between rat hepatocytes. Science 236:967–969.3576214
*Sagai M, Tappel AL. 1978. Effect of vitamin E on carbon tetrachloride-induced lipid peroxidation as demonstrated by in vivo pentane production. Toxicol Lett 2:149–155.
Sakai H, Tsukamoto T, Yamamoto M, 2000. Summation of initiation activities of low doses of teh non-hepatocarcinogen 1,2-dimethylhydrazine in the liver after carbon tetrachloride administration. Cancer Lett 148:59–63.10680593
*Sakata T, Watanabe A, Hobara N, 1987. Chronic liver injury in rats by carbon tetrachloride inhalation. Bull Environ Contam Toxicol 38:959–961.3580619
*Salgado S, Garcia J, Vera J, 2000. Liver cirrhosis is reverted by Urokinase-type plasminogen activator gene therapy. Mol Ther 2(6):545–551.11124055
Salie B, Matthes N, Knittel T, 1999. Transforming growth factor β and tumor necrosis factor α inhibit both apoptosis and proliferation of activated rat hepatic stellate cells. Hepatology 30:196–202.10385656
*Sanzgiri UY, Bruckner JV. 1997. Effect of emulphor, an emulsifier, on the pharmacokinetics and hepatotoxicity of oral carbon tetrachloride in the rat. Fundam Appl Toxicol 36(1):54–61.9073467
*Sanzgiri UY, Kim HJ, Muralidhara S, 1995. Effect of route and pattern of exposure on the pharmacokinetics and acute hepatotoxicity of carbon tetrachloride. Toxicol Appl Pharmacol 134:148–154.7676449
Sanzgiri UY, Muralidhara S, Bruckner JV. 1992. Correlation of tissue distribution and hepatoxicity of carbon tetrachloride (CCl4) following ingestion. Toxicologist 12:423.
*Sanzgiri UY, Srivattsan V, Muralidhara S, 1997. Uptake, distribution, and elimination of carbon tetrachloride in rat tissue following inhalation and ingestion exposures. Toxicol Appl Pharmacol 143:120–129.9073600
*Sasaki YF, Saga A, Akasaka M, 1998. Detection of in vivo genotoxcity of haloalkanes and haloalkenes carcinogenic to rodents by the alkaline single cell gel electrophoresis (comet) assay in multiple mouse organs. Mutat Res 419:13–20.9804871
*Sato A, Nakajima T. 1985. Enhanced metabolism of volatile hydrocarbons in rat liver following food deprivation, restricted carbohydrate intake, and administration of ethanol, phenobarbital, polychlorinated biphenyl and 3-methylcholanthrene: A comparative study. Xenobiotica 15(1):67–75.3920836
Sato A, Nakajima T. 1987. Pharmacokinetics of organic solvent vapors in relation to their toxicity. Scand J Work Environ Health 13:81–93.3299685
*Sato R, Maesawa C, Fujisawa K, 2004. Prevention of critical telomere shortening by oestradiol in human normal hepatic cultured cells and carbon tetrachloride induced rat liver fibrosis. Gut 53(7):1001–1009.15194652
Sato Y, Yoneda M, Nakamura K, 2003. Protective effect of central thyrotropin-releasing hormone on carbon tetrachloride-induced acute hepatocellular necrosis in rats. J Hepatol 39:47–54.12821043
Sawada S, Asakura S, Daimon H, 1995. Comparison of autoradiography, liquid scintillation counting and immunoenzymatic staining of 5-bromo-2'-deoxyuridine for measurement of unscheduled DNA synthesis and replicative DNA synthesis in rat liver. Mutat Res 344:109–116.7491128
*Sawada S, Yamanaka T, Yamatsu K, 1991. Chromosome aberrations, micronuclei and sister-chromatid exchanges (SCEs) in rat liver induced in vivo by hepatocarcinogens including heterocyclic amines. Mutat Res 251:59–69.1944376
*Sawant SP, Dnyanmote AV, Shankar K, 2004. Potentiation of carbon tetrachloride hepatotoxicity and lethality in type 2 diabetic rats. J Pharmacol Exp Ther 308(2):694–704.14610242
Scharf J-G, Dombrowski F, Novosyadlyy R, 2004. Insulin-like growth factor (IGF)-binding protein-1 is highly induced during acute carbon tetrachloride liver injury and potentiates the IGF-I-stimulated activation of rat hepatic stellate cells. Endocrinology 145(7):3463–3472.15070850
*Schiestl RH, Gietz RD, Mehta RD, 1989. Carcinogens induce intrachromosomal recombination in yeast. Carcinogenesis 10:1445–1446.2665967
Schoeffner DJ, Warren DA, Muralidhara S, 1999. Organ weights and fat volume in rats as a function of strain and age. J Toxicol Environ Health A 56:449–462.10201633
Schuetzie D, Crittenden AJ, Charison RJ. 1973. Application of computer controlled high resolution mass spectrometry to the analysis of air pollutants. J Air Pollut Control Assoc 23:704–709.
Schultz VD, Esposti SD, Panzica MA, 1997. Expression of TA1, a rat oncofetal cDNA with homology to transport-associated genes, in carbon-tetrachloride-induced liver injury. Pathobiology 65:14–25.9200186
*Schwarz M, Hummel J, Appel KE, 1979. DNA damage induced in vivo evaluated with a nonradioactive alkaline elution technique. Cancer Lett 6:221–226.35281
*Schwetz BA, Ledwig BKJ, Gehring PJ. 1974a. Embryo- and fetotoxicity of inhaled chloroform in rats. Toxicol Appl Pharmacol 28:442–451.4851839
*Schwetz BA, Leong BK J, Gehring PJ. 1974b. Embryo- and fetotoxicity of inhaled carbon tetrachloride, l,l-dichloroethane and methyl ethyl ketone in rats. Toxicol Appl Pharmacol 28:452–64.4851838
*Seawright AA, McLean AE M. 1967. The effect of diet on carbon tetrachloride metabolism. Biochem J 105:1055–1060.16742530
*Seawright AA, Wilkie IW, Costigan P, 1980. The effect of an equimolar mixture of carbon tetrachloride and carbon disulphide on the liver of the rat. Biochem Pharmacol 29:1007–1014.7387717
*Seidler A, Raum E, Arabin B, 1999. Maternal occupational exposure to chemical substances and the risk of infants small-for-gestational-age. Am J Ind Med 36(1):213–222.10361609
Sein KT, Chu N. 1979. Liver and kidney glucose-6-phosphatase levels in carbon tetrachloride- and PDT- administered mice. Enzyme 24:72–74.220042
*Seki M, Kasama K, Imai K. 2000. Effect of food restriction on hepatotoxicity of carbon tetrachloride in rats. J Toxicol Sci 25(1):33–40.
Selan FM, Evans MA. 1987. The role of microtubules in chlorinated alkane-induced fatty liver. Toxicol Lett 36:117–127.3576642
*Selden JR, Dolbeare F, Miller JE, 1994. Validation of a flow cytometric in vitro DNA repair (UDS) assay in rat heptocytes. Mutat Res 315(2):147–167.7520997
Semino G, Lilly P, Andersen ME. 1997. A pharmacokinetic model describing pulsatile uptake of orally-administered carbon tetrachloride. Toxicology 117:25–33.9020196
Semprini L. 1995. In situ bioremediation of chlorinated solvents. Environ Health Perspect Suppl 103:101–105.
*Sentjurc M, Mason RP. 1992. Inhibition of radical adduct reduction and reoxidation of the corresponding hydroxylamines in in vivo spin trapping of carbon tetrachloride-derived radicals. Free Radical Biology Medicine 13:151–160.1325396
*Setchell BP, Waites GM H. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
*Shah JJ, Heyerdahl EK. 1988. National ambient volatile organic compounds (VOCs) data base update. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. PB88–195631.
*Shah JJ, Singh HB. 1988. Distribution of volatile organic chemicals in outdoor and indoor air. Environ Sci Technol 22:1381–1388.22200458
*Shah H, Hartman SP, Weinhouse S. 1979. Formation of carbonyl chloride in carbon tetrachloride metabolism by rat liver in vitro. Cancer Res 39:3942–3947.476631
*Shamberger RJ, Andreone TL, Willis CE. 1974. Antioxidants and cancer. IV. Initiating activity of malonaldehyde as a carcinogen. J Natl Cancer Inst 53:1771–1773.4436871
Shankar K, Vaidya VS, Apte UM, 2003. Type 1 diabetic mice are protected from acetaminophen hepatotoxicity. Toxicol Sci 73:220–234.12700423
*Shara MA, Dickson PH, Bagchi D, 1992. Excretion of formaldehyde, malondialdehyde, acetaldehyde and acetone in the urine of rats in response to 2,3,7,8-tetrachlorodibenzo-p-dioxin, paraquat, endrin and carbon tetrachloride. J Chromatogr Biomed Appl 576:221–233.
*Shen ES, Garry VF, Anders MW. 1982. Effect of hypoxia on carbon tetrachloride hepatotoxicity. Biochem Pharmacol 31(23):3787–3793.7159461
*Shertzer HG, Sainsbury M. 1991. Chemoprotective and hepatic enzyme induction properties of indole and indenoindole antioxidants in rats. Food Chem Toxicol 29:391–400.1874467
Shertzer HG, Niemi MP, Reitman FA, 1987. Protection against carbon tetrachloride hepatotoxicity by pre-treatment with indo1–3-carbinol. Exper Mol Pathol 46:180–189.3556531
Shertzer HG, Reitman FA, Tabor MW. 1988. Influence of diet on the expression of hepatotoxicity from carbon tetrachloride in ICR mice. Drug Nutr Interact 5:275–282.3240710
Shi J, Aisaki K, Ikawa Y, 1998. Evidence of hepatocyte apoptosis in rat liver after the administration of carbon tetrachloride. Am J Pathol 153(2):515–525.9708811
Shibayama Y. 1988. On the pathogenesis of portal hypertension in cirrhosis of the liver. Liver 8:95–99.3367713
Shimizu Y, Nagase C, Kawai K. 1973. Accumulation and toxicity of carbon tetrachloride after repeated inhalation in rats. Ind Health 11:48–54.
Shimizu H, Uetsuka K, Nakayama H, 2001. Carbon tetrachloride-induced acute liver injury in Mini and Wistar rats. Exp Toxicol Pathol 53(1):11–17.11370728
Shindell S, Ulrich S. 1985. A cohort study of employees of a manufacturing plant using trichloroethylene. J Occup Med 27:577–579.4032094
*Short CL, Kinden DA, Stith R. 1976. Fetal and neonatal development of the microsomal monooxygenase system. Drug Metab Rev 5:1–42.
Siegers CP, Horn W, Younes M. 1985. Effect of hypoxia on the metabolism and hepatotoxicity of carbon tetrachloride and vinylidene chloride in rats. Acta Pharmacol Toxicol 56:81–86.
Simeonova PP, Gallucci RM, Hulderman T, 2001. The role of tumor necrosis factor-α in liver toxicity, inflammation, and fibrosis induced by carbon tetrachloride. Toxicol Appl Pharmacol 177:112–120.11740910
*Simko V, Michael S, Katz J, 1992. Protective effect of oral acetylcysteine against the hepatorenal toxicity of carbon tetrachloride potentiated by ethyl alcohol. Alcohol Clin Exp Res 16:795–799.1530143
*Simmon VF, Kavhanen K, Tardiff RG. 1977. Mutagenic activity of chemicals identified in drinking water. In: Scott D, Bridges BA, Sobesl FH, eds. Progress in genetic toxicology. New York: Elsevier/North-Holland Biomedical Press, 249–258.
*Simmonds PG, Alyea FN, Cardelino CA, 1983. The atmospheric lifetime experiment. 6. Results for carbon tetrachloride based on 3 years data. J Geophys Res 88:8427–8441.
*Simmonds PG, Cunnold DM, Alyea FN, 1988. Carbon tetrachloride lifetimes and emissions determined from daily global measurements during 1978–1985. J Atmospheric Chem 7:35–58.
*Simon M-F, Chap H, Douste-Blazy L. 1986. Selective inhibition of human platelet phosphilipase A_2_ by buffering cytoplasmic calcium with the flourescent indicator quin 2. Evidence for different calcium sensitive of phospolipases A2 and C. Biochim Biophys Acta 875:157–164.3080024
*Sina JF, Bean CL, Dysart GR, 1983. Evaluation of the alkaline elution/rat hepatocyte assay as a predictor of carcinogenic/mutagenic potential. Mutat Res 113:357–391.6877265
Singh HB, Fowler DP, Peyton TO. 1976. Atmospheric carbon tetrachloride: Another man-made pollutant. Science 192:1231–1234.17771757
*Singh HB, Lillian D, Appleby A, 1975. Atmospheric formation of carbon tetrachloride from tetrachloroethylene. Environ Lett 10:253–256.1213012
*Singh HB, Salas LJ, Cavanagh LA. 1977. Distribution, sources and sinks of atmospheric halogenated compounds. Air Pollut Cont 27:332–338.
*Singh HB, Salas LJ, Shigeishi H, 1979a. Atmospheric distributions, sources and sinks of selected halocarbons, hydrocarbons, SF_6_ and N_2_O. Draft final report. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development.
Singh HB, Salas LJ, Smith A, 1979b. Atmospheric measurements of selected toxic organic chemicals. Research Triangle Park, NC: U.S. Environmental Protection Agency, Atmospheric Chemistry and Physics Department, Environmental Sciences Research Laboratory.
*Singh HB, Salas LJ, Smith A, 1980. Measurements of some potentially hazardous organic chemicals in urban environments. Atmos Environ 15:601–612.
*Singh HB, Salas L, Viezee W, 1992. Measurement of volatile organic chemicals at selected sites in California. Atmos Environ 16:2929–2946.
Sipes IG, El Sisi AE, Sim WW, 1991. Reactive oxygen species in the progression of CCl_4_-induced liver injury. In: Biol Reactive Intermediates IV. New York, NY: Plenum Press, 489–497.
*Sipes IG, Krishna G, Gillette JR. 1977. Bioactivation of carbon tetrachloride, chloroform and bromotrichloromethane: Role of cytochrome P-450. Life Sci 20:1541–1548.17803
*Sirota JH. 1949. Carbon tetrachloride poisoning in man. I. The mechanism of renal failure and recovery. J Clin Invest 28:1412–1422.15395944
*Sivikova K, Piesova E, Dianovsky J. 2001. The protection of vitamin E and selenium against carbon tetrachloride-induced genotoxicity in ovine peripheral blood lymphocytes. Mutat Res 494:135–142.11423352
Skrzypinska-Gawrysiak M, Piotrowski JK, Sporny S. 2000. Circadian variations in hepatotoxicity of carbon tetrachloride in mice. Int J Occup Med Environ Health 13(2):165–173.10967846
*Slater TF. 1981. Free radicals as reactive intermediates in tissue injury. Adv Exp Med Biol 136(Part A):575–589.7344480
Slater TF. 1982. Activation of carbon tetrachloride: Chemical principles and biological significance. In: Slater TF, McBrien DCH, eds. Free radicals, lipid peroxidation and cancer. New York: Academy Press, 243–274.
Slater RW, Ho JS. 1989. Method 502.2. Volatile organic compounds in water by purge and trap capillary column gas chromatography with photoionization and electrolytic conductivity detectors in series. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development.
*Slater TF, Sawyer BC. 1970. The hepatotoxic action of carbon tetrachloride stimulatory effect of carbon tetrachloride on lipid peroxidation in microsomal suspenions. FEBS Lett 11(2):132–136.11945468
*Slater TF, Cheeseman KH, Davies MJ, 1987. Symposium on 'Nutritional Aspects of Free Radicals': Free radical mechanisms in relation to tissue injury. Proc Nutr Soc 46:1–12.3033678
Slater TF, Cheeseman KH, Ingold KU. 1985. Carbon tetrachloride toxicity as a model for studying free-radical mediated liver injury. Philos Trans R Soc Lond [Biol] 311:633–645.
*Smetana J. 1939. Nephrosis due to carbon tetrachloride. Arch Intern Med 63:760–777.
*Smialowicz RJ, Simmons JE, Luebke RW, 1991. Immunotoxicologic assessment of subacute exposure of rats to carbon tetrachloride with comparison to hepatotoxicity and nephrotoxicity. Fundam Appl Toxicol 17:186–196.1833255
Smyth HF. 1935. Carbon tetrachloride in industry-the present status and plans for further necessary studies. Ind Med 4:12–15.
*Smyth HF, Smyth HF Jr., Carpenter CP. 1936. The chronic toxicity of carbon tetrachloride; animal exposure and field studies. J Ind Hyg Toxicol 18:277–298.
Sogawa S, Nihro Y, Ueda H, 1994. Protective effects of hydroxychalcones on free radical-induced cell damage. Biol Pharm Bull 17(2):251–256.8205123
Song I-M, Lee Y-M, Chung S-J, 2003. Multiple alterations on canalicular membrane transport activities in rats with CCL4-induced hepatic injury. Drug Metab Dispos 31(4):482–490.12642476
Soni MG, Mehendale HM. 1991. Protection from chlordecone-amplified carbon tetrachloride toxicity by cyanidanol: Biochemical and histological studies. Toxicol Appl Pharmacol 108:46–57.1706539
*Soni MG, Mehendale HM. 1993. Hepatic failure leads to lethality of chlordecone-amplified hepatotoxicity of carbon tetrachloride. Fundam Appl Toxicol 21:442–450.7504640
Sonich C, Kraemer DF, Lucas JB. 1980. An epidemiolologic study of acute effects of a low level exposure to carbon tetrachloride (CCl_4_). Am J Epidemiol 112(3):445.
Spicer CW, Buxton BE, Holdren MW, 1996. Variability of hazardous air pollutants in an urban area. Atmos Environ 30(20):3443–3456.
*Spirtas R, Stewart PA, Lee JS, 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility. I. Epidemiological results. Br J Ind Med 48:515–530.1878308
*SRI. 2004. Directory of chemical producers. Menlo Park, CA: SRI Consulting, 408, 409, 501.
*Srivastava SP, Chen NQ, Holtzman JL. 1990. The in vitro NADPH-dependent inhibition by CCl_4_ of the ATP-dependent calcium uptake of hepatic microsomes from male rats. J Biol Chem 265:8392–8399.2140358
*Staples CA, Werner F, Hooghemm TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
*Steup DR, Hall P, McMillan DA, 1993. Time course of hepatic injury and recovery following coadministration of carbon tetrachloride and trichloroethylene in Fischer-344 Rats. Toxicol Pathol 21:327–334.8248722
Steup DR, Wiersma D, McMillian DA, 1991. Pretreatment with drinking water solutions containing trichloroethylene or chloroform enhances the hepatoxicity of carbon tetrachloride in Fischer 344 rats. Fundam Appl Toxicol 16:798–809.1884917
*Stevens H, Forster FM. 1953. Effect of carbon tetrachloride on the nervous system. Arch Neurol Psychiat 70:635–649.13091512
*Stewart BW. 1981. Generation and persistence of carcinogen-induced repair intermediates in rat liver DNA in vivo. Cancer Res 41:3238–3243.7248978
*Stewart A, Witts LJ. 1944. Chronic carbon tetrachloride intoxication. Br J Ind Med 1:11–19.
Stewart PA, Lee JS, Marano DE, 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility. II. Exposures and their assessment. Br J Ind Med 48:531–537.1878309
*Stewart RD, Dodd HC. 1964. Absorption of carbon tetrachloride, trichloroethylene, tetrachloroethylene, methylene chloride and l,l,l-trichloroethane through the human skin. Am Ind Hyg Assoc J 25:439–446.14209666
*Stewart RD, Boettner EA, Southworth RR, 1963. Acute carbon tetrachloride intoxication. J Am Med Assoc 183:94–97.
*Stewart RD, Dodd HC, Erley DS, 1965. Diagnosis of solvent poisoning. J Am Med Assoc 193:115–118.
*Stewart RD, Gay HH, Erley DS, 1961. Human exposure to carbon tetrachloride vapor. J Occup Expos 3:586–590.
Stoyanovsky DA, Cederbaum AI. 1996. Thiol oxidation and cytochrome P450-dependent metabolism of CCl4 triggers Ca^2+^ release from liver microsomes. Biochemistry 35(49):15839–15845.8961948
Stoyanovsky DA, Cederbaum AI. 1999. Metabolism of carbon tetrachloride to trichloromethyl radical: An ESR and HPLC-EC study. Chem Res Toxicol 12:730–736.10458707
*Straus B. 1954. Aplastic anemia following exposure to carbon tetrachloride. J Am Med Assoc 155:737–739.13162791
*Streetz KL, Tacke F, Leifeld L, 2003. Interleukin 6/gp130-dependent pathways are protective during chronic liver diseases. Hepatology 38(1):218–229.12830005
*Striker GE, Smuckler EA, Kohnen PW, 1968. Structural and functional changes in rat kidney during CCl_4_ intoxication. Am J Pathol 53:769–789.4300891
*Strubelt O. 1984. Alcohol potentiation of liver injury. Fundam Appl Toxicol 4:144–151.6724189
Suda H, Masui T, Ikawa E, 1987. Compared promoting potential of D-galactosamine, carbon tetrachloride and partial hepatectomy in rapid induction of preneoplastic liver lesions in the rat. Cancer Lett 37:163–171.3677052
*Suh JH, Shenvi SV, Dixon BM, 2004. Decline in transcriptional activity of Nrf2 causes age-related loss of glutathione synthesis, which is reversible with lipoic acid. Proc Natl Acad Sci U S A 101(10):3381–3386.14985508
*Suitheimer C, Bost R, Sunshine I. 1982. Volatiles by headspace chromatography. In: Sunshine I, Jatlow PI, eds. Methodology for analytical technology. Volume II. Boca Raton, FL: CRC Press Inc., 1–9.
Summerhays J. 1991. Evaluation of risks from urban air pollutants in the Southeast Chicago area. J Air Waste Manage Assoc 41:844–850.1910752
*Sundari PN, Wilfred G, Ramakrishna B. 1997. Does oxidative protein damage play a role in the pathogenesis of carbon tetrachloride-induced liver injury in the rat? Biochim Biophys Acta 1362(2–3):169–176.9540847
Suntres ZE, Lui EM. 1990. Biochemical mechanism of metallothionein-carbon tetrachloride interaction in vitro. Biochem Pharmacol 39:833–840.2310409
*Suzuki H, Hirano N, Watanabe C, 1997. Carbon tetrachloride does not induce micronucleus in either mouse bone marrow or peripheral blood. Mutat Res 394(1–3):77–80.9434846
*Svirbely JL, Highman B, Alford WC, 1947. The toxicity and narcotic action of monochloromonobromomethane with special reference to inorganic and volatile bromide in blood, urine and brain. J Indust Hyg 29:382–389.20271003
*Sweet CW, Vermette SJ. 1990. Monitoring toxic VOCs in urban air in Illinois. U.S. Environmental Protection Agency. Research Triangle Institute; Proceedings of the 1990 EPA/AWMA International Symposium. EPA600990026. PB91120279, 536–540
*Sweet CW, Vermette SJ. 1992. Toxic volatile organic compounds in urban air in Illinois. Environ Sci Technol 26:165–173.
Symons JM, Bellar TA, Carswell JK, 1975. National organics reconnaissance survey for halogenated organics. J Am Water Works Assoc 67:634–647.
*Tabak HH, Quave SA, Mashni CI, 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
*Tafazoli M, Baeten A, Geerlings P, 1998. In vitro mutagenicity and genotoxicity study of a number of short-chain chlorinated hydrocarbons using the micronucleus test and the alkaline single cell gel electrophoresis technique (Comet assay) in human lymphocytes: A structure-activity relationship (QSAR) analysis of the genotoxic and cytotoxic potential. Mutagenesis 13(2):115–126.9568582
*Tajima S, Nishimura N, Ito K. 1985. Suppression of delayed-type hypersensitivity mediated by macrophage-like cells in mice with experimental liver injury. Immunology 54:57–64.2982732
Takei N, Watanabe A, Sakata T, 1983. Brain tyrosine hydroxylase activity and calculated amount of brain dopa synthesized in carbon tetrachloride-intoxicated rats. Gastroenterol Jpn 18(1):11–14.6131851
*Takizawa S, Watanabe H, Naito Y, 1975. Preparative action of carbon tetrachloride in liver tumorigenesis by a single application of n-butylnitrosourea in male ICR/JCL strain mice. Gann 66:603–614.178559
Tanaka E. 1997. Short communication: Simultaneous determination of carbamazepine and its metabolites in plasma from carbon tetrachloride-intoxicated rats using a new reversed-phase chromatographic column of 2-um porous microspherical silica gel. J Chromatogr B Biomed Sci Appl 688(1):155–160.9029326
*Tanaka E. 1998. In vivo age-related changes in hepatic drug-oxidizing capacity in humans. J Clin Pharm Ther 23:247–255.9867310
Tanaka E, Sakamoto N, Inubushi M, 1995. Short communication simultaneous determination of plasma phenytoin and its primary hydroxylated metabolites in carbon tetrachloride-intoxicated rats by high-performance liquid chromatography. J Chromatogr B Biomed Appl 673(1):147–151.8925069
Tanaka S, Tsurukami H, Sakai A, 2003. Effects of 1,25(OH)_2_D_3_ on turnover, mineralization, and strength of bone in growing rats with liver cirrhosis induced by administration of carbon tetrachloride. Bone 32:275–283.12667555
*Tancrede M, Yanagisawa Y, Wilson R. 1992. Volatilization of volatile organic compounds from showers - I. Analytical method and quantitative assessment. Atmos Environ 26a:1103–1111.
Tang N. 1987. DDT and ethanol potentiation of the hepatotoxicity of carbon tetrachloride. Chin J Prev Med 21:196–198.
Tanka E. 2001. Chlorzoxazone: A probe drug the metabolism of which can be used to monitor one-point blood sampling in the carbon tetrachloride -intoxicated rat. Hum Exp Toxicol 20:381–385.11727787
*Taylor HF. 1925. A case of hypersensitiveness to carbon tetrachloride. J Am Med Assoc 84:280.
*Taylor SL, Tappel AL. 1976. Effect of dietary antioxidants and phenobarbital pretreatment on microsomal lipid peroxidation and activation by carbon tetrachloride. J Life Sci 19:1151–1160.
*Teschke R, Vierke W, Goldermann L. 1983. Carbon tetrachloride (CCl_4_) levels and serum activities of liver enzymes following activities CCl_4_ intoxication. Toxicol Lett 17:175–180.6623503
Teschke R, Vierke W, Gellert J. 1984. Effect of ethanol on carbon tetrachloride levels and hepatotoxicity after acute carbon tetrachloride poisoning. Arch Toxicol 56:78–82.6532381
Teta MJ, Ott MG. 1988. A mortality study of a research, engineering, and metal fabrication facility in Western New York State. Am J Epidemiol 127:540–551.3341358
*Tezuka M, Ishii S, Okada S. 1991a. Chromium (III) decreases carbon tetrachloride-originated trichloromethyl radical in mice. J Inorganic Biochem 44:261–265.
*Tezuka M, Momiyama K, Edano T, 1991b. Protective effect of chromium(III) on acute lethal toxicity of carbon tetrachloride in rats and mice. J Inorganic Biochem 42:1–8.
*Thakore KN, Mehendale HM. 1991. Role of hepatocellular regeneration in CCl_4_ autoprotection. Toxicol Pathol 19:47–58.2047707
Theocharis SE, Kanelli H, Margeli AP. 2000. Metallothionein and heat shock protein expression during acute liver injury and regeneration in rats. Clin Chem Lab Med 38(11):1137–1140.11156344
Theocharis SE, Margeli AP, Skaltsas SD, 2001. Induction of metallothionein in the liver of carbon tetrachloride intoxicated rats: An immunohistochemical study. Toxicology 161:129–138.11295262
*Thirunavukkarasu C, Yang Y, Subbotin VM, 2004. Endothelin receptor antagonist TAK-044 arrests and reverses the development of carbon tetrachloride induced cirrhosis in rats. Gut 53:1010–1019.15194653
Thomas MJ. 1995. The role of free radicals and antioxidents: How do we know that they are working? Crit Rev Food Sci Nutr 35:21–39.7748477
Thomas CE, Aust SD. 1986. Free radicals and environmental toxins. Ann Emerg Med 15:1075–1083.3526996
Thomas KW, Pellizzari ED, Cooper SD. 1991. A canister-based method for collection and GC/MS analysis of volatile organic compounds in human breath. J Anal Toxicol 15:54–59.2051745
Thrall KD, Kenny DV. 1996. Evaluation of a carbon tetrachloride physiologically based pharmacokinetic model using real-time breath-analysis monitoring of the rat. Inhal Toxicol 8:251–261.
*Thrall KD, Vucelick ME, Gies RA, 2000. Comparative metabolism of carbon tetrachloride in rats, mice, and hamsters using gas uptake and PBPK modeling. J Toxicol Environ Health A 60:531–548.10983521
*Tian L, Cai Q, Wei H. 1998. Alterations of antioxidant enzymes and oxidative damage to macromolecules in different organs of rats during aging. Free Radic Biol Med 24(9):1477–1484.9641266
Tomasi A, Albano E, Banni S, 1987. Free-radical metabolism of carbon tetrachloride in rat liver mitochondria. A study of the mechanism of action. Biochem J 246:313–317.2825631
*Tomenson JA, Baron CE, O'Sullivan J, 1995. Hepatic function in workers occupationally exposed to carbon tetrachloride. Occup Environ Med 52:508–514.7663635
*Topham JC. 1980. Do induced sperm-head abnormalities in mice specifically identify mammalian mutagens rather than carcinogens? Mutat Res 74:379–387.7207475
Tortoriello PJ, Riebow JF, Advani S, 1991. The anomaly of pyridine nucleotide synergism in carbon tetrachloride metabolism. Free Radic Biol Med 10:387–396.1654287
*Towner RA, Reinke LA, Janzen EG, 1991. Enhancement of carbon tetrachloride-induced liver injury by a single dose of ethanol: Proton magnetic resonance imaging (MRI) studies in vivo. Acta Biochem Biophys 1096:222–230.
Towner RA, Reinke LA, Janzen EG, 1994. In vivo magnetic resonance imaging study of Kupffer cell involvement in CCl_4_-induced hepatotoxicity. Can J Physiol Pharmacol 72(5):441–446.7954070
*Tracey JP, Sherlock P. 1968. Hepatoma following carbon tetrachloride poisoning. NYJ Med 68:2202–2204.
*Traiger GJ, Bruckner JV. 1976. The participation of 2-butanone in 2-butanol-induced potentiation of carbon tetrachloride hepatotoxicity. J Pharmacol Exp Therap 196:493–500.1255493
*Traiger GJ, Plaa GL. 1971. Differences in the potentiation of carbon tetrachloride in rats by ethanol and isopropanol pretreatment. Toxicol Appl Pharmacol 20:105–112.4329357
Traiger GJ, Bruckner JV, Jiang WD, 1989. Effect of 2-butanol and 2-butanone on rat hepatic ultrastructure and drug metabolizing enzyme activity. J Toxicol Environ Health 28:235–248.2507790
*Tribble DL, Aw TY, Jones DP. 1987. The pathophysiological significance of lipid peroxidation in oxidative cell injury. Hepatology 7(2):377–387.3549510
TRI02. 2004. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. December 23, 2004.
Triger DR, Wright R. 1973. Studies on hepatic uptake of antigen. II. The effect of hepatotoxins on the immune response. Immunology 25:951–956.4759564
*Tsuda H, Masui T, Ikawa E, 1987. Compared promoting potential of d-galactosamine, carbon tetrachloride and partial hepatectomy in rapid induction of preneoplastic liver lesions in the rat. Cancer Lett 37:163–171.3677052
*Tsuruta H. 1975. Percutaneous absorption of organic solvents. Comparative study of the in vivo percutaneous absorption of chlorinated solvents in mice. Industrial Health 13:227–236.
*Uehleke H, Hellmer KH, Tabarelli S. 1973. Binding of 14C-carbon tetrachloride to microsomal proteins in vitro and formation of CHC13 by reduced liver microsomes. Xenobiotica 3:1–11.4144825
*Uehleke H, Werner T, Greim H, 1977. Metabolic activation of haloalkanes and tests in vitro for mutagenicity. Xenobiotica 7:393–400.329590
*Uemitsu N. 1986. Inhalation pharmacokinetics of carbon tetrachloride in rats based on arterial blood: Inhaled air concentration ratios. Toxicol Appl Pharmacol 83:20–29.3952748
Uemitsu N, Nishimura C, Nakayoshi H. 1986. Evaluation of liver weight changes following repeated administration of carbon tetrachloride in rats and body-liver weight relationship. Toxicology 40:181–190.3726893
*Umiker W, Pearce J. 1953. Nature and genesis of pulmonary alterations in carbon tetrachloride poisoning. Arch Pathol 55:203–217.
Uryvaeva IV, Delone GV. 1995. An improved method of mouse liver micronucleus analysis: An application to age-related genetic alteration and polyploidy study. Mutat Res 334(1):71–80.7528339
*USC. 2003. Hazardous air pollutants. Washington, DC: United States Code. 42 USC 7412. http://www4.law.cornell.edu/uscode/. June 6, 2003.
*USITC. 1986. Synthetic organic chemicals. United States production and sales. 1986. Washington, DC: U.S. International Trade Commission, publication 2009, 212.
*USITC. 1991. Synthetic organic chemicals. United States production and sales. 1990. Washington, DC: U.S. International Trade Commission, publication 2470, 15–8, 15–30.
*USITC. 2002. Synthetic organic chemicals. United States production and sales. Washington, DC: U.S. International Trade Commission.
*USITC. 2003. Synthetic organic chemicals. United States production and sales. Washington, DC: U.S. International Trade Commission.
Valdivia E, Sonnad J. 1966. Fatty change of the granular preumocyte in carbon tetrachloride intoxication. Arch Pathol 81:514–519.5934084
Van de Casteele M, van Pelt JF, Nevens F, 2003. Low NO biovailability in CCl_4_ cirrhotic rat livers might result from low NO synthesis combined with decreased superoxide dismutase activity allowing superoxide-mediated NO breakdown: A comparison of two portal hypertensive rat models with healthy controls. Comp Hepatol 2(1):2.12575897
*van den Bosch H, Aarsman AJ, van Schaik RH N, 1990. Structural and enzymological properties of cellular phospholipases A2. Biochem Soc Trans 18:781–785.2083674
van Kuijk FJGM, Sevanian A, Handelman GJ, 1987. A new role for phospholipase A_2_: Protection of membranes from lipid peroxidation damage. Trends Biochem Sci 12:31–34.
Vannelli T, Logan M, Arciero DM, 1990. Degradation of halogenated aliphatic compounds by the ammonia-oxidizing bacterium nitrosomonas europaea. Appl Environ Microbiol 56:1169–1171.2339874
Van Stee EW, Boorman GA, Moorman MP, 1982. Time-varying concentration profile as a determinant of the inhalation toxicity of carbon tetrachloride. J Toxicol Environ Health 10:785–795.7161828
*Varma MM, Ampy FR, Verma K, 1988. In vitro mutagenicity of water contaminants in complex mixtures. J Appl Toxicol 8(4):243–248.3183290
*Vazquez C, Bujan J, Vallejo D. 1990. Blood coagulation variations induced by carbon tetrachloride inhalation in Wistar rats. Toxicol Appl Pharmacol 103:206–213.2330584
Veng-Pedersen P, Paustenback DJ, Carlson GP, 1987. A linear systems approach to analyzing the pharmacokinetics of carbon tetrachloride in the rat following repeated exposures of 8 and 11.5 h/day. Arch Toxicol 60:355–364.3117018
*Verschueren K. 1983. Handbook of environmental data on organic chemicals. New York: Van Nostrand Reinhold Company.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
*Villarruel MdC, de Toranzo EGD, Castro JA. 1977. Carbon tetrachloride activation, lipid peroxidation, and the mixed function oxygenase activity of various rat tissues. Toxicol Appl Pharmacol 41:337–344.408943
Villarruel MC, Fernandez G, Aguilar EG, 1987. Early biochemical alternations in liver mitochondria from carbon tetrachloride poisoned rats. J Appl Toxicol 7:173–177.3624775
*Vittozzi L, Nastainczyk W. 1987. Binding of reactive metabolites of CCl4 to specific microsomal proteins. Biochem Pharmacol 36:1401–1406.3579981
Vohra BP S, Hui X. 2001. Taurine protects against carbon tetrachloride toxicity in the cultured neurons and in vivo Arch Physiol Biochem 109(1):90–94.11471076
*Volkering F, Breure AM, Rulkens WH, 1998. Microbiological aspects of surfactant use for biological soil remediation. Biodegradation 8(6):410–417.
*von Oettingen WF. 1964. The halogenated hydrocarbons of industrial and toxicological importance. In: Browning E, ed. Elsevier monographs on toxic agents. New York, NY: Elsevier Publishing Co.
*von Oettingen WF, Powell CC, Sharpless NE, 1949. Relation between the toxic action of chlorinated methanes and their chemical and physicochemical properties. National Inst Health Bull No. 191.
von Oettingen WF, Powell CC, Sharpless NE, 1950. Comparative studies of the toxicity and pharmacodynamic action of chlorinated methanes with special reference to their physical and chemical characteristics. Arch Int Pharmacodyn 81:17–34.15399270
*Wacker M, Wanek P, Eder E. 2001. Detection of 1, N2-propanodeoxyguanosine adducts of trans-4-hydroxy-2-nonenal after gavage of trans-4-hydroxy-2-nonenal or induction of lipid peroxidation with carbon tetrachloride in F344 rats. Chem Biol Interact 137:269–283.11566294
Wackett LP, Logan M, Blocki F 1992. A mechanistic perspective on bacterial metabolism of chlorinated methanes. Biodegradation 3:19–36.
*Wahlberg JE, Boman A. 1979. Comparative percutaneous toxicity of ten industrial solvents in the guinea pig. Scand J Work Environ Health 5:345–351.538425
Walker BL, Cooper CD. 1992. Air pollution emission factors for medical waste incinerators. J Air Waste Manage Assoc 42:784–791.
*Wallace LA. 1986. Personal exposures, indoor and outdoor air concentrations and exhaled breath concentrations of selected volatile organic compounds measured for 600 residents of New Jersey, North Dakota, North Carolina and California. Toxicol Environ Chem 12:215–236.
*Wallace LA. 1991. Comparison of risks from outdoor and indoor exposure to toxic chemicals. Environ Health Perspect 95:7–13.1821381
*Wallace L, Buckley T, Pellizzar IE, 1996. Breath measurements as volatile organic compounds biomarkers. Environ Health Perspect 104:861–869.8933027
Wallace LA, Pellizzari ED, Hartwell TD, 1989. The influence of personal activities on exposure to volatile organic compounds. Environ Res 50:37–55.2792060
*Wallace LA, Pellizzari ED, Leaderer B, 1987. Emissions of volatile organic compounds from building materials and consumer products. Atmos Environ 21:385–393.
*Waller RL, Glende EA Jr., Recknagel RO. 1983. Carbon tetrachloride and bromotrichloromethane toxicity. Biochem Pharmacol 32:1613–1617.6860348
*Walters SM. 1986. Cleanup of samples. In: Zweig G, Shema J, eds. Analytical methods for pesticides and plant growth regulators. New York, NY: Academic Press, 67–110.
*Walton BT, Hendricks MS, Anderson TA, 1992. Soil sorption of volatile and semivolatile organic compounds in a mixture. J Environ Qual 21:552–558.
Wang B, Gao Z, Zou Q 2003. Quantitative diagnosis of fatty liver with dual-energy CT. Acta Radiol 44:92–97 12631006
Wang D-H, Ishii K, Zhen L-X, 1996. Enhanced liver injury in acatalasemic mice following exposure to carbon tetrachloride. Arch Toxicol 70:189–194.8825676
*Wang M-Y, Liehr JG. 1995. Lipid hydroperoxide-induced endogenous DNA adducts in hamsters: Possible mechanism of lipid hydroperoxide-mediated carcinogenesis. Arch Biochem Biophys 316(1):38–46.7840640
*Wang P-Y, Kaneko T, Tsukada H, 1997a. Dose- and route-dependent alterations in metabolism and toxicity of chemical compounds in ethanol-treated rats: Difference between highly (chloroform) and poorly (carbon tetrachloride) metabolized hepatotoxic compounds. Toxicol Appl Pharmacol 142:13–21.9007029
Wang P-Y, Kaneko T, Tsukada H, 1997b. Time courses of hepatic injuries induced by chloroform and by carbon tetrachloride: Comparison of biochemical and histopathological changes. Arch Toxicol 71:638–645.9332701
*Ware JH, Spengler JD, Neas LM, 1993. Respiratory and irritant health effects of ambient volatile organic compounds. Am J Epidemiol 137:1287–1301.8333411
Waring JF, Jolly RA, Ciurlionis R, 2001. Clustering of hepatotoxins based on mechanism of toxicity using gene expression profiles. Toxicol Appl Pharmacol 175(1):28–42.11509024
*Warrington JS, Greenblatt DJ, von Moltke LL. 2004. Age-related differences in CYP3A expression and activity in the rat liver, intestine, and kidney. J Pharmacol Exp Ther 309(2):720–729.14742746
Washall JW, Wampler TP. 1988. Purge and trap analysis of aqueous samples with cryofocusing. Am Lab July:70–74.
*Watanabe A, Shiota T, Takei N, 1986. Blood to brain transfer of carbon tetrachloride and lipoperoxidation in rat brain. Res Comm Chem Path Pharmacol 51:137–140.
Watanabe T, Niioka M, Hozawa S, 2000. Gene expression of interstitial collagenase in both progressive and recovery phase of rat liver fibrosis induced by carbon tetrachloride. J Hepatol 33(2):224–235.10952240
Waterfield CJ, Mesquita M, Parnham P, 1993. Taurine protects against the cytotoxicity of hydrazine, 1,4-naphthoquinone and carbon tetrachloride in isolated rat hepatocytes. Biochem Pharmacol 46(4):589–595.8363631
*Waterfield CJ, Turton JA, Scales MD, 1991. Taurine, a possible urinary marker of liver damage: A study of taurine excretion in carbon tetrachloride-treated rats. Arch Toxicol 65:548–555.1685880
*Wauthier V, Verbeeck RK, Calderon PB. 2004. Age-related changes in the protein and mRNA levels of CYP2E1 and CYP3A isoforms as well as in their hepatic activities in Wistar rats. What role for oxidative stress? Arch Toxicol 78:131–138.14600803
Weast RC. 1985. CRC handbook of chemistry and physics: A ready-reference book of chemical and physical data. Boca Raton, FL: CRC Press, Inc., C-349, C–350.
Weaver VM, Buckley TJ, Groopman JD. 1998. Approaches to environmental exposure assessment in children. Environ Health Perspect 106 (Suppl 3):827–832.9646045
*Weber FL, Macechko PT, Kelson SR, 1992. Increased muscle protein catabolism caused by carbon tetrachloride hepatic injury in rats. Gastroenterology 102:1700–1706.1568580
*Weber LW D, Boll M, Stampfl A. 2003. Hepatotoxicity and mechanism of action of haloalkanes: Carbon tetrachloride as a toxicological model. Crit Rev Toxicol 33(2):105–136.12708612
Weiner FR, Giambrone M-A, Czaja MJ, 1990. Ito-cell gene expression and collagen regulation. Hepatology 11:111–117.2295461
*Weisburger EK. 1977. Carcinogenicity studies on halogenated hydrocarbons. Environ Health Perspect 21:7–16.206428
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*Westrick JJ, Mello JW, Thomas RF. 1984. The groundwater supply survey. J Am Water Works Assoc 76:52–59.
*Whittaker SG, Zimmerman FK, Dicus B, 1989. Detection of induced mitotic chromosome loss in Saccharomyces cerevisiae- an interlaboratory study. Mutat Res 224:31–78.2671714
WHO. 1984. Guidelines for drinking-water quality. Volume 1. Recommendations. Geneva: World Health Organization.
*WHO. 1993. Guidelines for drinking water quality. Carbon tetrachloride. Geneva, Switzerland: World Health Organization. http://www.who.int/en/. June 6, 2003.
*WHO. 2000. Air quality guidelines. Geneva, Switzerland: World Health Organization. http://www.who.int/en/. June 6, 2003.
*Widdowson EM, Dickerson JW T. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
*Wilcosky TC, Checkoway H, Marshall EG, 1984. Cancer mortality and solvent exposures in the rubber industry. Am Ind Hyg Assoc J 45(12):809–811.6549104
*Will O, Mahler H-C, Arrigo A-P, 1999. Influence of glutathione levels and heat-shock on the steady-state levels of oxidative DNA base modifications in mammalian cells. Carcinogenesis 20(2):333–337.10069473
Williams CA, Jones HD, Freeman RW, 1994. The EPC approach to estimating safety from exposure to environmental chemicals. Regul Toxicol Pharmacol 20(3 part 1):259–280.7724834
*Wilson JG. 1954. Influence of the offspring of altered physiologic states during pregnancy in the rat. Ann NY Acad Sci 57:517–525.13189288
*Wirth KJ, Bickel M, Hropot M, 1997. The bradykinin B_2_ receptor antagonist Icatibant (HOE 140) corrects avid Na^+^ retention in rats with CCl_4_-induced liver cirrhosis: Possible role of enhanced microvascular leakage. Eur J Pharmacol 337(1):45–53.9389380
*Wirtschafter ZT. 1933. Toxic amblyopia and accompanying physiological disturbances in carbon tetrachloride intoxication. Am J Public Health 22:1035–1038.
Wirtschafter ZT, DeMeritt MG. 1959. Reticuloendothelial response to carbon tetrachloride. Arch Pathol 67:146–158.
*Withey JR, Collins BT, Collins PG. 1983. Effects of vehicle on the pharmacokinetics and uptake of four halogenated hydrocarbons from the gastrointestinal tract of rat. J Appl Toxicol 3:249–253.6662999
*Wolf CR, Mansuy D, Nastainczyk W, 1977. The reduction of polyhalogenated methanes by liver microsomal cytochrome P-450. Mol Pharmacol 13:698–705.18662
Wolff MS, Weston A. 1997. Breast cancer risk and environmental exposures. Environ Health Perspect Suppl 105(4):891–896.
Wolfgang GH, Donarski WJ, Petry TW. 1990. Effects of novel antioxidants on carbon tetrachloride-induced lipid peroxidation and toxicity in precision-cut rat liver slices. Toxicol Appl Pharmacol 106:63–70.2251684
Wong LCK, DiStefano V. 1966. Rapid accumulation of renal fat in cats after single inhalations of carbon tetrachloride. Toxicol Appl Pharmacol 9:485–494.
Wong CK, Ooi VE C, Wong CK. 2003. Protective effects of N-acetylcysteine against carbon tetrachloride- and trichloroethylene-induced poisoning in rats. Environ Toxicol Pharmacol 14:109–116.21782669
*Wong FWY, Chan WY, Lee SS T. 1998. Resistance to carbon tetrachloride-induced hepatotoxicity in mice which lack CYP2E1 expression. Toxicol Appl Pharmacol 153(1):109–118.9875305
Woodruff TJ, Axelrad DA, Caldwell J, 1998. Public health implications of 1990 air toxics concentrations across the United States. Environ Health Perspect 106:245–251.9518474
Wright PB, Moore L. 1991. Potentiation of the toxicity of model hepatotoxicants by acetaminophen. Toxicol Appl Pharmacol 109:327–335.2068730
Wu C, Miyagawa C, Kennedy DO, 1997. Involvement of polyamines in the protection of taurine against the cytotoxicity of hydrazine or carbon tetrachloride in isolated rat hepatocytes. Chem Biol Interact 103(3):213–224.9134011
Wynder E, Goldsmith R. 1977. The epidemiology of bladder cancer: A second look. Cancer 40:1246–1268.332323
Wyrebowska J, Jerykowski T. 1980. Some properties of aminopropanol dehydrogenase in rat serum studied in normal conditions and in acute carbon tetrachloride poisoning. J Toxicol Environ Health 6:613–620.7420468
Xu R-J, Cranwell PD. 1990. Development of gastric acid secretion in pigs from birth to thirty six days of age: The response to pentagastrin. J Dev Physiol 13:315–326.2084190
*Yamada Y, Fausto N. 1998. Deficient liver regeneration after carbon tetrachloride injury in mice lacking type 1 but not type 2 tumor necrosis factor receptor. Am J Pathol 152(6):1577–1589.9626061
*Yamada M, Ishiwada A, Hobo T, 1982. Novel chemiluminescence detector for determination of volatile polyhalogenated hydrocarbons by gas chromatography. J Chromatogr 238:347–356.
Yamagishi F, Komoda T, Ohnishi K, 1994. Correlation between various ratios of serum thyroid hormones and liver cytochrome P-450 in CCl_4_ treated and untraeted rats. Res Commun Chem Pathol Pharmacol 83(2):237–240.8202634
*Yamaguchi M, Tsurusaki Y, Misawa H, 2002. Potential role of regucalcin as a specific biochemical marker of chronic liver injury with carbon tetrachloride administration in rats. Mol Cell Biochem 241:61–67.12482026
*Yamamoto HA. 1990a. Brain phenylalanine and tyrosine levels and hepatic encephalopathy induced by CCl4 in rats. Toxicology 61:241–247.2330597
*Yamamoto HA. 1990b. Relation of Ca++ accumulation and lipid peroxidation with CCl_4_-induced toxicity in the rat liver. Pharmacol Toxicol 66:213–216.2333276
Yamamoto H, Sugihara N. 1987. Blood ammonia levels and hepatic encephalopathy induced by CCl_4_ in rats. Toxicol Appl Pharmacol 91:461–468.2962338
*Yamashita S, Ozawa R, Yamaguchi K, 1992. Analysis of volatile organic compounds in air by gas chromatography with thermal desorption cold-trap injection and atomic emission and mass selective detection. J High Resolut Chromatogr 15:549–551.
Yang Y, Harvey SA K, Gandhi CR. 2003. Kupffer cells are a major source of increased platelet activating factor in the CCl4-induced cirrhotic liver. J Hepatol 39:200–207.12873816
Yano T, Shibagaki T, Kitamura H, 1988. The mechanism of carbon tetrachloride induced pulmonary clara cell damage: Biochemical and morphologic studies. Res Commun Chem Pathol Pharmacol 62:483–493.3222526
Yata Y, Takahara T, Furui K, 1999. Expression of matrix metalloproteinase-13 and tissue inhibitor of metalloproteinase-1 in acute liver injury. J Hepatol 30:419–424.10190724
*Yaws C, Yang H-C, Pan X. 1991. Henry’s law constants for 362 organic compounds in water. Chem Eng 179–185.
Yokogawa K, Watanabe M, Takeshita H, 2004. Serum aminotransferase activity as a predictor of clearance of drugs metabolized by CYP isoforms in rats with actute hepatic failure induced by carbon tetrachloride. Int J Pharm 269:479–789.14706259
Yoneda M, Sato Y, Nakamura K, 2003. Involvement of calcitonin gene-related peptide and capsaicin-sensitive afferants in central thyrotropin-releasing hormone-induced hepatic cytoprotection. Eur J Pharmacol 478:173–177.14575802
Yoshida T, Adachi E, Nigi H, 1999. Changes of sinusoidal basement membrane collagens in early hepatic fibrosis induced with CC14 in cynomolgus monkeys. Pathology 31:29–35.10212919
Yoshida T, Andoh K, Fukuhara M. 1999. Estimation of absorption of trihalomethanes and carbon tetrachloride in low-level exposure by inhalation pharmacokinetic analysis in rats. Arch Environ Contam Toxicol 36:347–354.10047604
*Younes M, Siegers C-P. 1985. The role of iron in the paracetamol- and CCl4-induced lipid peroxidation and hepatotoxicity. Chem Biol Interact 55:327–334.4075439
*Young RA, Mehendale HM. 1989. Carbon tetrachloride metabolism in partially hepatectomized and sham-operated rats pre-exposed to chlordecone (kepone). J Biochem Toxicol 4:211–219.2483848
Yu C, Wang F, Jin C, 2003. Animal model: Role of fibroblast growth factor type 1 and 2 in carbon tetrachloride-induced hepatic injury and fibrogenesis. Am J Pathol 163(4):1653–1662.14507672
*Yuen ST, Gogo AR, Luk IS C, 1995. The effect of nicotine and its interaction with carbon tetrachloride in the rat liver. Pharmacol Toxicol 77:225–230.8884888
Zalatnai A, Sarosi I, Rot A, 1991. Inhibitory and promoting effects of carbon tetrachloride-induced liver cirrhosis on the diethylnitrosamine hepatocarcinogenesis in rats. Cancer Lett 57:67–73.2025881
*Zamara E, Novo E, Marra F, 2004. 4-Hydroxynonenal as a selective pro-fibrogenic stimulus for activated human hepatic stellate cells. J Hepatol 40:60–68.14672615
*Zangar RC, Benson JM, Burnett VL, 2000. Cytochrome P450 2E1 is the primary enzyme responsible for low-dose carbon tetrachloride metabolism in human liver microsomes. Chem Biol Interact 125:233–243.10731522
Zanovello A, Ferrara R, Manno M. 2003. Reductive activation of HCFC-123 by methaemalbumin. Toxicol Lett 144:127–136.12919730
*Zhang C, Valsaraj KT, Constant WD, 1998. Nutrient and surfactant enhancement for the biodegradation of chlorinated hydrocarbons in the wastewater from a Louisiana superfund site. J Hazard Mater 62:41–58.
*Zhao ZS, O'Brien PJ. 1996. The prevention of CCl_4_ -induced liver necrosis in mice by naturally occurring methylenedioxybenzenes. Toxicol Appl Pharmacol 140(2):411–421.8887459
Zhu W, Fung PC W. 2000. The roles played by crucial free radicals like lipid free radicals, nitric oxide, and enzymes NOS and NADPH in CCl_4_-induced acute liver injury of mice. Free Radic Biol Med 29(9):870–880.11063912
*Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
*Zielinska AB, Fujita E, Sagebiel J, 1998. Arizona hazardous air pollutants monitoring program. J Air Waste Manage Assoc 48:1038–1050.
*Zlatkis A, Kim K. 1976. Column elution and concentration of volatile compounds in biological fluids. J Chromatogr 126:475–485.977691