# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of carbon tetrachloride is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of carbon tetrachloride is located in Table 4-2.

Table 4-1 Chemical Identity of Carbon Tetrachloride

Characteristic | Information | Reference
Chemical name | Carbon tetrachloride | IARC 1979
Synonym(s) | Carbona; carbon chloride; carbon tet; methane tetrachloride; perchloromethane; tetrachloromethane; benzinoform | HSDB 2004
Registered trade name(s) | Benzinoform; Fasciolin; Flukoids; Freon 10; Halon 104; Tetraform; Tetrasol | IARC 1979
Chemical formula | CCl_4_ | IARC 1979
Chemical structure | [image] | IARC 1979
Identification numbers:
CAS registry | 56-23-5 | NLM1988
NIOSH RTECS | FG4900000 | HSDB 2004
EPA hazardous waste | U211; D019 | HSDB 2004
OHM/TADS | 7216634 | HSDB 2004
DOT/UN/NA/IMCO shipping | UN1846; IMCO 6.1 | HSDB 2004
HSDB | 53 | HSDB 2004
NCI | No data

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Carbon Tetrachloride

Property | Information | Reference
Molecular weight | 153.82 | Lide 1993
Color | Colorless | Verschueren 1983
Physical state | Liquid | Verschueren 1983
Melting point | −23 °C | Lide 1992
Boiling point | 76.5 °C | Lide 1992
Density | 1.594 g/mL | Lide 1992
Odor | Aromatic, sweet | HSDB 2004
Odor threshold:
Water | 0.52 mg/L | IRIS 2004
Air | 10–71,000 mg/m^3^ | Verschueren 1983
| 96 ppm (600 mg/m^3^) | Amoore and Hautala 1983
| 60–1,500 mg/m^3^ | Ruth 1986
Solubility:
Water at 20 °C | 800 mg/L | Verschueren 1983
Organic solvent(s) | Miscible | HSDB 2004
Partition coefficients:
Log K_ow_ | 2.64 | EPA 1984
Log K_oc_ | 2.04 | Kenaga 1980
Vapor pressure at 20 °C | 90 mmHg | Verschueren 1983
Henry’s law constant:
at 25 °C | 2.94×10^−2^ atm-m^3^/mol | Yaws et al. 1991
at 24.8 °C | 3.04×10^−2^ atm-m^3^/mol | HSDB 2004
at 20 °C | 2.04×10^−2^ atm-m^3^/mol | Tse et al. 1992
at 30 °C | 3.37×10^−2^ atm-m^3^/mol | Tse et al. 1992
Autoignition temperature | Nonflammable | HSDB 2004
Flashpoint | Nonflammable | HSDB 2004
Flammability limits | Nonflammable | HSDB 2004
Conversion factors
ppm (v/v) to mg/m^3^ in air (25 °C) | 1 ppm=6.39 mg/m^3^ | HSDB 2004
mg/m^3^ to ppm (v/v) in air (25 °C) | 1 mg/m^3^=0.16 ppm | Verschueren 1983
Explosive limits | No data