# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Carbon Tetrachloride Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Carbon Tetrachloride
CAS Number: | 56–23-5
Date: | June 2005
Profile Status: | Final Post-Public Comment Draft
Routre: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 30
Species: | Rat

[underlined: Minimal Risk Level]: 0.03 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Adams EM, Spencer HC, Rowe VK, 1952. Vapor toxicity of carbon tetrachloride determined by experiments on laboratory animals. Arch Ind Hyg Occup Med 6:50–66.

[underlined: Experimental design]: Groups of Wistar rats (15–25 males, 15–23 females) were exposed to vapors of carbon tetrachloride (5, 10, 25, 50, 100, 200, and 400 ppm) for 173–205 days (5 days/week, 7 hours/day). Two kinds of control groups were used: ‘unexposed controls’ that were maintained in the animal quarters and ‘air-exposed controls’ that were exposed to room air while in exposure chambers at equivalent frequency and duration as compound-exposed animals. Animals were weighed twice weekly and observed frequently for clinical signs. Food consumption was monitored. Hematological (prothrombin time) and biochemical indices (blood urea nitrogen, phospholipid, esterified cholesterol) were monitored in selected groups. Gross necropsy was performed and organ weights were determined for lung, heart liver, kidneys, spleen, and testes. Histopathological examination was performed on these and 11 other organs.

[underlined: Effects noted in study and corresponding doses]: No effects were observed in the 5 ppm exposure groups for any of the parameters measured. In rats, fatty degeneration of the liver and increased liver weight were evident at concentrations of ≥10 ppm and hepatic cirrhosis and pathology of the renal tubular epithelium (moderate cloudy swelling) occurred at ≥50 ppm. At ≥200 ppm, hepatic necrosis, increased kidney weight, degeneration of the renal tubular epithelium, and some testicular atrophy were observed. The severity of effects increased with exposure level.

[underlined: Dose and end point used for MRL derivation]: The MRL was based on a NOAEL of 5 ppm and a LOAEL of 10 ppm for fatty degeneration and increased liver weights.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans using a dosimetric adjustment
- [X] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?] Not applicable. If so, explain:

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose]: A human equivalent concentration was calculated from the rat NOAEL of 5 ppm in the principal study for an extrarespiratory effect of a type 3 gas, as recommended by EPA (1994) guidance for derivation of inhalation reference concentrations. A human equivalent concentration of the identified rat NOAEL of 5 ppm (NOAEL_HEC_) was calculated by multiplying the duration-adjusted rat NOAEL (NOAEL_ADJ_) by the ratio of the rat and human blood:gas partition coefficients. The NOAEL_ADJ_ is 0.9 ppm (5 ppm × 7 hours/24 hours × 5 days/7 days) and the blood:gas partition coefficient ratio is 1.7 (4.52/2.64). Because the ratio was greater than 1, a default value of 1 was applied, resulting in a NOAEL_HEC_ of 0.9 ppm. An uncertainty factor of 30 was applied to the NOAEL_HEC_ of 0.9 ppm (3 for extrapolation from animals to humans using a dosimetric adjustment and 10 for human variability).

[underlined: Other additional studies or pertinent information which lend support to this MRL]: Limited human data are available for intermediate-duration inhalation exposure to carbon tetrachloride. Effects in humans exposed intermittently included gastrointestinal effects (nausea, dyspepsia) at 20–50 ppm, central nervous system depression at 40 ppm, and narcosis at 80 ppm (Elkins 1942; Heiman and Ford 1941; Kazantzis and Bomford 1960). An occupational study of hepatic effects in workers exposed from <1 to >5 years indicated that serum levels of hepatic enzymes were significantly elevated only at exposures >1 ppm, but the actual durations of exposure were not reported (Tomenson et al. 1995). Interpretation of this study is also limited by the finding that the group estimated to have had the highest exposure did not show the highest levels of serum enzymes. The liver appears to be the most sensitive target in animals exposed for intermediate durations. Fatty degeneration, sometimes with increased liver weight, was observed at a LOAEL of 10 ppm in rats, mice, and guinea pigs treated 6–8 hours/day, 5 days/week for 12–36 weeks or continuously for 90 days (Adams et al. 1952; DOE 1999; Japan Bioassay Research Center 1998; Prendergast et al. 1967), and 50–100 ppm in monkeys (Adams et al. 1952; Smyth et al. 1936). Increased serum enzymes and necrosis were observed in mice at 20 ppm and hamsters at 100 ppm (DOE 1999). Exposure to higher concentrations resulted in cirrhosis in guinea pigs (25 ppm) and rats (50–270 ppm) (Adams et al. 1952; Japan Bioassay Research Center 1998; Prendergast et al. 1967; Smyth et al. 1936). In studies examining other organs, renal effects (tubular degeneration) were noted at 50–200 ppm in rats (Adams et al. 1952; Smyth et al. 1936), at 90 ppm in rats and mice (Japan Bioassay Research Center 1998), and at 200 ppm in monkeys (Smyth et al. 1936). Injury to sciatic and optical nerves was noted in rats at 50 ppm (Smyth et al. 1936); hematological effects (decreased erythrocytes, hemoglobin, hematocrit; hemolysis, increased spleen weight) were observed in rats and mice exposed to 90–270 ppm (Japan Bioassay Research Center 1998; Smyth et al. 1936), and reproductive toxicity (decreased litters, testicular atrophy) was noted at 200 ppm (Adams et al. 1952; Smyth et al. 1936). Hepatotoxicity is identified as the critical effect of intermediate-duration inhalation exposure to carbon tetrachloride since it was noted at the lowest LOAELs. The study by Adams et al. (1952) is selected as the principal study because it identified the lowest LOAEL and the highest NOAEL for the critical effect.

[underlined: Agency Contacts (Chemical Managers)]: Obaid Faroon, Ph.D.; Jessilynn Taylor, M.S.; Nickolette Roney, M.P.H.

## Carbon Tetrachloride Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Carbon Tetrachloride
CAS Number: | 56-23-5
Date: | June 2005 Profile
Status: | Final Post-Public Comment Draft
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 50
Species: | Rat

[underlined: Minimal Risk Level]: 0.03 [ ] mg/kg/day [X] ppm

[underlined: References]: Japan Bioassay Research Center. 1998. Subchronic inhalation toxicity and carcinogenicity studies of carbon tetrachloride in F344 rats and BDF1 mice (Studies Nos. 0020, 0021, 0043, and 0044). Kanagawa, Japan Industrial Safety and Health Association, Japan Bioassay Research Center (Unpublished report to the Ministry of Labor). Hirasawa Hadano Kanagawa, 257 Japan. (In 2001, T. Matsushima provided to SRC organ weight data tables for these studies.)

(Methods published in: Nagano K, Nishizawa T, Yamamoto S, 1998. Inhalation carcinogenesis studies of six halogenated hydrocarbons in rats and mice. In: Chiyotani K, Hosoda Y, Aizawa Y, eds. Advances in the prevention of occupational respiratory diseases. Elsevier Science B.V., 741–746.)

[underlined: Experimental design]: Groups of 50 male and 50 female F344/DuCrj rats were exposed (whole-body) to vapors of carbon tetrachloride (>99% pure) at concentrations of 0, 5, 25, or 125 ppm, 6 hours/day, 5 days/week for 104 weeks. Rats were observed daily for clinical signs, behavioral changes, and mortality. Body weights were measured weekly for the first 13 weeks and every 4 weeks thereafter. Urinalysis was performed at the end of the dosing period. Hematology and serum chemistry were measured in blood samples taken during final euthanization after overnight fasting. All organs and tissues were examined for gross lesions, weighed, and fixed for histopathological analysis.

[underlined: Effects noted in study and corresponding concentrations]: Male rats at ≥5 ppm exhibited enhanced hemosiderin deposition in the spleen; this was apparently a residual effect of anemia that was observed in the 13-week study, but not at 104 weeks. No significant hepatic effects were noted at 5 ppm. At ≥25 ppm, significant hepatic effects were observed: statistically significant elevations relative liver weights, serum parameters (total bilirubin, ALT, AST), and increased incidences of liver histopathology (fatty change, granulation, foci in the liver, deposition of ceroid, and serious effects such as fibrosis and cirrhosis). Chronic nephropathy was observed in all groups, including controls, but at greater severity at 25 ppm and above; significant proteinuria (dipstick values of 3+ or 4+) was also observed in all groups (in >90% of controls), but at higher severity in males treated at 5 ppm and females at 25 ppm and above. At 25 ppm, females had significant hematological changes (decreased hemoglobin, hematocrit, and lymphocyte counts and increased leukocyte and segmented neutrophil counts). At 125 ppm, body weights were decreased and there was increased mortality from chronic nephrosis and tumors.

The tumors observed at 125 ppm included: hepatocellular adenomas in 21/50 males and 40/50 females and hepatocellular carcinomas in 32/50 males and 15/50 females. At 25 ppm, females had significant hematological changes (decreased hemoglobin, hematocrit, and lymphocyte counts and increased leukocyte and segmented neutrophil counts).

[underlined: Dose and end point used for MRL derivation]: A NOAEL of 5 ppm LOAEL of 25 ppm for increased liver weight, serum enzymes, and liver histopathology (fatty change, granulation, foci, deposition of ceroid, fibrosis, and cirrhosis).

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans using dosimetric adjustment
- [X] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?] Not applicable. If so, explain:

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent concentration]: A human equivalent concentration was calculated from the rat NOAEL of 5 ppm in the principal study for an extrarespiratory effect of a type 3 gas, as recommended by EPA (1994) guidance for derivation of inhalation reference concentrations. A human equivalent concentration of the identified rat NOAEL of 5 ppm for hepatic effects (Japan Bioassay Research Center 1998) was calculated by multiplying the duration-adjusted rat NOAEL (NOAEL_ADJ_) by the ratio of the rat and human blood:gas partition coefficients. The NOAEL_ADJ_ is 0.9 ppm (5 ppm × 6 hours/24 hours × 5 days/7 days) and the blood:gas partition coefficient ratio is 1.7 (4.52/2.64). Because the ratio was greater than 1, a default value of 1 was applied, resulting in a NOAEL_HEC_ of 0.9 ppm. An uncertainty factor of 30 was applied to the NOAEL_HEC_ to derive the chronic-duration inhalation MRL.

[underlined: Other additional studies or pertinent information which lend support to this MRL]: The chronic-duration inhalation database for carbon tetrachloride includes the occupational study by Tomenson et al. (1995) and 2-year bioassays in rats and mice (Japan Bioassay Research Center 1998; Nagano et al. 1998). As discussed under the intermediate-duration MRL, elevated hepatic serum enzymes were observed in workers who had been exposed to concentrations >1 ppm for <1–>5 years, but the actual durations of exposure were not reported (Tomenson et al. 1995). Interpretation of this study is also limited by the finding that the group estimated to have had the highest exposure did not show the highest levels of serum enzymes. In the 2-year bioassay in BDF_1_ mice, groups of 50/sex were treated at 0, 5, 25, or 125 ppm, 6 hours/day, 5 days/week for 104 weeks (Japan Bioassay Research Center 1998; Nagano et al. 1998). No effects were noted at the lowest concentration of 5 ppm. In mice, 25 ppm was a LOAEL for most observed effects: hematological (increased extramedullary hematopoeisis in spleen associated with recovery from anemia), body weight (reduced body weight gain), renal (protein casts and altered clinical chemistry values), and hepatic (increased liver weights, degeneration, cyst, deposition of ceroid, increased serum enzymes, cholesterol, bilirubin in both sexes, and thrombus and necrosis in females). Mice at ≥25 ppm also exhibited significant increases in the incidences of hepatic adenoma and carcinoma with increased mortality.

One effect in rat was noted at 5 ppm, but was not selected as the critical effect of chronic-duration inhalation exposure. The severity of proteinuria, but not renal histopathology, was elevated in male and female rats treated at 5 ppm compared to controls; however, as the severity in control rats was so high (>90% with scores of 3+ or 4+), this lesion was not used as the basis for MRL derivation. Hepatotoxicity is selected as the critical effect of chronic-duration inhalation exposure because the severity of effects at 25 ppm was greater compared to other end points. Furthermore, selection of hepatotoxicity as the critical effect of chronic exposure is consistent with the database for intermediate-duration inhalation exposure. The 2-year bioassay in rats is selected as the principal study for the chronic-duration inhalation MRL since it provided a NOAEL of 5 ppm and a LOAEL of 25 ppm for hepatic effects without increased mortality.

[underlined: Agency Contacts (Chemical Managers)]: Obaid Faroon, Ph.D.; Jessilynn Taylor, M.S.; Nickolette Roney, M.P.H.

## Carbon Tetrachloride Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Carbon Tetrachloride
CAS Number: | 56-23-5
Date: | June 2005 Profile
Status: | Final Post-Public Comment Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graphy Key: | 23
Species: | Rat

[underlined: Minimal Risk Level]: 0.02 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Smialowicz RJ, Simmons JE, Luebke RW, 1991. Immunotoxicologic assessment of subacute exposure of rats to carbon tetrachloride with comparison to hepatotoxicity and nephrotoxicity. Fundam Appl Toxicol 17:186–196.1833255

[underlined: Experimental design]: Groups of 5–6 male Fischer 344 rats were dosed by gavage for 10 consecutive days with 0, 5, 10, 20, or 40 mg/kg/day of carbon tetrachloride in corn oil. Serum chemistry profiles, hepatic cytochrome P-450 content and activity, and kidney and liver organ weight and histopathology were assessed. Various immune function parameters were also examined in these animals, and in another set exposed to 40, 80, or 160 mg/kg/day. Immune function end points included relative spleen and thymus weights; natural killer cell activity; lymphoproliferative response to concanavalin A, phytohemagglutinin, pokeweed mitogen, and Salmonella typhimurium mitogen; allogeneic cytotoxic T lymphocyte reaction; and primary antibody response to sheep red blood cells.

[underlined: Effects noted in study and corresponding doses]: No hepatic effects were observed in controls. Minimal centrilobular vacuolar degeneration was detectable in all rats at 5 mg/kg/day; degeneration was mild in all rats treated at 10 and 20 mg/kg/day and 5/6 rats at 40 mg/kg/day and moderate in one high-dose rat. Hepatocellular necrosis was minimal in 3/6 rats at 10 mg/kg/day, 5/6 rats at 20 mg/kg/day, and 5/6 rats at 40 mg/kg/day, and mild in one high-dose rat. Serum ALT and AST levels were significantly elevated 1.5–5.4-fold compared to controls at doses of 20 and 40 mg/kg/day. Mean relative liver weight was significantly (p<0.01) increased by 17.7% compared to controls at 40 mg/kg/day. Treatment with carbon tetrachloride had no significant effect compared to controls on body weight, absolute liver weight, or renal parameters at doses from 5 to 40 mg/kg/day. However, when three separate 40 mg/kg/day groups and their controls were analyzed by two-way ANOVA with carbon tetrachloride and replicates as factors, a significant decrease in weight gain was detected. Body weight gain was significantly reduced at 80 mg/kg/day and higher, as determined by comparison of the slopes of weight gains over the dosing period. There were no adverse effects on immunological parameters at doses up to 160 mg/kg/day.

[underlined: Dose and end point used for MRL derivation]: LOAEL of 5 mg/kg/day for minimal vacuolar degeneration of centrilobular hepatocytes.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL [X]
- 10 for extrapolation from animals to humans [X]
- 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?] Not applicable. If so, explain:

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:] Not applicable.

[underlined: Other additional studies or pertinent information which lend support to this MRL]: In humans, hepatic toxicity (fatty accumulation, necrosis) has been noted following ingestion of single doses of carbon tetrachloride in the range of 80–180 mg/kg (Docherty and Burgess 1922; Docherty and Nicholls 1923; Phelps and Hu 1924). Single doses of 70 mg/kg had no overt neurological effect, but various neurological symptoms indicative of depression of the central nervous system have been reported at doses between 114 and 10,800 mg/kg (Cohen 1957; Hall 1921; Leach 1922; Stevens and Forster 1953; Stewart et al. 1963). Gastrointestinal effects in humans following ingestion of single doses include nausea at ≥100 mg/kg (Ruprah et al. 1985) and vomiting and abdominal pain at 680–910 mg/kg (Hardin 1954; New et al. 1962; Smetana 1939; Umiker and Pearce 1953; von Oettingen 1964). In laboratory animals, mild hepatic effects (cytoplasmic vacuolization and increased serum enzymes) have been reported to occur following treatment with single doses of 40–80 mg/kg or repeated dosing at 5–20 mg/kg/day (Bruckner et al. 1986; Kim et al. 1990b; Korsrud et al. 1972; Smialowicz et al. 1991). No renal effects or positive results in special tests for immunological function were observed in rats following repeated administration at 5–160 mg/kg/day (Bruckner et al. 1986; Smialowicz et al. 1991). Renal effects (fatty degeneration, swelling of convoluted tubules) were observed in dogs given single doses of 3,200–6,400 mg/kg (Chandler and Chopra 1926; Gardner et al. 1925). Hepatic toxicity is selected as the critical effect of acute-duration oral exposure to carbon tetrachloride because effects were observed at the lowest effect level. The study of Smialowicz et al. (1991) is selected as the principal study because it provides the lowest LOAEL of 5 mg/kg/day for the critical effect.

[underlined: Agency Contacts (Chemical Managers):] Obaid Faroon, Ph.D.; Jessilynn Taylor, M.S.; Nickolette Roney, M.P.H.

## Carbon Tetrachloride Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Carbon Tetrachloride
CAS Number: | 56-23-5
Date: | June 2005 Profile
Status: | Final Post-Public Comment Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 46
Species: | Rat

[underlined: Minimal Risk Level]: 0.007 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Bruckner JV, MacKenzi WF, Muralidhara S, 1986. Oral toxicity of carbon tetrachloride: Acute, subacute and subchronic studies in rats. Fundam Appl Toxicol 6:16–34.3710021

[underlined: Experimental design]: Male Sprague-Dawley rats (15–16/dose) were administered carbon tetrachloride (0, 1, 10, or 33 mg/kg) in corn oil by gavage 5 days/week for 12 weeks. Body weight was monitored twice weekly. Blood samples were collected from five rats per group just before dosing at 2, 4, 6, 8, 10, and 12 weeks for measurement of serum levels of sorbitol dehydrogenase (SDH), ornithine carbamyl transferase (OCT), alanine aminotransferase (ALT), and blood urea nitrogen (BUN). Each rat served as a blood donor twice during the study at 6-week intervals. At the end of the 12-week period, 7–9 rats per group were sacrificed and the remaining were maintained for 13 days without dosing before sacrifice. Histopathological examination of the liver and kidneys was performed.

[underlined: Effects noted in study and corresponding doses]: No adverse effects were noted at 1 mg/kg. Body weight gain was reduced in the 33 mg/kg group by 17% compared to controls after 90 days (p<0.05). At 10 mg/kg, there were statistically significant increases in serum SDH activity, 2-fold higher than controls, observed as early as 10 weeks; a statistically significant 35% elevation in serum ALT was observed in this group at 12 weeks. Elevations in these serum parameters returned to control levels during the recovery period. Mild centrilobular vacuolization was observed in the liver of all animals treated at 10 mg/kg/day for 12 weeks. Substantial liver toxicity was observed at 33 mg/kg as early as 2 weeks. At 2 weeks, serum ALT was elevated 5-fold, OCT 6-fold, and SDH 38-fold compared to controls; after 12 weeks, serum ALT was elevated 20-fold, OCT 5-fold, and SDH 45-fold compared to controls. Only the serum ALT elevation (2-fold) was still statistically different from controls after 2 weeks of recovery. The liver:body weight ratio was significantly elevated by 46% in the 33 mg/kg group compared to controls. Extensive hepatic lesions observed in the 33 mg/kg group after 12 weeks included vacuolization, periportal fibrosis, bile duct hyperplasia, hyperplastic nodules, and single-cell necrosis. Treatment with carbon tetrachloride had no significant effect on kidney:body weight ratios, a kidney-related serum parameter (BUN) or on the incidence of kidney lesions.

[underlined: Dose and end point used for MRL derivation]: The NOAEL of 1 mg/kg for mild centrilobular vacuolization and increased serum SDH was used to derive the MRL. The NOAEL was adjusted for intermittent exposure (5 days/7 days), resulting in a duration-adjusted NOAEL of 0.71 mg/kg/day.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose]? Not applicable. If so, explain:

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:] Not applicable.

[underlined: Other additional studies or pertinent information which lend support to this MRL]: The intermediate-duration oral toxicity database for carbon tetrachloride is somewhat limited in that no human data are available and many studies in laboratory animals restricted analysis to the liver or to the liver and kidney. The incidence and severity of hepatic effects were dose-related in animal studies. Whereas no hepatic effects were noted at 1 mg/kg, significantly elevated sorbitol dehydrogenase (SDH) and mild centrilobular vacuolization were noted in rats exposed at 10 mg/kg 5 days/week for 12 weeks (Bruckner et al. 1986). In mice ingesting carbon tetrachloride 5 days/week for 12–13 weeks, no hepatic effects were detected at a dose of 1.2 mg/kg (Condie et al. 1986). Significant elevation in some serum enzymes (ALT, aspartate aminotransferase [AST], lactate dehydrogenase [LDH]), and mild necrosis were seen in mice at doses of 12 mg/kg and higher (Condie et al. 1986; Hayes et al. 1986). More extensive hepatic lesions (fatty accumulation, fibrosis, cirrhosis, necrosis) were noted in rats at doses of 20–25 mg/kg and higher (Allis et al. 1990; Bruckner et al. 1986; Koporec et al. 1995). At 100 mg/kg/day, hepatic effects in rats also included cytomegaly and various types of hyperplasia, which were perhaps adaptive responses to necrosis (Koporec et al. 1995). Effects in other organ systems include reduced body weight gain at doses between 33 and 100 mg/kg/day (Bruckner et al. 1986; Koporec et al. 1995) and neurological effects (increased serotonin synthesis) at 290 mg/kg/day (Bengtsson et al. 1987). No renal effects were observed in mice exposed at 1,200 mg/kg/day despite hepatic effects at lower levels (Hayes et al. 1986). Increased mortality was observed in rats exposed at 25 mg/kg/day (Koporec et al. 1995) and cancer (hepatoma) in mice treated with 20 mg/kg/day for 120 days and hamsters treated once weekly with 120 mg/kg/day for 30 weeks (Eschenbrenner and Miller 1946; Della Porta et al. 1961). Hepatic effects were selected as the critical effects of intermediate-duration oral exposure to carbon tetrachloride because they occurred at the lowest effect level. The rat study of Bruckner was selected as the principal study because it provided the lowest LOAEL for the critical effect.

[underlined: Agency Contacts (Chemical Managers):] Obaid Faroon, Ph.D.; Jessilynn Taylor, M.S.; Nickolette Roney, M.P.H.