# VERSION HISTORY

Date | Description
July 2025 | Final toxicological profile released
October 2024 | Draft for public comment toxicological profile released
August 1996 | Final toxicological profile released