# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding carbon disulfide in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for carbon disulfide.

Table 7-1 Regulations and Guidelines Applicable to Carbon Disulfide

Agency | Description | Information | Reference
Air
EPA | RfC | 0.7 mg/m^3^ (0.2 ppm) | IRIS 2002
WHO | Air quality guidelines | 100 µg/m^3^ (0.03 ppm)^a^ averaged over 24 hours | WHO 2000
Water & Food
EPA | Drinking water standards and health advisories | Not listed | EPA 2018a
EPA | National primary drinking water regulations | Not listed | EPA 2023b
EPA | RfD | 0.1 mg/kg/day | IRIS 2002
WHO | Drinking water quality guidelines | Not listed | WHO 2022
FDA | Substances added to food (formerly EAFUS) | Not listed | FDA 2025
Cancer
HHS | Carcinogenicity classification | Not evaluated | NTP 2021
EPA | Carcinogenicity classification | Not evaluated | IRIS 2002
IARC | Carcinogenicity classification | Not evaluated | IARC 2025
Occupational
OSHA | PEL (8-hour TWA) for general industry | 20 ppm (60 mg/m^3^)^b^ | OSHA 2023a
OSHA | Ceiling limit | 30 ppm | OSHA 2023a
OSHA | Maximum peak for an 8-hour shift | 100 ppm for 30 minutes | OSHA 2023a
OSHA | PEL (8-hour TWA) for construction and shipyards | 20 ppm (60 mg/m^3^)^c^ | OSHA 2023b, 2023c
NIOSH | REL (up to 10-hour TWA) | 1 ppm (3 mg/m^3^)^d^ | NIOSH 2019
NIOSH | STEL (15-minute TWA) | 10 ppm (30 mg/m^3^) | NIOSH 2019
NIOSH | IDLH | 500 ppm | NIOSH 2019
Emergency Criteria
EPA | AEGLs-air | | EPA 2018b
EPA | AEGL 1^e^ | | EPA 2018b
EPA | 10-minute | 17 ppm | EPA 2018b
EPA | 30-minute | 17 ppm | EPA 2018b
EPA | 60-minute | 13 ppm | EPA 2018b
EPA | 4-hour | 8.4 ppm | EPA 2018b
EPA | 8-hour | 6.7 ppm | EPA 2018b
EPA | AEGL 2^e^ | | EPA 2018b
EPA | 10-minute | 200 ppm | EPA 2018b
EPA | 30-minute | 200 ppm | EPA 2018b
EPA | 60-minute | 160 ppm | EPA 2018b
EPA | 4-hour | 100 ppm | EPA 2018b
EPA | 8-hour | 50 ppm | EPA 2018b
EPA | AEGL 3^e^ | | EPA 2018b
EPA | 10-minute | 600 ppm | EPA 2018b
EPA | 30-minute | 600 ppm | EPA 2018b
EPA | 60-minute | 480 ppm | EPA 2018b
EPA | 4-hour | 300 ppm | EPA 2018b
EPA | 8-hour | 150 ppm | EPA 2018b
DOE | PACs-air | | DOE 2025a
DOE | PAC-1^f^ | 13 ppm | DOE 2025a
DOE | PAC-2^f^ | 160 ppm | DOE 2025a
DOE | PAC-3^f^ | 480 ppm | DOE 2025a

a A guideline value of 20 µg/m^3^ (0.006 ppm), averaged over 30 minutes, based on sensory effects, is recommended when carbon disulfide is used as an index substance for viscose emissions (WHO 2000).

b Reflects the exposure limit that was in effect prior to the issuance of newer limits (carbon disulfide PEL of 4 ppm and STEL of 12 ppm) on January 19, 1989, which were then vacated by the Eleventh Circuit Court of Appeals on July 7, 1992 (NIOSH 2018).

c Skin designation.

d Skin notation.

e Definitions of AEGL terminology are available from EPA (2018c).

f Definitions of PAC terminology are available from DOE (2025b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term exposure limit; TWA = time-weighted average; WHO = World Health Organization