# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of carbon disulfide is presented in Table 4-1. Carbon disulfide (also frequently referred to as carbon bisulfide) is an inorganic, linear, small molecule with a single carbon atom double-bonded with two sulfur atoms on opposite sides.

Table 4-1 Chemical Identity of Carbon Disulfide

Characteristic | Information | Reference
Chemical name | Carbon disulfide | NLM 2023
Synonym(s) and registered trade name(s) | Carbon bisulphide; carbon disulphide; carbon sulfide; carbon sulphide; dithiocarbonic anhydride; sulphocarbonic anhydride; Weeviltox®; Caswell No. 162® | NLM 2023
Chemical formula | CS_2_ | NLM 2023
SMILES | C(=S)=S | NLM 2023
Chemical structure | S=C=S | NLM 2023
CAS Registry Number | 75-15-0 | NLM 2023

CAS = Chemical Abstracts Service; SMILES = simplified molecular-input line-entry system

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of carbon disulfide is presented in Table 4-2. Pure carbon disulfide is a clear colorless liquid with a pleasant odor, while the commercial version may contain small traces of other sulfur-containing substances such as hydrogen sulfide, which may give it a yellow color and unpleasant odor. It is a highly volatile, flammable, and mobile liquid that is miscible in several solvents.

Table 4-2 Physical and Chemical Properties of Carbon Disulfide

Property | Information | Reference
Molecular weight | 76.15 g/mol | NLM 2023
Color | Clear, colorless, or faintly yellow | Sax and Lewis 1987
Physical state | Highly refractive, mobile liquid | Windholz 1983
Melting point | −110.8°C | Weast 1989
Melting point | −111.7°C | NLM 2023
Boiling point | 46.5°C (at 760 torr) | Windholz 1983
Density
at 15°C | 1.27055 g/mL | Windholz 1983
at 20°C | 1.2632 g/mL | Windholz 1983
at 30°C | 1.24817 g/mL | Windholz 1983
Odor | Purest distillates have sweet, pleasing, and ethereal odor; commercial and reagent grades have foul sulfuric “rotten egg” smell | ATSDR 1999; Flick 1985; Windholz 1983
Odor threshold:
Water | 0.0026 mg/L (faint odor) | Verschueren 1983
Air | 0.31–0.65 mg/m^3^ (0.1–0.2 ppm) | ACGIH 1986
Air | Low=0.0243 mg/m^3^ (0.008 ppm) | Ruth 1986
Air | High=23.1 mg/m^3^ (7.39 ppm) | Ruth 1986
Air | 0.31 mg/m^3^ (0.1 ppm) (response in 50% of subjects) | MCA 1968
Air | 0.65 mg/m^3^ (0.21 ppm) (response in 100% of subjects) | MCA 1968
Air | 0.05 mg/m^3^ (0.016 ppm) (perception in humans) | Verschueren 1983
Air | 0.04 mg/m^3^ (0.01 ppm) (nonperception with adverse reflex response in humans) | Verschueren 1983
Taste threshold | No data
Solubility:
Water
at 20°C | 2,940 mg/L | Windholz 1983
at 22°C | 2,300 mg/L | Verschueren 1983
Organic solvents | Miscible with anhydrous methanol, ethanol, ether, benzene, chloroform, carbon tetrachloride, and oils | Windholz 1983
Partition coefficients:
Log K_ow_ | 1.84–2.16 (calculated) | Verschueren 1983
Log K_oc_ | 1.68 | NLM 2023
Vapor pressure
at 0°C | 127.0 mmHg | Flick 1985
at 10°C | 200 mmHg | Verschueren 1983
at 20°C | 260 mmHg | Verschueren 1983
at 20°C | 297.5 mmHg | Timmerman 1978
at 25°C | 353.6 mmHg | Worthing 1987
at 30°C | 430 mmHg | Verschueren 1983
Henry’s law constant at 25°C | 1.33x10^−2^ atm m^3^/mol | EPA 1981a
Autoignition temperature | 100°C | Windholz 1983; Sax and Lewis 1987
Autoignition temperature | 125–135°C | Worthing 1987
Flashpoint | −30°C (closed cup) | NFPA 1986; Sax and Lewis 1987; Windholz 1983
Flammability limits in air | 1–50% (v/v) (explosive range) | Flick 1985; Windholz 1983
Flammability limits in air | 1.3–50% | NFPA 1986; OSHA 2022
Conversion factors | 0.32 ppm=1 mg/m^3^ | Beauchamp et al. 1983
Explosive limits | Lower=1% | NLM 2023
Explosive limits | Upper=50%