# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR CARBON DISULFIDE

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to carbon disulfide, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to carbon disulfide:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to carbon disulfide. The inclusion criteria used to identify relevant studies examining the health effects of carbon disulfide are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species; Human; Laboratory mammals
Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data)
Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen were conducted to identify studies examining the health effects of carbon disulfide. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the literature searches were intended to update the Toxicological Profile for Carbon Disulfide. See Appendix B for the databases searched and the search strategy.

A total of 3,825 and 1,025 records relevant to all sections of the toxicological profile were identified in the initial and update literature search, respectively.

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of carbon disulfide.

Title and Abstract Screen. In the Title and Abstract Screen step, 169 documents (inclusive of all literature searches) were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 171 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 171 documents (180 studies), 124 documents (121 studies) were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted from Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for Carbon Disulfide and overviews of the results of the inhalation, oral, and dermal exposure studies are presented in Sections 2.2–2.18 of the profile and in the Levels Significant Exposures tables in Section 2.1 of the profile (Tables 2-1, 2-2, and 2-3, respectively).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for carbon disulfide identified in human and animal studies are presented in Tables C-3 and C-4, respectively. Available human studies evaluating noncancer effects include numerous occupational exposure studies and a limited number of general population exposure studies. These studies suggest that the cardiovascular, ophthalmological, hepatic (altered lipid homeostasis), and neurological systems may be targets of carbon disulfide exposure following long term inhalation exposure. Animal studies evaluated a comprehensive set of endpoints following inhalation exposure, a limited set of endpoints following oral exposure, and dermal studies were limited to two acute-duration and one intermediate-duration studies evaluating dermal and ocular effects only. Cardiovascular, altered lipid homeostasis, neurological, male reproductive, and developmental effects were considered sensitive outcomes following inhalation exposure in animals, and neurological and developmental effects were considered sensitive outcomes following oral exposure in animals (i.e., effects were observed at low concentrations or doses). Based on effects noted in human and animal studies, epidemiological and experimental studies examining cardiovascular effects, ophthalmology, altered lipid synthesis, neurological effects, male reproductive endpoints, and developmental effects following inhalation exposure and neurological and developmental effects following oral exposure were evaluated using the systematic review process. There were 121 studies (published in 124 documents) examining these potential outcomes were carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for Carbon Disulfide Evaluated In Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Prospective/Longitudinal cohort | | 3 | 6 | | 2 | | 4 | 1 | | 1 | 1 | | 5 | 1 | | 2 | 2
Prospective/Longitudinal cohort | | 2 | 4 | | | | 1 | 0 | | 1 | 1 | | 3 | 1 | | 0 | 0
Retrospective cohort | 1 | | 18 | 2 | 4 | 1 | 16 | 2 | | 8 | 4 | | 23 | 11 | 1 | 6 | 4
Retrospective cohort | 1 | | 12 | 1 | 1 | 0 | 7 | 2 | | 6 | 2 | | 21 | 7 | 0 | 2 | 0
Case control | | 1 | | | | | | | | | | | | | | | 3
Case control | | 0 | | | | | | | | | | | | | | | 3
Population | | | | | | | | | | | | | | | | 1
Population | | | | | | | | | | | | | | | | 1
Cross-sectional | | 1 | | | 2 | | 2 | 1 | | | 4 | | 2 | 1 | | 1
Cross-sectional | | 0 | | | 0 | | 0 | 0 | | | 3 | | 2 | 0 | | 1
Case series | | 2 | | 2 | | | | | | | | | 2
Case series | | 2 | | 2 | | | | | | | | | 2
Experimental | | | | | | | 1 | | | | | | 1
Experimental | | | | | | | 0 | | | | | | 1
Ecological | | | | | | | | | | | | | | | | | 2
Ecological | | | | | | | | | | | | | | | | | 0
Oral studies
All study types
Dermal studies
All study types

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Table C-4 Overview of the Health Outcomes for Carbon Disulfide Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration | 7 | 5 | 3 | | 1 | | 7 | 1 | | | | | 11 | 4 | 4
Acute-duration | 2 | 3 | 1 | | 1 | | 4 | 0 | | | | | 10 | 0 | 3
Intermediate-duration | 21 | 7 | 9 | 3 | 3 | 4 | 9 | 7 | | 3 | 3 | 3 | 17 | 15 | 6
Intermediate-duration | 14 | 0 | 3 | 0 | 2 | 0 | 3 | 1 | | 0 | 0 | 0 | 16 | 7 | 3
Chronic-duration | 1 | | 1 | | | | 1
Chronic-duration | 0 | | 0 | | | | 1
Oral studies
Acute-duration | 6 | | 2 | | 1 | | 3 | | | | | 1 | 4 | | 4
Acute-duration | 4 | | 2 | | 1 | | 3 | | | | | 1 | 4 | | 3
Intermediate-duration | 3 | | 1 | | | 1 | | | | | | | 5
Intermediate-duration | 3 | | 1 | | | 1 | | | | | | | 5
Chronic-duration
Dermal studies
Acute-duration | | | | | | | | | 2
Acute-duration | | | | | | | | | 2
Intermediate-duration | | | | | | | | | | 1
Intermediate-duration | | | | | | | | | | 1
Chronic-duration

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias; Were the comparison groups appropriate?
Confounding bias; Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were experimental conditions identical across study groups?; Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk-of-bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of carbon disulfide health effects studies (observational epidemiology and animal experimental studies) are presented in Tables C-8 and C-9, respectively.

Table C-8 Summary of Risk of Bias Assessment for Carbon Disulfide—Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables?^*^ | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization?^*^ | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Cardiovascular effects
Retrospective cohort studies
Bortkiewicz et al. 1997 | ++ | + | + | – | + | ++ | Second
Bortkiewicz et al. 2001 | ++ | + | + | – | + | ++ | Second
Chang et al. 2007 | + | + | + | – | + | ++ | Second
Franco et al. 1982 | ++ | – | ++ | – | + | ++ | Second
Jhun et al. 2007 | + | – | ++ | – | + | ++ | Second
Jhun et al. 2009 | + | – | ++ | – | + | ++ | Second
Kamal et al. 1991 | + | – – | ++ | – – | + | ++ | Second
Kim et al. 2000 | + | – | ++ | + | – | ++ | Second
Kotseva and De Bacquer 2000 | ++ | + | ++ | – | + | ++ | Second
Kotseva et al. 2001 | + | + | ++ | – | + | ++ | Second
Liss and Finkelstein 1996 | – | – – | – | – – | – | + | Third
NIOSH 1984a | + | + | + | ++ | + | ++ | First
Reinhardt et al. 1997a | + | – | + | – | – | + | Second
Schramm et al. 2016 | + | + | ++ | + | + | ++ | First
Sugimoto et al. 1978 | + | – | + | – – | + | + | Second
Sweetnam et al. 1987; Tiller et al. 1968 | – | – – | – | – – | – | + | Third
Tolonen et al. 1976 | + | – | + | + | + | + | Second
Vanhoorne et al. 1992a | – | + | + | – | + | ++ | Second
Prospective/Longitudinal cohort studies
Balcarova and Halik 1991 | – | – – | + | – | – | – | Third
Chrostek-Maj and Czeczotko 1995a | + | – – | – – | – – | – | – | Third
Finnish Longitudinal cohort studies (Hernberg and Tolonen 1981; Hernberg et al. 1970, 1973, 1976; Nurminen and Hernberg 1985; Nurminen et al. 1982; Tolonen et al. 1975, 1979) | ++ | – | ++ | – | + | ++ | Second
Swaen et al. 1994 | + | – – | + | – | – | ++ | Second
Takebayashi et al. 2004 | + | + | + | ++ | + | ++ | First
Vertin 1978 | – | – – | ++ | + | + | – | Second
Outcome: Altered lipid homeostasis (inhalation only)
Retrospective cohort studies
Chang et al. 2007 | + | – | + | – | ++ | ++ | Second
Cirla and Graziano 1981 | ++ | – | ++ | + | ++ | ++ | Second
Franco et al. 1982 | ++ | – | ++ | – | ++ | ++ | Second
Hernberg et al. 1971 | ++ | – | ++ | – | ++ | ++ | Second
Jhun et al. 2007 | + | – | ++ | – | ++ | ++ | Second
Jhun et al. 2009 | + | – | ++ | – | ++ | ++ | Second
Kim et al. 2000 | + | – | ++ | + | – | ++ | Second
Kotseva and De Bacquer 2000 | ++ | + | ++ | – | ++ | ++ | Second
Kotseva et al. 2001 | + | + | ++ | – | ++ | ++ | Second
Luo et al. 2011 | – | – | ++ | – | ++ | ++ | Second
NIOSH 1984a | + | + | + | ++ | + | ++ | First
Schramm et al. 2016 | + | – | ++ | + | ++ | ++ | Second
Sidorowicz et al. 1980 | – | – – | ++ | – – | ++ | + | Third
Stanosz et al. 1994b | + | – – | ++ | – | ++ | ++ | Second
Sugimoto et al. 1978 | + | – | + | – – | ++ | + | Second
Vanhoorne et al. 1992a | – | + | + | – | ++ | + | Second
Prospective/longitudinal cohort studies
Chrostek-Maj and Czeczotko 1995a | + | – – | – – | – – | ++ | – | Third
Takebayashi et al. 2004 | + | – | + | ++ | ++ | ++ | Second
Raitta et al. 1974 | + | – | + | – – | ++ | ++ | Second
Vertin 1978 | – | – – | ++ | + | + | – | Second
Outcome: Ophthalmological effects (inhalation only)
Retrospective cohort studies
Cirla and Graziano 1981 | ++ | – | ++ | + | ++ | ++ | Second
Kim et al. 2000 | + | – | ++ | + | – | ++ | Second
NIOSH 1984a | + | + | + | ++ | – | ++ | Second
Sugimoto et al. 1976 | – | – | + | – – | + | ++ | Second
Sugimoto et al. 1977 | + | – | + | – – | + | ++ | Second
Sugimoto et al. 1978 | + | – | + | – – | ++ | + | Second
Vanhoorne et al. 1996 | + | + | + | – | ++ | ++ | Second
Longitudinal cohort studies
Raitta et al. 1974 | + | – | + | – – | ++ | ++ | Second
Raitta and Tolonen 1975 | + | – | + | – – | + | ++ | Second
Outcome: Neurological effects
Retrospective cohort studies
Chang et al. 2003 | – | + | ++ | – | ++ | ++ | Second
Cirla and Graziano 1981 | ++ | – | ++ | + | + | ++ | Second
Godderis et al. 2006 | + | + | ++ | + | + | ++ | First
Foa et al. 1976 | + | – | + | – | + | ++ | Second
Hirata et al. 1996 | + | – | + | + | ++ | ++ | Second
Johnson et al. 1983; NIOSH 1984a | + | – | ++ | + | ++ | ++ | Second
Kim et al. 2000 | + | – | ++ | + | + | ++ | Second
Raitta et al. 1981 | + | + | + | – – | + | ++ | Second
Reinhardt et al. 1997a | + | – | + | + | ++ | + | Second
Reinhardt et al. 1997b | + | – | + | + | ++ | + | Second
Ruijten et al. 1990 | + | – | + | + | ++ | + | Second
Ruijten et al. 1993 | + | – | + | + | ++ | + | Second
Seppalainen and Tolonen 1974 | + | – – | – | – – | ++ | + | Second
Vanhoorne et al. 1995 | + | + | – | – | ++ | ++ | Second
Vanhoorne et al. 1996 | + | + | + | – | ++ | ++ | Second
Prospective/longitudinal cohort studies
Cassitto et al. 1993 | – | – | – | – | – | – | Third
Chrostek-Maj and Czeczotko 1995b | + | – – | – – | – – | – | + | Third
Nishiwaki et al. 2004 | + | + | + | ++ | ++ | ++ | First
Raitta et al. 1974 | + | – | + | – – | ++ | ++ | Second
Yoshioka et al. 2017 | + | + | + | ++ | ++ | ++ | First
Outcome: Male reproductive effects
Retrospective cohort studies
Cirla et al. 1978 | + | – | – | – | – | + | Third
Guo et al. 2016 | + | – | + | ++ | ++ | ++ | Second
NIOSH 1983 | + | + | + | + | – | + | Second
NIOSH 1984a | + | + | + | ++ | – | ++ | Second
Takebayashi et al. 2003 | + | + | + | + | – | ++ | Second
Vanhoorne et al. 1993 | + | – | + | – | + | ++ | Second
Vanhoorne et al. 1994 (Study 1) | + | – | + | – | – | + | Second
Vanhoorne et al. 1994 (Study 2) | + | – | + | – | – | + | Second
Wägar et al. 1981 | + | – | + | – | + | ++ | Second
Wägar et al. 1983 | + | – | + | – | + | ++ | Second
Outcome: Developmental effects
Retrospective cohort studies
Zhou et al. 1988 | + | – | + | + | – | – | Second

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

Table C-9 Summary of Risk of Bias Assessment for Carbon Disulfide—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Cardiovascular effects (inhalation only)
Inhalation acute-duration exposure
Lewis et al. 1999 | ++ | + | + | + | + | + | + | ++ | First
Tarkowski and Sobczak 1971 | – | + | + | – | – | – | – | + | Third
Inhalation intermediate-duration exposure
Antov et al. 1985 | – | + | + | + | + | – | – | ++ | Second
Lewis et al. 1999 | + | + | + | + | + | – | + | ++ | First
Morvai et al. 2005 | – | + | + | + | ++ | + | ++ | + | First
Phillips 1983a | ++ | + | + | + | + | ++ | ++ | ++ | First
Phillips 1983b | ++ | + | + | + | + | ++ | ++ | ++ | First
Phillips 1983c | ++ | + | + | + | + | ++ | ++ | ++ | First
Wrońska-Nofer et al. 1980 | – | + | + | + | + | – | + | ++ | First
Outcome: Ophthalmological effects (inhalation only)
Inhalation intermediate-duration exposure
Phillips 1983a | ++ | + | + | + | + | ++ | ++ | ++ | First
Phillips 1983b | ++ | + | + | + | + | ++ | ++ | ++ | First
Phillips 1983c | ++ | + | + | + | + | ++ | ++ | ++ | First
Outcome: Altered lipid homeostasis (inhalation only)
Inhalation acute-duration exposure
Freundt et al. 1974b | – | – | ++ | + | – | + | + | ++ | First
Simmons et al. 1988 | – | – | ++ | + | + | + | + | ++ | First
Simmons et al. 1989 | – | – | ++ | + | + | + | + | ++ | First
Inhalation intermediate-duration exposure
Wrońska-Nofer 1973 | – | – | ++ | + | + | – | + | ++ | First
Wrońska-Nofer 1972 | – | – | ++ | + | + | – | + | ++ | First
Inhalation chronic-duration exposure
Wrońska-Nofer et al. 1980 | – | – | + | + | + | – | + | ++ | First
Outcome: Neurological effects
Inhalation acute-duration exposure
Carreres Pons et al. 2017 | – | – | ++ | + | ++ | – | + | ++ | First
Denny and Gerhart 1991 (main study) | ++ | – – | + | + | ++ | ++ | – | ++ | Second
Herr et al. 1998; Moser et al. 1998; Sills et al. 1998a, 1998b; Valentine et al. 1997 (2 weeks) | ++ | – | ++ | + | + | + | ++ | + | First
Lehotzky et al. 1985 | – | – | + | – | ++ | – | – | ++ | Third
Liang et al. 1983 | – | – | + | – | – | + | – | + | Third
Magos 1970 | – | – | + | + | ++ | + | ++ | ++ | First
Magos et al. 1974 | – | – | + | + | + | – | ++ | ++ | First
Qingfen et al. 1999 | + | – | + | + | ++ | – | + | ++ | First
Tarkowski and Sobczak 1971 | – | – | + | + | ++ | – | ++ | ++ | First
Wilmarth et al. 1993 | – | – | + | + | ++ | + | + | ++ | First
Inhalation intermediate-duration exposure
Chalansonnet et al. 2018 | – | – | + | + | + | – | + | ++ | First
Clerici and Fechter 1991 | – | – | + | + | ++ | – | + | ++ | First
Eskin et al. 1988 | – | – | + | + | ++ | – | – | ++ | Second
Frantik 1970 | – | – | + | – | + | – | – | – | Third
Graham and Popp 1992a; Phillips 1983a | ++ | – | ++ | + | ++ | ++ | ++ | ++ | First
Graham and Popp 1992b; Phillips 1983b | ++ | – | ++ | + | ++ | ++ | ++ | ++ | First
Herr et al. 1998; Moser et al. 1998; Sills et al. 1998a, 1998b; Valentine et al. 1997 (4 weeks) | ++ | – | ++ | + | + | + | ++ | + | First
Herr et al. 1998; Moser et al. 1998; Sills et al. 1998a, 1998b; Valentine et al. 1997 (8 weeks) | ++ | – | ++ | + | + | + | ++ | + | First
Herr et al. 1998; Moser et al. 1998; Sills et al. 1998a, 1998b; Valentine et al. 1997 (13 week) | ++ | – | ++ | + | + | + | ++ | + | First
Hirata et al. 1992 | – | – | ++ | + | ++ | – | ++ | ++ | First
Merigan et al. 1988 | – | – | + | + | ++ | – | – | ++ | Second
Morvai et al. 2005 | – | – | ++ | + | ++ | + | ++ | ++ | First
Phillips 1983c | ++ | – | ++ | + | ++ | ++ | ++ | ++ | First
Qingfen et al. 1999 | + | – | + | + | ++ | – | + | ++ | First
Rebert and Becker 1986 | – | – | + | + | + | ++ | ++ | ++ | First
Wrońska-Nofer 1973 | – | – | – | + | + | – | – | ++ | First
Oral acute-duration exposure
Kanada et al. 1994 | – | – | + | + | – | – | + | ++ | Second
NCTR 1984a (preliminary) | ++ | ++ | ++ | ++ | ++ | ++ | + | ++ | First
NCTR 1984a (teratology) | ++ | ++ | ++ | ++ | ++ | ++ | + | ++ | First
NCTR 1984b (preliminary) | ++ | ++ | ++ | ++ | ++ | ++ | + | ++ | First
NCTR 1984b (teratology) | ++ | ++ | ++ | ++ | ++ | ++ | + | ++ | First
Oral intermediate-duration exposure
Gao et al. 2014; Wang et al. 2016 | + | – | ++ | – | ++ | + | – | ++ | Second
Liu et al. 2023 | – | – | + | – | + | – | + | ++ | Second
Liu et al. 2024 | – | – | + | – | + | – | + | ++ | Second
Song et al. 2009 | + | – | ++ | – | – | + | – | ++ | Third
Wang et al. 2017 | + | – | ++ | – | ++ | ++ | + | ++ | First
Outcome: Male reproductive effects (inhalation only)
Inhalation acute-duration exposure
NIOSH 1980 (mouse) | + | – – | + | + | + | + | – | ++ | Second
NIOSH 1980 (rat) | + | – – | + | + | + | + | – | ++ | Second
Sills et al. 1998b (2 weeks) | ++ | – | ++ | + | + | + | ++ | + | First
Zenick et al. 1984 | – | + | + | + | – | + | + | ++ | First
Inhalation intermediate-duration exposure
Guo et al. 2014 | + | + | + | + | ++ | + | + | ++ | First
Guo et al. 2015 | + | + | + | + | + | + | + | ++ | First
Huang et al. 2012 | + | + | + | ++ | + | – | ++ | ++ | First
Phillips 1983a | ++ | + | + | + | + | ++ | ++ | ++ | First
Phillips 1983b | ++ | + | + | + | + | ++ | ++ | ++ | First
Phillips 1983c | ++ | + | + | + | + | ++ | ++ | ++ | First
Sills et al. 1998b (4 weeks) | ++ | – | ++ | + | + | + | ++ | + | First
Sills et al. 1998b (8 weeks) | ++ | – | ++ | + | + | + | ++ | + | First
Sills et al. 1998b (13 weeks) | ++ | – | ++ | + | + | + | ++ | + | First
Tepe and Zenick 1984 (Study 1) | – | – | + | – | + | – | – | ++ | Second
Tepe and Zenick 1984 (Study 2) | – | + | + | + | + | – | + | ++ | First
Zenick et al. 1984 | – | + | + | + | – | + | + | ++ | First
Outcome: Developmental effects
Inhalation acute-duration exposure
Denny and Gerhart 1991 (dose-range finding) | ++ | + | ++ | + | ++ | + | – | ++ | Second
Denny and Gerhart 1991 (main study) | ++ | + | ++ | + | ++ | + | + | ++ | First
Hardin et al. 1981; NIOSH 1980 (rat, gestation) | + | – | ++ | + | ++ | – | + | ++ | First
Lehotzky et al. 1985 | – | – | + | – | – | – | – | – | Third
Inhalation intermediate-duration exposure
Hardin et al. 1981; NIOSH 1980 (rabbit, gestation) | + | – | ++ | + | ++ | – | + | ++ | First
Holson 1992 | ++ | – | ++ | + | ++ | + | + | ++ | First
NIOSH 1980 (rat, premate) | + | – | ++ | + | ++ | – | + | ++ | First
NIOSH 1980 (rabbit, premate) | + | – | ++ | + | ++ | – | + | ++ | First
Saillenfait et al. 1989 | + | – | ++ | + | ++ | + | + | ++ | First
Tabacova and Balabaeva 1980; Tabacova et al. 1978, 1983 | – | – | + | – | – | – | – | ++ | Third
Oral acute-duration exposure
NCTR 1984a (teratology) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | First
NCTR 1984b (preliminary) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | First
NCTR 1984b (teratology) | ++ | ++ | ++ | ++ | ++ | ++ | ++ | ++ | First
Tsai et al. 2000 | – | – | + | + | ++ | – | + | ++ | First

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to carbon disulfide and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to carbon disulfide and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-10, C-11, and C-12, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-10 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-11 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-12 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining cardiovascular, altered lipid homeostasis, ophthalmological, neurological, male reproductive, and developmental effects observed in the observational epidemiology and animal experimental studies are presented in Tables C-13 and C-14, respectively.

Table C-13 Presence of Key Features of Study Design for Carbon Disulfide—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Cardiovascular effects
Retrospective cohort studies
Bortkiewicz et al. 1997 | No | Yes | Yes | Yes | Moderate
Bortkiewicz et al. 2001 | No | Yes | Yes | Yes | Moderate
Chang et al. 2007 | No | Yes | Yes | Yes | Moderate
Franco et al. 1982 | No | Yes | Yes | Yes | Moderate
Jhun et al. 2007 | No | Yes | Yes | Yes | Moderate
Jhun et al. 2009 | No | Yes | Yes | Yes | Moderate
Kamal et al. 1991 | No | Yes | Yes | Yes | Moderate
Kim et al. 2000 | No | Yes | Yes | Yes | Moderate
Kotseva and De Bacquer 2000 | No | Yes | Yes | Yes | Moderate
Kotseva et al. 2001 | No | Yes | Yes | Yes | Moderate
Liss and Finkelstein 1996 | No | Yes | No | Yes | Low
NIOSH 1984a | No | Yes | Yes | Yes | Moderate
Reinhardt et al. 1997a | No | Yes | Yes | Yes | Moderate
Schramm et al. 2016 | No | Yes | Yes | Yes | Moderate
Sugimoto et al. 1978 | No | Yes | Yes | Yes | Moderate
Sweetnam et al. 1987; Tiller et al. 1968 | No | Yes | No | Yes | Low
Tolonen et al. 1976 | No | Yes | Yes | Yes | Moderate
Vanhoorne et al. 1992a | No | Yes | Yes | Yes | Moderate
Prospective/longitudinal cohort studies
Balcarova and Halik 1991 | No | Yes | Yes | Yes | Moderate
Chrostek-Maj and Czeczotko 1995a | No | Yes | Yes | Yes | Moderate
Finnish Longitudinal cohort studies (Hernberg and Tolonen 1981; Hernberg et al. 1970, 1973, 1976; Nurminen and Hernberg 1985; Nurminen et al. 1982; Tolonen et al. 1975, 1979) | No | Yes | Yes | Yes | Moderate
Swaen et al. 1994 | No | Yes | Yes | Yes | Moderate
Takebayashi et al. 2004 | No | Yes | Yes | Yes | Moderate
Vertin 1978 | No | Yes | Yes | No | Low
Outcome: Altered lipid homeostasis (inhalation only)
Retrospective cohort studies
Chang et al. 2007 | No | Yes | Yes | Yes | Moderate
Cirla and Graziano 1981 | No | Yes | Yes | Yes | Moderate
Franco et al. 1982 | No | Yes | Yes | Yes | Moderate
Hernberg et al. 1971 | No | Yes | Yes | Yes | Moderate
Jhun et al. 2007 | No | Yes | Yes | Yes | Moderate
Jhun et al. 2009 | No | Yes | Yes | Yes | Moderate
Kim et al. 2000 | No | Yes | Yes | Yes | Moderate
Kotseva and De Bacquer 2000 | No | Yes | Yes | Yes | Moderate
Kotseva et al. 2001 | No | Yes | Yes | Yes | Moderate
Luo et al. 2011 | No | Yes | Yes | Yes | Moderate
NIOSH 1984a | No | Yes | Yes | Yes | Moderate
Schramm et al. 2016 | No | Yes | Yes | Yes | Moderate
Sidorowicz et al. 1980 | No | Yes | Yes | No | Low
Stanosz et al. 1994b | No | Yes | Yes | Yes | Moderate
Sugimoto et al. 1978 | No | Yes | Yes | Yes | Moderate
Vanhoorne et al. 1992a | No | Yes | Yes | Yes | Moderate
Prospective/longitudinal cohort studies
Chrostek-Maj and Czeczotko 1995a | No | Yes | Yes | Yes | Moderate
Takebayashi et al. 2004 | No | Yes | Yes | Yes | Moderate
Raitta et al. 1974 | No | Yes | Yes | Yes | Moderate
Vertin 1978 | No | Yes | Yes | No | Low
Outcome: Ophthalmological effects (inhalation only)
Retrospective cohort studies
Cirla and Graziano 1981 | No | Yes | Yes | Yes | Moderate
Kim et al. 2000 | No | Yes | Yes | Yes | Moderate
NIOSH 1984a | No | Yes | Yes | Yes | Moderate
Sugimoto et al. 1976 | No | Yes | Yes | Yes | Moderate
Sugimoto et al. 1977 | No | Yes | Yes | Yes | Moderate
Sugimoto et al. 1978 | No | Yes | Yes | Yes | Moderate
Vanhoorne et al. 1996 | No | Yes | Yes | Yes | Moderate
Raitta et al. 1974 | No | Yes | Yes | Yes | Moderate
Raitta and Tolonen 1975 | No | Yes | Yes | Yes | Moderate
Outcome: Neurological effects
Retrospective cohort studies
Chang et al. 2003 | No | Yes | Yes | No | Low
Cirla and Graziano 1981 | No | Yes | Yes | Yes | Moderate
Godderis et al. 2006 | No | Yes | Yes | Yes | Moderate
Foa et al. 1976 | No | Yes | Yes | Yes | Moderate
Hirata et al. 1996 | No | Yes | Yes | Yes | Moderate
Johnson et al. 1983; NIOSH 1984a | No | Yes | Yes | Yes | Moderate
Kim et al. 2000 | No | Yes | Yes | Yes | Moderate
Raitta et al. 1981 | No | Yes | Yes | Yes | Moderate
Reinhardt et al. 1997a | No | Yes | Yes | Yes | Moderate
Reinhardt et al. 1997b | No | Yes | Yes | Yes | Moderate
Ruijten et al. 1990 | No | Yes | Yes | Yes | Moderate
Ruijten et al. 1993 | No | Yes | Yes | Yes | Moderate
Seppalainen and Tolonen 1974 | No | Yes | Yes | Yes | Moderate
Vanhoorne et al. 1995 | No | Yes | Yes | Yes | Moderate
Vanhoorne et al. 1996 | No | Yes | Yes | Yes | Moderate
Prospective/longitudinal cohort studies
Cassitto et al. 1993 | No | Yes | Yes | Yes | Moderate
Chrostek-Maj and Czeczotko 1995b | No | Yes | Yes | Yes | Moderate
Nishiwaki et al. 2004 | No | Yes | Yes | Yes | Moderate
Raitta et al. 1974 | No | Yes | Yes | Yes | Moderate
Yoshioka et al. 2017 | No | Yes | Yes | Yes | Moderate
Outcome: Male reproductive effects
Retrospective cohort studies
Cirla et al. 1978 | No | Yes | Yes | Yes | Moderate
Guo et al. 2016 | No | Yes | Yes | Yes | Moderate
NIOSH 1983 | No | Yes | Yes | Yes | Moderate
NIOSH 1984a | No | Yes | Yes | Yes | Moderate
Takebayashi et al. 2003 | No | Yes | Yes | Yes | Moderate
Vanhoorne et al. 1993 | No | Yes | Yes | Yes | Moderate
Vanhoorne et al. 1994 (Study 1) | No | Yes | Yes | Yes | Moderate
Vanhoorne et al. 1994 (Study 2) | No | Yes | Yes | Yes | Moderate
Wägar et al. 1981 | No | Yes | Yes | Yes | Moderate
Wägar et al. 1983 | No | Yes | Yes | Yes | Moderate
Outcome: Developmental effects
Retrospective cohort studies
Zhou et al. 1988 | No | Yes | Yes | Yes | Moderate

Table C-14 Presence of Key Features of Study Design for Carbon Disulfide—Experimental Animal Studies

Reference | Key features | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Cardiovascular effects (inhalation only)
Inhalation acute-duration exposure
Lewis et al. 1999 | Yes | Yes | Yes | Yes | High
Tarkowski and Sobczak 1971 | Yes | Yes | Yes | No | Low
Inhalation intermediate-duration exposure
Antov et al. 1985 | Yes | Yes | Yes | No | Moderate
Lewis et al. 1999 | Yes | Yes | Yes | Yes | High
Morvai et al. 2005 | Yes | Yes | Yes | Yes | High
Phillips 1983a | Yes | Yes | Yes | Yes | High
Phillips 1983b | Yes | Yes | Yes | Yes | High
Phillips 1983c | Yes | Yes | Yes | Yes | High
Wrońska-Nofer et al. 1980 | Yes | Yes | Yes | Yes | High
Outcome: Ophthalmological effects (inhalation only)
Inhalation intermediate-duration exposure
Phillips 1983a | Yes | Yes | Yes | Yes | High
Phillips 1983b | Yes | Yes | Yes | Yes | High
Phillips 1983c | Yes | Yes | Yes | Yes | High
Outcome: Altered lipid homeostasis (inhalation only)
Inhalation acute-duration exposure
Freundt et al. 1974b | Yes | Yes | No | Yes | Moderate
Simmons et al. 1988 | Yes | Yes | Yes | Yes | High
Simmons et al. 1989 | Yes | No | Yes | Yes | Moderate
Inhalation intermediate-duration exposure
Wrońska-Nofer 1973 | Yes | Yes | Yes | Yes | High
Wrońska-Nofer 1972 | Yes | Yes | Yes | Yes | High
Inhalation chronic-duration exposure
Wrońska-Nofer et al. 1980 | Yes | Yes | Yes | Yes | High
Outcome: Neurological effects
Inhalation acute-duration exposure
Carreres Pons et al. 2017 | Yes | Yes | Yes | Yes | High
Denny and Gerhart 1991 (main study) | Yes | Yes | Yes | Yes | High
Herr et al. 1998; Moser et al. 1998 (2 week) | Yes | Yes | Yes | Yes | High
Lehotzky et al. 1985 | Yes | No | Yes | No | Moderate
Liang et al. 1983 | No | No | Yes | No | Low
Magos 1970 | Yes | Yes | Yes | Yes | High
Magos et al. 1974 | Yes | Yes | Yes | Yes | High
Qingfen et al. 1999 | Yes | Yes | Yes | Yes | High
Tarkowski and Sobczak 1971 | Yes | Yes | Yes | No | Moderate
Wilmarth et al. 1993 | Yes | Yes | Yes | No | Moderate
Inhalation intermediate-duration exposure
Chalansonnet et al. 2018 | Yes | Yes | Yes | Yes | High
Clerici and Fechter 1991 | Yes | No | Yes | Yes | Moderate
Eskin et al. 1988 | Yes | No | Yes | No | Low
Frantik 1970 | Yes | Yes | No | No | Low
Graham and Popp 1992a; Phillips 1983a | Yes | Yes | Yes | Yes | High
Graham and Popp 1992b; Phillips 1983b | Yes | Yes | Yes | Yes | High
Herr et al. 1998; Moser et al. 1998 (4 weeks) | Yes | Yes | Yes | Yes | High
Herr et al. 1998; Moser et al. 1998 (8 weeks) | Yes | Yes | Yes | Yes | High
Herr et al. 1998; Moser et al. 1998 (13 weeks) | Yes | Yes | Yes | Yes | High
Hirata et al. 1992 | Yes | Yes | Yes | Yes | High
Merigan et al. 1988 | Yes | No | Yes | No | Low
Morvai et al. 2005 | Yes | Yes | No | No | Low
Phillips 1983c | Yes | Yes | Yes | Yes | High
Qingfen et al. 1999 | Yes | Yes | Yes | Yes | High
Rebert and Becker 1986 | Yes | No | Yes | Yes | Moderate
Wrońska-Nofer 1973 | Yes | Yes | No | No | Low
Oral acute-duration exposure
Kanada et al. 1994 | No | Yes | Yes | Yes | Moderate
NCTR 1984a (preliminary) | Yes | Yes | Yes | No | Moderate
NCTR 1984a (teratology) | Yes | Yes | Yes | Yes | High
NCTR 1984b (preliminary) | Yes | Yes | Yes | Yes | High
NCTR 1984b (teratology) | Yes | Yes | Yes | Yes | High
Oral intermediate-duration exposure
Gao et al. 2014; Wang et al. 2016 | Yes | Yes | Yes | Yes | High
Liu et al. 2023 | Yes | No | Yes | No | Low
Liu et al. 2024 | Yes | Yes | Yes | Yes | High
Song et al. 2009 | Yes | Yes | Yes | Yes | High
Wang et al. 2017 | Yes | Yes | Yes | Yes | High
Outcome: Male reproductive effects (inhalation only)
Inhalation acute-duration exposure
NIOSH 1980 (mouse) | Yes | Yes | No | Yes | Moderate
NIOSH 1980 (rat) | Yes | Yes | No | Yes | Moderate
Sills et al. 1998b (2 weeks) | Yes | Yes | No | No | Low
Zenick et al. 1984 | Yes | Yes | Yes | Yes | High
Inhalation intermediate-duration exposure
Guo et al. 2014 | Yes | Yes | Yes | No | Moderate
Guo et al. 2015 | Yes | Yes | Yes | No | Moderate
Huang et al. 2012 | Yes | Yes | Yes | Yes | High
Phillips 1983a | Yes | Yes | No | Yes | Moderate
Phillips 1983b | Yes | Yes | No | Yes | Moderate
Phillips 1983c | Yes | Yes | No | Yes | Moderate
Sills et al. 1998b (4 weeks) | Yes | Yes | No | No | Low
Sills et al. 1998b (8 weeks) | Yes | Yes | No | No | Low
Sills et al. 1998b (13 weeks) | Yes | Yes | No | No | Low
Tepe and Zenick 1984 (Study 1) | Yes | Yes | Yes | Yes | High
Tepe and Zenick 1984 (Study 2) | Yes | Yes | Yes | Yes | High
Zenick et al. 1984 | Yes | Yes | Yes | Yes | High
Outcome: Developmental effects
Inhalation acute-duration exposure
Denny and Gerhart 1991 (range-finding) | No | No | Yes | Yes | Low
Denny and Gerhart 1991 (main study) | Yes | Yes | Yes | Yes | High
NIOSH 1980 (rat) | Yes | Yes | Yes | Yes | High
Lehotzky et al. 1985 | Yes | No | No | Yes | Low
Inhalation intermediate-duration exposure
NIOSH 1980 (rabbit) | Yes | Yes | Yes | Yes | High
Holson 1992 | Yes | Yes | Yes | Yes | High
NIOSH 1980 (rat) | Yes | Yes | Yes | Yes | High
NIOSH 1980 (rabbit) | Yes | Yes | Yes | Yes | High
Saillenfait et al. 1989 | Yes | Yes | Yes | Yes | High
Tabacova et al. 1983 | Yes | Yes | Yes | Yes | High
Oral acute-duration exposure
NCTR 1984a | Yes | Yes | Yes | Yes | High
NCTR 1984b (preliminary) | Yes | Yes | No | Yes | Moderate
NCTR 1984b (teratology) | Yes | Yes | Yes | Yes | High
Tsai et al. 2000 | Yes | Yes | Yes | Yes | High

A summary of the initial confidence ratings for each outcome is presented in Table C-15. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-15.

Table C-15 Initial Confidence Rating for Carbon Disulfide Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Cardiovascular effects (inhalation only)
Inhalation acute-duration exposure
Animal studies
Lewis et al. 1999 | High | High
Tarkowski and Sobczak 1971 | Low | High
Inhalation acute-duration exposure
Animal studies
Antov et al. 1985 | Moderate | High
Lewis et al. 1999 | High | High
Morvai et al. 2005 | High | High
Phillips 1983a | High | High
Phillips 1983b | High | High
Phillips 1983c | High | High
Inhalation chronic-duration exposure
Human studies
Balcarova and Halik 1991 | Moderate | Moderate
Bortkiewicz et al. 1997 | Moderate | Moderate
Bortkiewicz et al. 2001 | Moderate | Moderate
Chang et al. 2007 | Moderate | Moderate
Chrostek-Maj and Czeczotko 1995a | Moderate | Moderate
Finnish Longitudinal cohort studies (Hernberg and Tolonen 1981; Hernberg et al. 1970, 1973, 1976; Nurminen and Hernberg 1985; Nurminen et al. 1982; Tolonen et al. 1975, 1979) | Moderate | Moderate
Franco et al. 1982 | Moderate | Moderate
Jhun et al. 2007 | Moderate | Moderate
Jhun et al. 2009 | Moderate | Moderate
Kamal et al. 1991 | Moderate | Moderate
NIOSH 1984a | Moderate | Moderate
Kim et al. 2000 | Moderate | Moderate
Kotseva and De Bacquer 2000 | Moderate | Moderate
Kotseva et al. 2001 | Moderate | Moderate
Liss and Finkelstein 1996 | Low | Moderate
Reinhardt et al. 1997a | Moderate | Moderate
Schramm et al. 2016 | Moderate | Moderate
Sugimoto et al. 1978 | Moderate | Moderate
Swaen et al. 1994 | Moderate | Moderate
Takebayashi et al. 2004 | Moderate | Moderate
Sweetnam et al. 1987; Tiller et al. 1968 | Low | Moderate
Tolonen et al. 1976 | Moderate | Moderate
Vanhoorne et al. 1992a | Moderate | Moderate
Vertin 1978 | Low | Moderate
Outcome: Altered lipid homeostasis (inhalation only)
Inhalation acute-duration exposure
Animal studies
Freundt et al. 1974b | Moderate | High
Simmons et al. 1988 | High | High
Simmons et al. 1989 | Moderate | High
Inhalation intermediate-duration exposure
Animal studies
Wrońska-Nofer 1973 | High | High
Wrońska-Nofer 1972 | High | High
Inhalation chronic-duration exposure
Human studies
Chang et al. 2007 | Moderate | Moderate
Chrostek-Maj and Czeczotko 1995a | Moderate | Moderate
Cirla and Graziano 1981 | Moderate | Moderate
Franco et al. 1982 | Moderate | Moderate
Hernberg et al. 1971 | Moderate | Moderate
Jhun et al. 2007 | Moderate | Moderate
Jhun et al. 2009 | Moderate | Moderate
Kim et al. 2000 | Moderate | Moderate
Kotseva and De Bacquer 2000 | Moderate | Moderate
Kotseva et al. 2001 | Moderate | Moderate
Luo et al. 2011 | Moderate | Moderate
NIOSH 1984a | Moderate | Moderate
Raitta et al. 1974 | Moderate | Moderate
Schramm et al. 2016 | Moderate | Moderate
Sidorowicz et al. 1980 | Low | Moderate
Stanosz et al. 1994b | Moderate | Moderate
Sugimoto et al. 1978 | Moderate | Moderate
Takebayashi et al. 2004 | Moderate | Moderate
Vanhoorne et al. 1992a | Moderate | Moderate
Vertin 1978 | Low | Moderate
Animal studies
Wrońska-Nofer et al. 1980 | High | High
Outcome: Ophthalmological effects (inhalation only)
Inhalation intermediate-duration exposure
Animal studies
Phillips 1983a | High | High
Phillips 1983b | High | High
Phillips 1983c | High | High
Inhalation chronic-duration exposure
Human studies
Cirla and Graziano 1981 | Moderate | Moderate
Kim et al. 2000 | Moderate | Moderate
NIOSH 1984a | Moderate | Moderate
Sugimoto et al. 1976 | Moderate | Moderate
Sugimoto et al. 1977 | Moderate | Moderate
Sugimoto et al. 1978 | Moderate | Moderate
Vanhoorne et al. 1996 | Moderate | Moderate
Raitta et al. 1974 | Moderate | Moderate
Raitta and Tolonen 1975 | Moderate | Moderate
Outcome: Neurological effects
Inhalation acute-duration exposure
Animal studies
Carreres Pons et al. 2017 | High | High
Denny and Gerhart 1991 (main study) | High | High
Herr et al. 1998; Moser et al. 1998 (2 weeks) | High | High
Lehotzky et al. 1985 | Moderate | High
Liang et al. 1983 | Low | High
Magos 1970 | High | High
Magos et al. 1974 | High | High
Qingfen et al. 1999 | High | High
Tarkowski and Sobczak 1971 | Moderate | High
Wilmarth et al. 1993 | Moderate | High
Inhalation intermediate-duration exposure
Animal studies
Chalansonnet et al. 2018 | High | High
Clerici and Fechter 1991 | Moderate | High
Eskin et al. 1988 | Low | High
Frantik 1970 | Low | High
Graham and Popp 1992a; Phillips 1983a | High | High
Graham and Popp 1992b; Phillips 1983b | High | High
Herr et al. 1998; Moser et al. 1998 (4 weeks) | High | High
Herr et al. 1998; Moser et al. 1998 (8 weeks) | High | High
Herr et al. 1998; Moser et al. 1998 (13 weeks) | High | High
Hirata et al. 1992 | High | High
Merigan et al. 1988 | Low | High
Morvai et al. 2005 | Low | High
Phillips 1983c | High | High
Qingfen et al. 1999 | High | High
Rebert and Becker 1986 | Moderate | High
Wrońska-Nofer 1973 | Low | High
Inhalation chronic-duration exposure
Human studies
Chang et al. 2003 | Low | Moderate
Cirla and Graziano 1981 | Moderate | Moderate
Godderis et al. 2006 | Moderate | Moderate
Foa et al. 1976 | Moderate | Moderate
Hirata et al. 1996 | Moderate | Moderate
Johnson et al. 1983 | Moderate | Moderate
Kim et al. 2000 | Moderate | Moderate
Raitta and Tolonen 1975 | Moderate | Moderate
Reinhardt et al. 1997a | Moderate | Moderate
Reinhardt et al. 1997b | Moderate | Moderate
Ruijten et al. 1990 | Moderate | Moderate
Ruijten et al. 1990 | Moderate | Moderate
Seppalainen and Tolonen 1974 | Moderate | Moderate
Vanhoorne et al. 1995 | Moderate | Moderate
Vanhoorne et al. 1996 | Moderate | Moderate
Cassitto et al. 1993 | Moderate | Moderate
Chrostek-Maj and Czeczotko 1995b | Moderate | Moderate
Nishiwaki et al. 2004 | Moderate | Moderate
Raitta et al. 1974 | Moderate | Moderate
Yoshioka et al. 2017 | Moderate | Moderate
Oral acute-duration exposure
Animal studies
Kanada et al. 1994 | Moderate | High
NCTR 1984a (preliminary) | Moderate | High
NCTR 1984a (teratology) | High | High
NCTR 1984b (preliminary) | High | High
NCTR 1984b (teratology) | High | High
Oral intermediate-duration exposure
Animal studies
Gao et al. 2014; Wang et al. 2016 | High | High
Liu et al. 2023 | Low | High
Liu et al. 2024 | High | High
Song et al. 2009 | High | High
Wang et al. 2017 | High | High
Outcome: Male reproductive effects (inhalation only)
Inhalation acute-duration exposure
Animal studies
NIOSH 1980 (rat) | Moderate | High
NIOSH 1980 (rat) | Moderate | High
Sills et al. 1998b (2 weeks) | Low | High
Zenick et al. 1984 | High | High
Inhalation intermediate-duration exposure
Animal studies
Guo et al. 2014 | Moderate | High
Guo et al. 2015 | Moderate | High
Huang et al. 2012 | High | High
Phillips 1983a | Moderate | High
Phillips 1983b | Moderate | High
Phillips 1983c | Moderate | High
Sills et al. 1998b (4 weeks) | Low | High
Sills et al. 1998b (8 weeks) | Low | High
Sills et al. 1998b (13 weeks) | Low | High
Tepe and Zenick 1984 (Study 1) | High | High
Tepe and Zenick 1984 (Study 2) | High | High
Zenick et al. 1984 | High | High
Inhalation chronic-duration exposure
Human studies
Cirla et al. 1978 | Moderate | Moderate
Guo et al. 2016 | Moderate | Moderate
NIOSH 1983 | Moderate | Moderate
NIOSH 1984a | Moderate | Moderate
Takebayashi et al. 2003 | Moderate | Moderate
Vanhoorne et al. 1993 | Moderate | Moderate
Vanhoorne et al. 1994 (Study 1) | Moderate | Moderate
Vanhoorne et al. 1994 (Study 2) | Moderate | Moderate
Wägar et al. 1981 | Moderate
Wägar et al. 1983 | Moderate
Outcome: Developmental effects (inhalation only)
Inhalation chronic-duration exposure
Human studies
Zhou et al. 1988 | Moderate | Moderate
Inhalation acute-duration exposure
Animal studies
Denny and Gerhart 1991 (dose range-finding) | Low | High
Denny and Gerhart 1991 (main study) | High | High
NIOSH 1980 (rat) | High | High
Lehotzky et al. 1985 | Low | High
Inhalation intermediate-duration exposure
Animal studies
NIOSH 1980 (rabbit) | High | High
Holson 1992 | High | High
NIOSH 1980 (rat) | High | High
NIOSH 1980 (rabbit) | High | High
Saillenfait et al. 1989 | High | High
Tabacova et al. 1983 | High | High
Oral acute-duration exposure
NCTR 1984a | High | High
NCTR 1984b (preliminary) | Moderate | High
NCTR 1984b (teratology) | High | High
Tsai et al. 2000 | High | High

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for cardiovascular, altered lipid homeostasis, ophthalmological, neurological, male reproductive, and developmental effects are presented in Table C-16. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with carbon disulfide exposure is presented in Table C-17.

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-8 and C-9). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Table C-16 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Cardiovascular effects (inhalation only)
Human studies | Moderate | −1 Risk of bias; +1 Large magnitude of effect | Moderate
Animal studies | High | | High
Outcome: Altered lipid homeostasis (inhalation only)
Human studies | Moderate | −1 Risk of bias; −1 Unexplained inconsistency | Very low
Animal studies | High | −1 Unexplained inconsistency | Moderate
Outcome: Ophthalmological effects (inhalation only)
Human studies | Moderate | −1 Risk of bias; +1 Consistency in the body of evidence | Moderate
Animal studies | High | −1 Unexplained inconsistency (limited data) | Moderate
Outcome: Neurological effects
Human studies, inhalation only | Moderate | −1 Risk of bias; +1 Consistency in the body of evidence; +1 Dose response | High
Animal studies | High | +1 Consistency in the body of evidence; +1 Large magnitude of effect | High
Outcome: Male reproductive effects (inhalation only)
Human studies | Moderate | −1 Risk of bias; −1 Unexplained inconsistency | Very low
Animal studies | High | −1 Unexplained inconsistency | Moderate
Outcome: Developmental effects (inhalation only)
Human studies | Moderate | −1 Risk of bias | Low
Animal studies | High | −1 Unexplained inconsistency | Moderate

Table C-17 Confidence in the Body of Evidence for Carbon Disulfide

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Cardiovascular effects (inhalation only) | Moderate | High
Altered lipid homeostasis (inhalation only) | Very low | Moderate
Neurological effects | High | High
Male reproductive effects (inhalation only) | Very low | Moderate
Developmental effects | Low | Moderate

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for carbon disulfide, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for carbon disulfide is presented in Table C-18.

Table C-18 Level of Evidence of Health Effects for Carbon Disulfide

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies (inhalation only)
Cardiovascular | Moderate | Health effect | Moderate
Altered lipid homeostasis | Very low | Health effect | Inadequate
Ophthalmological effects | Moderate | Health effect | Moderate
Neurological effects | High | Health effect | High
Male reproductive | Very low | Health effect | Inadequate
Developmental | Low | No health effect | Inadequate
Animal studies
Cardiovascular (inhalation only) | High | Health effect | High
Altered lipid homeostasis (inhalation only) | Moderate | Health effect | Moderate
Ophthalmological effects (inhalation only) | Moderate | No health effect | Inadequate
Neurological effects | High | Health effect | High
Male reproductive (inhalation only) | Moderate | Health effect | Moderate
Developmental | Moderate | Health effect | Moderate

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Figure C-1 Hazard Identification Scheme

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for carbon disulfide are listed below and summarized in Table C-19.

Known Health Effects

- Neurological effects (inhalation)
  ○ Neurological effects are a commonly evaluated and reported endpoint in occupational cohorts exposed to carbon disulfide, particularly peripheral neuropathy.
    ■ At low concentrations (<10 ppm) findings include alterations in nerve conduction velocity (Hirata et al. 1996; Kim et al. 2000; Johnson et al. 1983; Ruijten et al. 1990, 1993; Seppalainen and Tolonen 1974; Vanhoorne et al. 1995; Yoshioka et al. 2017). Some of these studies also reported increased self-reported symptoms of polyneuropathy at exposure concentrations ranging from 0.43 to 36 ppm, such as pain, insensitive spots, paresthesia, numbness, and difficulty walking (Kim et al. 2000; Vanhoorne et al. 1994).
    ■ Studies indicate that neuropathy may be reversible at low concentrations (<10 ppm) but may be persistent at concentrations >20 ppm (Seppalainen and Tolonen 1974; Yoshioka et al. 2017).
    ■ Overt polyneuritis or polyneuropathy are common findings among highly exposed workers (≥100 ppm), including impaired nerve conduction, subjective complaints, decreased pain sensitivity, tremors, and abnormal movements resembling early Parkinsonism (Chapman et al. 1991; Chu et al. 1995; Lancranjan et al. 1972; Peters et al. 1988; Vasilescu 1976).
  ○ The nervous system is a sensitive endpoint of carbon disulfide toxicity in animals following inhalation exposure. The most common neurological findings include impaired peripheral nerve conduction velocity and behavioral/clinical evidence peripheral nerve damage (e.g., foot drag, hindlimb paralysis) (Frantik 1970; Graham and Popp 1992a; Herr et al. 1998; Phillips 1983a, 1983b, 1983c; Rebert and Becker 1986; Wrońska-Nofer 1973) and damage to the sensory nerve tracts in the spinal cord (Graham and Popp 1992a; Phillips 1983a, 1983b; Valentine et al. 1997).

Presumed Health Effects

- Cardiovascular effects (inhalation)
  ○ A meta-analysis by Tan et al. (2002) of 11 studies published between 1970 and 1996 determined a positive association between occupational exposure and prevalence of cardiovascular disease.
  ○ Increased risk of death from cardiovascular disease has been reported in several occupational cohorts of carbon disulfide exposure, particularly in past decades with higher occupational exposure levels (>10 ppm) (Section 2.5).
  ○ Increased prevalence of cardiovascular disease has also been reported in some workers exposed to carbon disulfide, including myocardial infarction, ischemic or coronary heart disease, and/or angina (Balcarova and Halik 1991; Hernberg et al. 1970; Kotseva et al. 2001; Takebayashi et al. 2004; Tolonen et al. 1975). However, others did not observe associations at similar exposure levels (Sugimoto et al. 1978; Tolonen et al. 1976; Vanhoorne et al. 1992a; Vertin 1978).
  ○ Evidence for associations between occupational carbon disulfide exposure and elevated blood pressure and abnormal ECGs are inconsistent (Section 2.5)
  ○ A limited number of inhalation studies in rats have reported altered cardiac function following exposure to carbon disulfide, including decreased cardiac rate (Tarkowski and Sobczak 1971) and increased blood pressure and decreased cardiac output (Morvai et al. 2005).
  ○ While the cardiovascular system is not a sensitive target of oral exposure to carbon disulfide, atherosclerotic lesions occurred in animals exposed to carbon disulfide when also exposed to a high-fat diet (Antov et al. 1985; Lewis et al. 1999).
- Ophthalmological effects (inhalation)
  ○ Increased prevalence of retinal microaneurysms has been reported in several cohorts of viscose rayon workers from multiple countries, including the United States, Belgium Korea, and Japan (Kim et al. 2000; NIOSH 1984a; Sugimoto et al. 1976, 1977; Vanhoorne et al. 1996). In some cohorts, prevalence and severity was associated with both increased exposure concentration and duration.
  ○ There may be differences in susceptibility because retinal microaneurysms were not increased in a Finnish cohort with exposure concentrations comparable to, or higher than, effected cohorts from other countries, although mild changes in retinal hemodynamics were observed (Raitta et al. 1974; Sugimoto et al. 1977).
  ○ Ophthalmological data from animals are limited to a series of 90-day inhalation studies in rats and mice, which did not observe any adverse effects at concentrations up to 798.4 ppm for 90 days (Phillips 1983a, 1983b, 1983c).
- Neurological effects (oral)
  ○ No oral data in humans are available.
  ○ Oral data in animals are limited but available data report cognitive impairments and overt clinical signs at doses ≥200 mg/kg/day, including incoordination and gait impairments, lethargy, ataxia, tremor, paralysis, and convulsions (Gao et al. 2014; Liu et al. 2023, 2024; NCTR 1984a, 1984b; Song et al. 2009; Wang et al. 2016, 2017). Impaired caudal nerve conduction was reported at ≥300 mg/kg/day (Liu et al. 2024) and brain edema and cortical and hippocampal neuronal loss were reported at ≥400 mg/kg/day (Wang et al. 2017).

Suspected Health Effects

- Altered lipid homeostasis (inhalation)
  ○ Elevated serum cholesterol has been associated with increased cumulative carbon disulfide exposure in some cohorts of viscose rayon workers (Jhun et al. 2007; Kotseva and De Bacquer 2000; Stanosz et al. 1994b; Vanhoorne et al. 1992a), but not several others at similar exposure levels (Section 2.9).
  ○ In animals, elevated liver lipid synthesis, liver lipid/cholesterol content, and serum lipid and/or cholesterol levels have been observed in following acute-, intermediate-, and chronic-duration inhalation exposure (Freundt et al. 1974b; Wrońska-Nofer 1972, 1973; Wrońska-Nofer et al. 1980). However, data are available only from a few studies, and evaluations at low concentrations following repeated exposures are lacking. Confidence in the evidence was downgraded due to conflicting findings from acute-duration inhalation studies by Simmons et al. (1988, 1989), in which Simmons et al. (1988) reported decreased hepatic cholesterol synthesis and Simmons et al. (1989) reported no change in cholesterol synthesis at the same concentration. The study authors attributed the inconsistency to lack of statistical power in the later study; however, findings are still in conflict with elevated synthesis observed by Wrońska-Nofer (1972). This may be due to different methodology. Simmons et al. (1988) measured synthesis ex vivo, while Wrońska-Nofer (1972) measured synthesis in vivo. Additionally, Simmons et al. (1988) evaluated male F-344 rats after a 6-hour exposure and Wrońska-Nofer (1972) evaluated female Wistar rats after exposure for 8 months.
- Male reproductive effects (inhalation)
  ○ A few studies provide evidence of potential associations between self-reported impairments in male sexual function and occupational exposure to carbon disulfide (Vanhoorne et al. 1994; Wägar et al. 1981). However, there is no evidence of impaired fertility in male workers exposed to carbon disulfide (NIOSH 1983; Vanhoorne et al. 1994).
  ○ Evidence for associations between occupational carbon disulfide exposure and sperm damage or altered male reproductive hormone levels are inconsistent (Section 2.16).
  ○ Animal studies reported altered mating behaviors in male rats following inhalation exposure to carbon disulfide (Tepe and Zenick 1984; Zenick et al. 1984).
  ○ Similar to human data, findings in animals pertaining to altered sperm parameters, serum hormone levels, and histopathological changes the testes are inconsistent between studies (Section 2.16).
- Developmental effects (inhalation, oral)
  ○ Data in humans are limited to a single study that did not observe an association between occupational exposure during pregnancy and congenital malformations (Zhou et al. 1988).
  ○ Developmental effects (increased postimplantation loss, decreased fetal body weight, decreased neonatal viability) have been reported in both rats and rabbits following inhalation exposure during gestation to exposures >500 ppm, with visceral and skeletal malformations at >800 ppm (Denny and Gerhart 1991; Holson 1992; Saillenfait et al. 1989). Postnatal exposures ≥225 ppm were associated with delayed reflex ontology and impaired neurodevelopment (Lehotzky et al. 1985).
  ○ In contrast to traditional teratology studies described above, a series of studies utilizing a non-traditional two-generation exposure design reported malformations in F1 and F2 rats at ≥32 ppm (Tabacova and Balabaeva 1980; Tabacova et al. 1978, 1983). However, there are numerous limitations and discrepancies within and between these reports, including transiency of effects and low exposure levels, lack of examination of all endpoints at higher exposure levels, different control groups for lower and higher exposure groups, and lack of clear exposure-response.
  ○ Developmental effects have been observed both rats and rabbits in oral gestational exposure studies at ≥200 and 25 mg/kg/day, respectively (NCTR 1984a, 1984b). Another oral study in rats did not observe adverse developmental effects at concentrations up to 1,200 mg/kg/day (Tsai et al. 2000).

Table C-19 Hazard Identification Conclusions for Carbon Disulfide

Outcome | Hazard identification
Cardiovascular (inhalation) | Presumed
Altered lipid homeostasis (inhalation) | Suspected
Ophthalmological effects (inhalation) | Presumed
Neurological effects (inhalation) | Known
Neurological effects (oral) | Presumed
Male reproductive effects (inhalation) | Suspected
Developmental (inhalation, oral) | Suspected