# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR CARBON DISULFIDE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to carbon disulfide.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for carbon disulfide. ATSDR primarily focused on peer-reviewed articles without language restrictions. Foreign language studies are reviewed based on available English-language abstracts and/or tables (or summaries in regulatory assessments, such as International Agency for Research on Cancer [IARC] documents). If the study appears critical for hazard identification or MRL derivation, translation into English is requested. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of carbon disulfide have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of carbon disulfide are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen^a^

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

a Physical-chemical properties are not generally obtained from literature searches, but rather from curated governmental databases such as PubChem.

### B.1.1 Literature Search

The literature search was conducted to update the Toxicological Profile for Carbon Disulfide released in 1996. All literature cited in the previous (1996) toxicological profile were considered for inclusion in the updated profile. The initial literature search, which was performed in June 2022, was restricted to studies added to databases since January 1994. An updated literature search was performed after the Toxicological Profile for Carbon Disulfide Draft for Public Comment was released in October 2024 to identify any additional studies added to databases between January 2021 and January 2025.

The following main databases were searched in June 2022 and/or January 2025:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s Toxcenter

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for carbon disulfide. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to carbon disulfide were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
01/2025 | (75-15-0[rn] OR “Carbon Disulfide”[mh] OR “Carbon bisulfide”[tw] OR “Carbon bisulphide”[tw] OR “Carbon disulfide”[tw] OR “carbon disulphide”[tw] OR “Carbondisulfide”[tw] OR “Methanedithione”[tw] OR “Carbon sulfide (CS2)”[tw] OR “Dithiocarbonic anhydride”[tw] OR “Dithiocarbonic, anhydrous”[tw] OR “Sulphocarbonic anhydride”[tw] OR “Sulphuret of carbon”[tw] OR “Weeviltox”[tw]) AND (2021:3000[dp] OR 2022/06/01:3000[mhda] OR 2022/06/01:3000[edat] OR 2022/06/01:3000[crdat])
06/2022 | (75-15-0[rn] AND (1994:3000[dp] OR 1994:3000[mhda] OR 1994:3000[edat] OR 1994:3000[crdat])) OR (((“Carbon bisulfide”[tw] OR “Carbon bisulphide”[tw] OR “Carbon disulfide”[tw] OR “carbon disulphide”[tw] OR “Carbondisulfide”[tw] OR “Methanedithione”[tw] OR “Carbon sulfide (CS2) “[tw] OR “Dithiocarbonic anhydride”[tw] OR “Dithiocarbonic, anhydrous”[tw] OR “Sulphocarbonic anhydride”[tw] OR “Sulphuret of carbon”[tw] OR “Weeviltox”[tw]) AND (1994:3000[dp] OR 1994:3000[edat] OR 1994:3000[crdat])) NOT medline[sb])
NTRL
01/2025 | Limited to 2021 to present; “Carbon bisulfide” OR “Carbon bisulphide” OR “Carbon disulfide” OR “carbon disulphide” OR “Carbondisulfide” OR “Methanedithione” OR “Carbon sulfide” OR “Dithiocarbonic anhydride” OR “Dithiocarbonic, anhydrous” OR “Sulphocarbonic anhydride” OR “Sulphuret of carbon” OR “Weeviltox”
06/2022 | “Carbon bisulfide” OR “Carbon bisulphide” OR “Carbon disulfide” OR “carbon disulphide” OR “Carbondisulfide” OR “Methanedithione”; “Carbon sulfide”; “Dithiocarbonic anhydride” OR “Dithiocarbonic, anhydrous” OR “Sulphocarbonic anhydride” OR “Sulphuret of carbon” OR “Weeviltox”
Toxcenter
01/2025 | FILE ‘TOXCENTER’ ENTERED AT 17:52:17 ON 14 JAN 2025; CHARGED TO COST=ET027.02.03.LB.02; L1 16816 SEA 75-15-0; L2 13162 SEA L1 NOT PATENT/DT; L3 943 SEA L2 AND ED>=20220601; L4 1470 SEA L2 AND PY>2020; L5 1478 SEA L3 OR L4; ACTIVATE TOXQUERY/Q; ---------; L6 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L7 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L8 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L9 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L10 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L11 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L12 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L13 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L14 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L15 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L16 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L17 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L18 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L19 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L20 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L21 QUE (ENDOCRIN? AND DISRUPT?); L22 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L23 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L24 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L25 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L26 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L27 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L28 QUE (NEPHROTOX? OR HEPATOTOX?); L29 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L30 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L31 QUE L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30; L32 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L33 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L34 QUE L31 OR L32 OR L33; L35 QUE (NONHUMAN MAMMALS)/ORGN; L36 QUE L34 OR L35; L37 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L38 QUE L36 OR L37; ---------; L39 838 SEA L5 AND L38; L40 15 SEA L39 AND MEDLINE/FS; L41 814 DUP REM L39 (24 DUPLICATES REMOVED); L*** DEL 838 S L5 AND L38; L*** DEL 838 S L5 AND L38; L42 814 SEA L41; L43 789 SEA L42 AND EN/LA; L44 814 SEA L42 NOT LA/FA; L45 25 SEA L42 NOT L43; D CLUSTER; D SEL; D SET; L*** DEL 838 S L5 AND L38; L*** DEL 838 S L5 AND L38; L46 814 SEA L41; L47 789 SEA L46/ENGLISH; D SCAN L45; D SCAN L43
06/2022 | FILE ‘TOXCENTER’ ENTERED AT 08:28:36 ON 15 JUN 2022; CHARGED TO COST=EH038.15.02.LB.04; L1 15306 SEA FILE=TOXCENTER 75-15-0; L2 15206 SEA FILE=TOXCENTER L1 NOT TSCATS/FS; L3 11992 SEA FILE=TOXCENTER L2 NOT PATENT/DT; L4 6648 SEA FILE=TOXCENTER L3 AND PY>=1994; ACTIVATE TOXQUERY/Q; ---------; L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L20 QUE (ENDOCRIN? AND DISRUPT?); L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L27 QUE (NEPHROTOX? OR HEPATOTOX?); L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29; L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L33 QUE L30 OR L31 OR L32; L34 QUE (NONHUMAN MAMMALS)/ORGN; L35 QUE L33 OR L34; L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L37 QUE L35 OR L36; ---------; L38 3495 SEA FILE=TOXCENTER L4 AND L37; L39 361 SEA FILE=TOXCENTER L38 AND MEDLINE/FS; L40 299 SEA FILE=TOXCENTER L38 AND BIOSIS/FS; L41 2786 SEA FILE=TOXCENTER L38 AND CAPLUS/FS; L42 49 SEA FILE=TOXCENTER L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L43 3078 DUP REM L39 L40 L42 L41 (417 DUPLICATES REMOVED); L*** DEL 361 S L38 AND MEDLINE/FS; L*** DEL 361 S L38 AND MEDLINE/FS; L44 361 SEA FILE=TOXCENTER L43; L*** DEL 299 S L38 AND BIOSIS/FS; L*** DEL 299 S L38 AND BIOSIS/FS; L45 140 SEA FILE=TOXCENTER L43; L*** DEL 2786 S L38 AND CAPLUS/FS; L*** DEL 2786 S L38 AND CAPLUS/FS; L46 2536 SEA FILE=TOXCENTER L43; L*** DEL 49 S L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L*** DEL 49 S L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L47 41 SEA FILE=TOXCENTER L43; L48 2717 SEA FILE=TOXCENTER (L44 OR L45 OR L46 OR L47) NOT MEDLINE/FS D SCAN L48

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
01/2025; 06/2022 | Compounds searched: 75-15-0
NTP
01/2025 | Limited 2020 to present; “75-15-0” “Carbon bisulfide” “Carbon disulfide” “Carbondisulfide”; “Carbon bisulphide” “carbon disulphide” “Methanedithione” “Carbon sulfide”; “Dithiocarbonic anhydride” “Dithiocarbonic, anhydrous” “Sulphocarbonic anhydride”; “Sulphuret of carbon”; “Weeviltox”
06/2022 | “75-15-0” “Carbon bisulfide” “Carbon disulfide” “Carbondisulfide”; “Carbon bisulphide” “carbon disulphide” “Methanedithione” “Carbon sulfide”; “Dithiocarbonic anhydride” “Dithiocarbonic, anhydrous” “Sulphocarbonic anhydride”; “Sulphuret of carbon”; “Weeviltox”
Regulations.gov
01/2025; 06/2022 | “Carbon bisulfide”; “Carbon bisulphide”; “Carbon disulfide”; “carbon disulphide”; “Carbondisulfide”; “Methanedithione”; “Carbon sulfide(CS2)”; “Dithiocarbonic anhydride”; “Dithiocarbonic, anhydrous”; “Sulphocarbonic anhydride”; “Sulphuret of carbon”; “Weeviltox”
NIH RePORTER
02/2025 | Search Criteria: Fiscal Year: Active Projects Text Search: “Carbon bisulfide” OR “Carbon bisulphide” OR “Carbon disulfide” OR “carbon disulphide” OR “Carbondisulfide” OR “Methanedithione” OR “Carbon sulfide” OR “Dithiocarbonic anhydride” OR “Dithiocarbonic, anhydrous” OR “Sulphocarbonic anhydride” OR “Sulphuret of carbon” OR “Weeviltox” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
05/2023 | Fiscal Year: Active Projects; Text Search: “Carbon bisulfide” OR “Carbon bisulphide” OR “Carbon disulfide” OR “carbon disulphide” OR “Carbondisulfide” OR “Methanedithione” OR “Carbon sulfide” OR “Dithiocarbonic anhydride” OR “Dithiocarbonic, anhydrous” OR “Sulphocarbonic anhydride” OR “Sulphuret of carbon” OR “Weeviltox” (advanced); Limit to: Project Title, Project Terms, Project Abstracts
Other | Includes additional reference identified throughout the assessment process, which may include studies found by tree searching; recommended by intraagency, interagency, peer, or public reviewers; or published more recently than the date of literature search(es). Additional references include those for specific regulations or guidelines and publications found by targeted searches for specific information (e.g., searches for reviews of general [not chemical-specific] mechanisms of toxicity).

The 2022 pre-public comment search results were:

- Number of records identified from PubMed, NTRL, and Toxcenter (after duplicate removal): 3,621
- Number of records identified from other strategies: 204
- Total number of records to undergo literature screening: 3,825

The 2025 post-public comment search results were:

- Number of records identified from PubMed, NTRL, and Toxcenter (after duplicate removal): 1,001
- Number of records identified from other strategies: 24
- Total number of records to undergo literature screening: 1,025

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on carbon disulfide during the pre- and post-public comment drafts:

- Title and abstract screen
- Full text screen

Pre-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 3,825
- Number of studies considered relevant and moved to the next step: 419

Pre-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 419
- Number of studies cited in the previous toxicological profile: 307
- Total number of studies cited in the profile: 426

Prioritization of Human Data. The epidemiological database for carbon disulfide is extensive but is largely focused on a small number of endpoints: cardiovascular, lipid homeostasis, ophthalmological, neurological, and male reproductive endpoints. For endpoints with few epidemiological studies, all relevant human data and study designs were considered. For the data-rich endpoints, the inclusion criteria defined in Table B-1 were refined to facilitate the selection of chronic-duration human studies of greater utility in assessing the hazards of carbon disulfide, and only studies meeting the refined criteria were included in the Toxicological Profile. The refined criteria are shown below, and Table B-4 summarizes how the criteria were applied to the available epidemiological data by health outcome.

- Only studies in which exposure was measured prior to outcome determination (cohort studies) were included. Study designs that lacked this clear temporality data (e.g., cross-sectional studies) were excluded, as they cannot draw conclusions regarding causality (Mann 2003). This approach is supported by conclusions reported in published review of EPA quality considerations for epidemiological studies in risk assessment, which indicate that cross-sectional studies are lower quality than cohort studies and should only be considered as supplemental material for regulatory use (LaKind et al. 2023). However, cumulative exposure index analyses conducted in cross-sectional studies were included, as these study designs estimated exposure levels prior to outcome determination. Therefore, several occupational studies that are referred to as “cross-sectional” by study authors (e.g., Johnson et al. 1983) meet inclusion criteria due to inclusion of historical exposure data and/or estimates of cumulative exposure based on current exposure metrics. For the purposes of the profile, the cumulative exposure analyses from these occupational studies are classified as cohort analyses.
- Case series, case reports, and other studies lacking control/referent groups were excluded.
- Only studies for which exposure was assessed via external monitoring or validated biomarker (TTCA in urine). Studies that just evaluated “exposed” compared to “unexposed” without measures of exposure were not included since these studies would not provide any relevant dose-response data.
- Studies that only evaluated endpoints that were mechanistic in nature (e.g., oxidative stress) were not included in the systematic review. Where relevant, these studies were discussed in the mechanisms of toxicity sections in Chapter 2.
- Studies evaluating toxicity of compounds that metabolize into carbon disulfide, such as disulfiram (Antabuse) and certain pesticides (thiocarbamates), were not included; they are considered outside the scope of this profile due to exposure to compounds other than the profile chemical.

Table B-4 Application of Selection Criteria to Epidemiological Data by Health Outcome

Outcome | Selection process
Death | All studies included
Body weight | All studies included
Respiratory | All studies included
Cardiovascular | Criteria applied
Gastrointestinal | All studies included
Hematological | All studies included
Musculoskeletal | No studies identified
Hepatic | Lipid homeostasis and metabolism: Criteria applied; Other endpoints: All studies included
Renal | All studies included
Dermal | All studies included
Ocular | Criteria applied
Endocrine | All studies included
Immunological | No studies identified
Neurological | Criteria applied
Reproductive | Male reproductive: Criteria applied; Female reproductive: All studies included
Developmental | No studies identified
Other noncancer | Criteria applied (diabetes/metabolic syndrome)
Cancer | All studies included

Prioritization of Animal Data. The neurological endpoint is extremely well studied in rodents following intermediate-duration inhalation exposure. To facilitate the selection of animal studies of greater utility in assessing the neurological dose-response effects of carbon disulfide, single exposure level studies evaluating neurological effects in rodents following intermediate-duration inhalation exposure were excluded unless they were evaluating a specialized endpoint (e.g., visual or auditory function).

As noted for human studies, animal studies evaluating disulfiram and thiocarbamates were not included (outside scope of profile).

A summary of the results of the pre-public literature search and screening is presented in Figure B-1.

Figure B-1 June 2022 Pre-Public Comment Literature Search Results and Screen for Carbon Disulfide^*^ * The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.

Post-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 1,025
- Number of studies considered relevant and moved to the next step: 63

Post-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 63
- Number of studies cited in the pre-public draft of the toxicological profile: 426
- Total number of studies cited in the profile: 441

A summary of the results of the post-public comment literature search and screening is presented in Figure B-2.

Figure B-2 January 2025 Post-Public Comment Literature Search Results and Screen for Carbon Disulfide^*^ * The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.