# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

## Carbon disulfide Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Carbon disulfide
CAS Numbers: | 75-15-0
Date: | July 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 0.2 ppm (0.6 mg/m^3^)
Critical Effect: | Increased total lipid levels in hepatic microsomal fraction
Reference: | Freundt et al. 1974b
Point of Departure: | LOAEL of 20 ppm (LOAEL_HEC_ of 16 ppm)
Uncertainty Factor: | 90
LSE Graph Key: | 2
Species: | Rat

MRL Summary: An acute-duration inhalation MRL of 0.2 ppm was derived for carbon disulfide based on altered lipid homeostasis (increased total lipid levels in hepatic microsomal fractions) in rats exposed to concentrations ≥20 ppm for 8 hours; a no-observed-adverse-effect level (NOAEL) was not identified (Freundt et al. 1974b). The MRL is based on a lowest-observed-adverse-effect level (LOAEL) of 20 ppm, which was converted to a LOAEL_HEC_ of 16 ppm and divided by a total uncertainty factor of 90 (3 for use of a minimal LOAEL, 3 for extrapolation from animals to humans after dosimetric adjustment, and 10 for human variability).

Selection of the Critical Effect: Endpoints identified as known (neurological), presumed (cardiovascular), or suspected (altered lipid homeostasis, male reproductive, developmental) human health effects following inhalation exposure based on systematic review (Appendix C) were considered as candidate critical effects for the acute-duration inhalation MRL. No reliable acute-duration human data are available. In animals, effects associated with altered lipid homeostasis were the only adverse effects noted below the lowest concentration associated with increased mortality following acute-duration inhalation exposure to carbon disulfide (Table A-1). Due to the large dose spacing in the developmental study by Lehotzky et al. (1985), the true NOAEL and LOAEL for observed effects lie within the wide interval between the lowest tested concentration of 3.2 ppm and next lowest concentration of 225 ppm, identified as a serious LOAEL for developmental effects (Table A-1). However, data reporting was inadequate for benchmark dose (BMD) modeling to estimate benchmark concentration (BMC) and 95% lower confidence limit on the benchmark concentration (BMCL) levels for developmental effects. Therefore, the effect associated with the lowest identified LOAEL of 20 ppm (altered lipid homeostasis) identified in the study by Freundt et al. (1974b) was selected as the critical effect for the acute-duration inhalation MRL. Additional support for this critical endpoint is provided by intermediate- and chronic-duration inhalation studies in rats, which report altered lipid homeostasis at all evaluated concentrations tested in rats (Wrońska-Nofer 1972, 1973; Wrońska-Nofer et al. 1980); see Other Additional Studies or Pertinent Information that Lend Support to this MRL below.

Table A-1 Selected LOAEL Values in Animals for Acute-Duration Inhalation Exposure to Carbon Disulfide

Species | Duration | Effect level (ppm) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Rat | 8 hours | ND | 20 | Altered lipid homeostasis: 15% increase in total lipids in the hepatic microsomal fraction | Freundt et al. 1974b
Mouse | 60 minutes | ND | 220 | Death: LC_50_ | Gibson and Roberts 1972
Rat | 8 days; GDs 7–15; 6 hours/day | 3.2 | 225; (SLOAEL) | Developmental: 35% perinatal mortality; delayed eye opening; altered motor activity; impaired motor coordination; altered operant conditioning | Lehotzky et al. 1985
Mouse | 30 minutes | 119.5 | 577.6 | Neurological: Impaired operant training | Liang et al. 1983
Rabbit | 12 days; GDs 6–18; 6 hours/day | 304.1 | 597.9; (SLOAEL) | Developmental: Increased postimplantation loss and early resorptions; 9% decrease in fetal body weight | Denny and Gerhart 1991
Rat | 6 hours | 300 | 600 | Altered lipid homeostasis: Decreased ex vivo hepatic cholesterol synthesis | Simmons et al. 1988
Rat | 14 days; 10 hours/day | ND | 600; (SLOAEL) | Neurological: Narcotic-like stupor; ataxia; hind-limb splay | Wilmarth et al. 1993
Rat | 8 days; GDs 7–15; 6 hours/day | 225 | 642; (SLOAEL) | Neurological: Tremor and muscle weakness in dams that died | Lehotzky et al. 1985
Rat | 1 hour | ND | 642 | Neurological: Decrease in brain noradrenaline; increase in brain dopamine | Magos et al. 1974
Rat | 2 weeks; 6 hours/day; 5 days/week | 500 | 800 | Neurological: Slight gait impairment and ataxia in males; increased foot splay in females | Moser et al. 1998
Rat | 18 hours | ND | 803; (SLOAEL) | Cardiovascular: Decreased cardiac rate; Neurological: Severe narcosis; straightening of hindlimbs | Tarkowski and Sobczak 1971

Selected study for derivation of acute-duration inhalation MRL.

GD = gestation day; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; SLOAEL = serious LOAEL

Selection of the Principal Study: Freundt et al. (1974b) was selected as the principal study because it identifies the lowest LOAEL for the critical effect (altered lipid homeostasis). Based on systematic review (Appendix C), this study was considered a first tier, medium confidence study for the evaluation of altered lipid homeostasis.

Summary of the Principal Study:

Freundt KJ, Schauenburg KJ, Eichhorn P. 1974b. Effect of acute exposure to carbon disulfide vapour upon some components of the hepatic-microsomal enzyme system in rats. Arch Toxicol 32:233–240.4154735

Groups of adult female Wistar rats (5–15/group) were exposed to reagent-grade carbon disulfide via whole-body inhalation at concentrations of 20, 100, or 400 ppm for 8 hours. Additional groups of rats served as air-only controls (n=23) or were exposed to 400 ppm and then examined 36 hours later (recovery group; n=10). After the exposure period (or recovery period), rats were sacrificed. Livers were weighed and processed for determination of total lipid levels in the microsomal fraction. Liver weights were not reported; however, measured liver weights were used for reporting of lipid levels in mg/g of liver wet weight. Specific phospholipid levels (phosphatidylethanolamine, phosphatidylcholine, phosphatidylserine, sphingomyelin, lysophosphatidylcholine) and neutral lipid levels (cholesterol, triglycerides, diglycerides, free fatty acids) were determined in six animals/group in the main group and nine animals in the recovery group. Microsomal protein levels and activities in the microsomal fraction were determined in 7–13 rats/group from the main group only.

The total lipid content in the microsomal fraction of the liver was significantly increased by 15, 32, and 72% at 20, 100, and 400 ppm, respectively. Observed changes were attributable to elevated changes in neutral lipids (increased triglycerides at ≥20 ppm, cholesterol and free fatty acids at ≥100 ppm, and diglycerides at 400 ppm), as well as phospholipids (increased sphingomyelin at ≥20 ppm, phosphatidylcholine at ≥100 ppm, and lysophosphatidylcholine at 400 ppm). After 36 hours, total lipid levels in rats exposed to 400 ppm were returning to normal, but were still significantly elevated by 25%, including residual increases in triglycerides, cholesterol, and sphingomyelin. The microsomal total protein content was increased by 16% at 400 ppm at the end of exposure.

Selection of the Point of Departure for the MRL: The LOAEL of 20 ppm for elevated total lipid levels in the microsomal fraction of hepatic tissue was selected as the point of departure (POD) for the acute-duration inhalation MRL.

In order to identify the POD, benchmark dose (BMD) modeling was attempted for total lipid levels in female rats reported by Freundt et al. (1974b). The data modeled for hepatic microsomal lipid levels are shown in Table A-2. Data were fit to all available continuous models in EPA’s Benchmark Dose Software (BMDS) (version 3.3) using a benchmark response (BMR) of 1 standard deviation. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, BMCL that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Based on these criteria, none of the models tested adequately fit the data for total lipid levels in hepatic microsomes; all models were deemed questionable by BMDS using constant or non-constant variance. Therefore, the LOAEL of 20 ppm was selected as the POD for the acute-duration inhalation MRL. This LOAEL is considered a minimal LOAEL because findings are slight in magnitude (15%), representing the start of the dose-response curve, with effects of greater magnitude at higher concentrations (e.g., 72% increase at 400 ppm) in this study and following longer-duration exposure (Wrońska-Nofer 1972, 1973; Wrońska-Nofer et al. 1980). Findings from the 400-ppm dose group also suggest that acute-duration effects may be partially reversible (total lipid levels were elevated by only 25% by 36 hours post-exposure).

Table A-2 Selected Lipid Levels in the Hepatic Microsomal Fraction in Male Rats Following Inhalation Exposure to Carbon Disulfide for 8 Hours

| Concentration (ppm)
| 0 | 20 | 100 | 400
Total lipids; (mg/g wet weight) | 6.0±1.4^a^; (23) | 6.9±0.7^b^; (6) | 7.9±0.9^c^; (5) | 10.3±3.1^c^; (15)

a Mean±SD (number of animals). SD values calculated from reported SE values (SD = SE * √N).

b p<0.05.

c p<0.01.

N = number of animals; SE = standard error of the mean; SD = standard deviation

Source: Freundt et al. 1974b

Adjustment for Intermittent Exposure: Because effects observed at the LOAEL were mild and transient following a single 8-hour exposure, an adjustment to 24-hour exposure may overestimate toxic effects. Therefore, no adjustment was made for continuous exposure.

Human Equivalent Concentration: The LOAEL of 20 ppm was converted to a LOAEL_HEC_ based on dosimetric adjustments for systemic effects using the ratio of animal:human blood gas partition coefficients (EPA 1994). For carbon disulfide, the rat partition coefficient is 2.8 ppm (WHO 1979) and human blood:air partition coefficient is 3.61 (Kramer et al. 2016).

L O A E L_H E C_ = L O A E L × (r a t p a r t i o n c o e f f i c i e n t)/(h u m a n p a r t i t i o n c o e f f i c e n t) = 20 p p m × (2.8)/(3.61) = 16 p p m

Uncertainty Factor: The following uncertainty factors were applied to the LOAEL_HEC_ to derive the MRL:

- Uncertainty factor of 3 for use of a minimal LOAEL
- Uncertainty factor of 3 for extrapolation from animals to humans with dosimetric adjustments
- Uncertainty factor of 10 for human variability

Subsequently, the MRL for acute-duration exposure to carbon disulfide via inhalation is:

M R L = (L O A E L_H E C_)/(( U F )) = (16 p p m)/(90) = 0.18 p p m ≈ 0.2 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that altered lipid homeostasis is a suspected target of carbon disulfide toxicity in humans following inhalation exposure based on inadequate evidence in humans and a moderate level of evidence in laboratory animals (Appendix C).

Several cohort studies of viscose rayon workers reported associations between cumulative carbon disulfide exposure and elevated total serum cholesterol levels (Jhun et al. 2007; Kotseva and De Bacquer 2000; NIOSH 1984a; Stanosz et al. 1994b; Vanhoorne et al. 1992a). Some of these studies also reported elevated serum LDL and/or decreased serum HDL levels in exposed workers (NIOSH 1984a; Stanosz et al. 1994b; Vanhoorne et al. 1992b). Historical exposure levels in these cohorts ranged from 0.58 to 36 ppm. A prospective cohort also observed increased serum triglycerides over a 5-year exposure to concentrations up to 21 ppm (Chrostek-Maj and Czeczotko 1995a). However, several other occupational studies with historical exposure levels ranging from 0.42 to 60 ppm did not exhibit any associations with any adverse serum lipid level effects (see Section 2.9 for citations). In general, findings from these occupational studies are challenging to interpret due to limited details on exposure for many studies (e.g., broad historical ranges), lack of control for concurrent chemical exposures in statistical analyses, and lack of control for any confounding factors in approximately 80% of all available studies, such as known risk factors for elevated serum lipids (e.g., smoking, alcohol intake, BMI, etc.).

Most available data from animals more clearly show that altered lipid homeostasis can occur following inhalation exposure; however, data are only available from a few studies and findings from acute-duration studies show some inconsistencies. Acute-duration inhalation studies other than Freundt et al. (1974b) were shorter in duration (6 hours versus 8 hours), in a different rat strain (Wistar versus F-344), in males versus females, and showed inter-study inconsistencies from the same laboratory (Simmons et al. 1988, 1989). Simmons et al. (1988) reported decreased ex vivo hepatic cholesterol synthesis following a single 6-hour exposure to 600 ppm, while Simmons et al. (1989) did not observe the same effect after 6-hour exposures for 1–3 days. The study authors attributed the discrepancy to decreased animal number (and therefore statistical power) in the latter study. Based on these issues, ATSDR considers the support from the intermediate- and chronic-duration animal studies to outweigh the conflicting evidence from the Simmons et al. (1988, 1989) studies with regard to animal evidence of altered lipid homeostasis. Altered lipid homeostasis has been observed at all evaluated intermediate- and chronic-duration concentrations tested in rats (Wrońska-Nofer 1972, 1973; Wrońska-Nofer et al. 1980). In the intermediate-duration studies, serum cholesterol, phospholipid, and triglyceride levels generally increased in a concentration- and duration-dependent manner following exposure to concentrations ≥74 ppm for 2– 8 months; however, a plateauing of effects appeared to occur between 321 and 546 ppm. This may be due to overt toxicity occurring at 546 pm, including >20% decreases in body weight and hindlimb paralysis (Wrońska-Nofer 1973). Liver lipid synthesis increased by 38–82% in a concentration-related manner after 8 months. Chronic-duration data are limited to a 44–58% increase in total and esterified serum cholesterol levels in female rats exposed to 321 ppm for 12–15 months; this study only evaluated a single exposure level (Wrońska-Nofer et al. 1980). Recovery groups were not employed in the intermediate- and chronic-duration studies, so reversibility of these effects following repeated exposure are unknown.

While findings pertaining to lipid homeostasis appear to be mild, and at least partially reversible, they are considered adverse and relevant to human exposure due to the numerous adverse health effects in humans associated with high cholesterol (e.g., cardiovascular disease). This is particularly relevant for carbon disulfide since alterations in lipid homeostasis and metabolism are a proposed mechanism of atherosclerosis seen in some viscose rayon workers (Huang et al. 2004; Wrońska-Nofer et al. 2002). In support, the chronic-duration lipid homeostasis study discussed above also observed increase esterified cholesterol levels in the aortic walls of exposed rats (Wrońska-Nofer et al. 1980).

Agency Contacts (Chemical Managers): Custodio Muianga

## Carbon disulfide Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Carbon disulfide
CAS Numbers: | 75-15-0
Date: | July 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data to support derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: Endpoints identified as known (neurological), presumed (cardiovascular), or suspected (altered lipid homeostasis, male reproductive, developmental) human health effects following inhalation exposure based on systematic review (Appendix C) were considered as candidate critical effects for the intermediate-duration inhalation MRL. There are no human studies evaluating potential health effects following intermediate-duration exposure to carbon disulfide. The most sensitive effects in animals following intermediate-duration inhalation exposure are male reproductive effects (Table A-3).

Table A-3 Selected LOAEL Values in Animals for Intermediate-Duration Inhalation Exposure to Carbon Disulfide

Species | Duration | Effect level (ppm) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Rat | 10 weeks; 5 days/week; 2 hours/day | ND | 16 | Male reproduction: Increased incidence of teratospermias, 3.2% decrease in sperm motility, and 9% decrease in sperm beat cross frequency; 28% decrease in serum LH | Huang et al. 2012
Rat | 21 days; 8 hours/day; GDs 1–21 | ND | 32; (SLOAEL) | Developmental: Club foot in F1 and F2 fetuses and microcephaly in F2 fetuses | Tabacova and Balabaeva 1980; Tabacova et al. 1978, 1983
Rat | 13 weeks; 6 hours/day; 5 days/week | ND | 50 | Neurological: Slight gait impairments | Moser et al. 1998
Rat | 8 months; 6 days/week; 5 hours/day | ND | 74 | Altered lipid homeostasis: Increased serum lipids; increased liver cholesterol synthesis | Wrońska-Nofer 1973
Rat | 8 months; 6 days/week; 5 hours/day | ND | 177 | Altered lipid homeostasis: Increased serum lipids; increased liver cholesterol synthesis | Wrońska-Nofer 1972
Rat | 14 weeks; 6 hours/day | ND | 225 | Cardiovascular: Increased blood pressure; decreased cardiac output; increased vascular resistance | Morvai et al. 2005

GD = gestation day; LH = luteinizing hormone; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; SLOAEL = serious LOAEL

In order to identify the most sensitive POD, BMD modeling was attempted for male reproductive effects reported by Huang et al. (2012). BMD modeling was attempted for serum luteinizing hormone and sperm effects (increased teratospermia, decreased sperm beat cross frequency, decreased progressive sperm motility) using a BMR of 1 standard deviation. Model fits were obtained for sperm beat cross frequency and sperm motility only, resulting in BMCL values of 5.7 and 2.7 ppm, respectively. Of the candidate PODs (Table A-4), the lowest BMCL of 2.7 ppm based on decreased progressive sperm motility was selected as the POD.

Table A-4 Candidate PODs for Intermediate-Duration Inhalation MRL based on Male Reproductive Effects in Rats Exposed to Carbon Disulfide (Huang et al. 2012)

Effect | Effect level (ppm)
Effect | NOAEL | LOAEL | BMCL | BMC
Decreased serum luteinizing hormone | ND | 16 | NA | NA
Increased teratospermia incidence | ND | 16 | NA | NA
Decreased sperm beat cross frequency | ND | 16 | 5.8 | 15
Decreased progressive sperm motility | ND | 16 | 2.7 | 11

BMC = benchmark concentration; BMCL = 95% lower confidence limit on the benchmark concentration; LOAEL = lowest-observed-adverse-effect level; NA = not applicable (modeling attempted; no adequate models); ND = not determined; NOAEL = no-observed-adverse-effect level

The BMCL of 2.7 ppm was adjusted for continuous exposure (2 hours/24 hours; 5 days/7 days) to a BMCL_ADJ_ of 0.16 ppm and converted into a BMCL_HEC_ of 0.12 ppm using the ratio of rat:human blood gas partition coefficients of 0.78 (see acute-duration inhalation MRL for details). Using the BMCL_HEC_ of 0.12 ppm as the final POD and a total uncertainty factor of 30 (3 for extrapolation from animals to humans and 10 for human variability) would result in an intermediate-duration inhalation MRL of 0.004 ppm. However, this value is not proposed for the intermediate-duration inhalation MRL for the following reasons:

- There is some uncertainty regarding the biological significance of small deviations in sperm parameters in rodents. The standard BMR of 1 standard deviation may be overly conservative, as human data indicate that there is a range of acceptable deviation for these parameters (WHO 2021).
- The candidate intermediate-duration inhalation MRL based on sperm effects in rats would be lower than the proposed chronic-duration inhalation MRL based on neurological effects in humans. The confidence in the chronic-duration MRL is much higher due to both the endpoint and the study population.

Based on this information, derivation of a chronic-duration MRL of 0.1 ppm based on human data from seven occupational studies on a well-established target of carbon disulfide toxicity (peripheral neuropathy) is selected over derivation of an intermediate-duration MRL of 0.004 ppm based on rodent data based on an endpoint (male reproductive toxicity) with some uncertainties.

The next lowest candidate POD is based on developmental effects reported in a series of studies by Tabacova and colleagues (Tabacova and Balabaeva 1980; Tabacova et al. 1978, 1983). However, these studies are not considered of sufficient quality to serve as the basis for the MRL. Based on systematic review (Appendix C), these studies are considered third tier studies due to multiple methodological and reporting deficiencies. However, these studies do indicate potential for serious developmental effects at 32 ppm, precluding consideration of any candidate PODs >32 ppm as the potential basis for the intermediate-duration inhalation MRL.

Agency Contacts (Chemical Managers): Custodio Muianga

## Carbon disulfide Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Carbon disulfide
CAS Numbers: | 75-15-0
Date: | July 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic
MRL: | 0.1 ppm (0.3 mg/m^3^)
Critical Effect: | Impaired peripheral nerve conduction
Reference: | Cirla and Graziano 1981; Godderis et al. 2006; Hirata et al. 1996; Johnson et al. 1983; Kim et al. 2000; Reinhardt et al. 1997a; Yoshioka et al. 2017
Point of Departure: | 95% lower confidence limit of the weighted median NOAEL/LOAEL boundary of 4.02 ppm (POD_ADJ_ of 0.957 ppm)
Uncertainty Factor: | 10
LSE Graph Key: | 57
Species: | Human

MRL Summary: A chronic-duration inhalation MRL of 0.1 ppm was derived for carbon disulfide based on impaired peripheral nerve conduction velocity in humans reported in several occupational exposure studies. The MRL is based on the duration-adjusted 95% lower confidence limit of the weighted median of 0.957 ppm calculated from the observed NOAEL/LOAEL boundary identified from seven occupational cohort studies (Cirla and Graziano 1981; Godderis et al. 2006; Hirata et al. 1996; Johnson et al. 1983; Kim et al. 2000; Reinhardt et al. 1997a; Yoshioka et al. 2017) and a total uncertainty factor of 10 for human variability.

Selection of the Critical Effect: Endpoints identified as known (neurological), presumed (cardiovascular), or suspected (altered lipid homeostasis, male reproductive, developmental) human health effects following inhalation exposure based on systematic review (Appendix C) were considered as candidate critical effects for the chronic-duration inhalation MRL.

Most of the available information on the chronic-duration toxicity of carbon disulfide vapor comes from numerous epidemiological studies of workers, predominately from the viscose rayon industry. While the entire body of evidence was considered, only occupational studies rated as tier 1 or tier 2 studies in risk of bias assessment with reliable exposure estimates allowing for NOAEL/LOAEL determinations were considered during the selection of a critical effect (Appendix C). Studies that were determined to have definite or probable high risk of bias for the key systematic review question “Is there confidence in the exposure characterization?” were excluded from consideration due to low confidence in the exposure estimates.

Reliable LOAELs were identified for neurological effects, cardiovascular effects, altered lipid homeostasis, and ophthalmological effects (Table A-5). The NOAEL and LOAEL ranges for these effects show considerable overlap; however, the lowest LOAEL was identified for neurological effects. Additionally, strength of evidence based on the number of studies and quality of the studies and overall database is strongest for neurological effects (see Appendix C). Specifically, all LOAELs shown in Table A-5 are based on impaired peripheral nerve conduction velocity. Therefore, impaired nerve conduction velocity was selected as the critical effect for derivation of the chronic-duration inhalation MRL for carbon disulfide.

Table A-5 Summary of NOAELs and LOAELs for Sensitive Effects Reported in Epidemiological Studies of Carbon Disulfide

| Range (ppm) | Median (ppm) | References
Neurological (impaired nerve conduction velocity)
NOAELs | 4.02–5.64 | 4.85 | Cirla and Graziano 1981; Johnson et al. 1983; Reinhardt et al. 1997a; Yoshioka et al. 2017
LOAELs | 2.9–9.35 | 7.60 | Godderis et al. 2006; Hirata et al. 1996; Johnson et al. 1983; Kim et al. 2000; Ruijten et al. 1990, 1993; Yoshioka et al. 2017
Cardiovascular (elevated blood pressure)
NOAELs | 6.44–14 | 7.5 | Schramm et al. 2016; Tolonen et al. 1976; Vertin 1978
LOAELs | 3.36–8.26 | 5.00 | Kim et al. 2000; NIOSH 1984a; Takebayashi et al. 2004
Altered lipid homeostasis (elevated total serum cholesterol and/or LDL levels)
NOAELs | 5.6–14 | 6.44 | Cai and Bao 1981; Schramm et al. 2016; Vertin 1978
LOAELs | 3.36–8.26 | 5.81 | Kim et al. 2000; NIOSH 1984a
Ophthalmological (retinal microaneurysms)
NOAELs | 5.6 | 5.6 | Cai and Bao 1981
LOAELs | 3.36–8.26 | 5.81 | Kim et al. 2000; NIOSH 1984a
Developmental (congenital malformations)
NOAELs | 5.2 | 5.2 | Zhou et al. 1988
LOAELs
Male reproductive (fertility, sexual desire, sperm parameters, serum testosterone levels)
NOAELs | 5–8.26 | 8.1 | NIOSH 1983, 1984a; Takebayashi et al. 2004
LOAEL

LDL = low-density lipoprotein; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Summary of the Principal Study: Rather than selecting an individual study as the principal study, a group of seven studies that provide information on the NOAEL/LOAEL boundary were selected as the principal studies (see the Selection of the Point of Departure for the MRL section below for information on criteria for selecting these studies). Citations for the principal studies are listed below; summaries of these studies are included in Table A-6.

Cirla AM, Graziano C. 1981. Health impairment in viscose-rayon workers with carbon disulfide risk below 30 mg/m3: An exposed-controls study. G Ital Med Lav 3:69–73.

Godderis L, Braeckman L, Vanhoorne M, . 2006. Neurobehavioral and clinical effects in workers exposed to CS(2). Int J Hyg Environ Health 209(2):139–150. 10.1016/j.ijheh.2005.09.005.16503300

Hirata M, Ogawa Y, Goto S. 1996. A cross-sectional study on nerve conduction velocities among workers exposed to carbon disulphide. Med Lav 87(1):29–34.8699979

Johnson BL, Boyd J, Burg JR, . 1983. Effects on the peripheral nervous system of worker’s exposure to carbon disulfide. Neurotoxicology 4(1):53–65.6683827

Kim JS, Lim HS, Cheong HK, . 2000. Validity and cost-effectiveness of diagnostic procedures in CS2 poisoning. Ind Health 38(4):385–395. 10.2486/indhealth.38.385.11061482

Reinhardt F, Drexler H, Bickel A, . 1997a. Electrophysiological investigation of central, peripheral and autonomic nerve function in workers with long-term low-level exposure to carbon disulphide in the viscose industry. Int Arch Occup Environ Health 70(4):249–256. 10.1007/s004200050215.9342625

Yoshioka N, Takebayashi T, Nishiwaki Y, . 2017. Changes of median nerve conduction velocity in rayon manufacturing workers: A 6-year cohort study. J Occup Health 59(2):187–193. 10.1539/joh.16-0255-OA.28111416

Table A-6 Summary of the Principal Studies Examining Peripheral Nerve Conduction Velocity in Workers Exposed to Carbon Disulfide

Reference: Cirla and Graziano 1981; Study type and population: Retrospective cohort of 50 male viscose rayon workers (26–55 years old) and 50 matched male referents from Italy. Duration of exposure of workers was 3–12 years.; Measured air concentration: Mean values during a 12-year period (stationary air sampling); - Range: 10–25 mg/m^3^ (3.2–8.0 ppm); Analysis: Matching was based on sex, age (±3 years), physical feature (normal, slim, fat), work shift (daily, rotating), smoking history (never, light, heavy, very heavy, past only), alcohol history (never, light, heavy, very heavy, past only), socioeconomic status (all blue-collar), contractual skill, basic instruction (never above 8 years of school), district of birth and residence, and presumably the diet (one time a day at the canteen of the factory and generally eating uses of the rural tradition). Statistical analysis was based on paired Student’s t-test comparisons.; Results:
Mean ± SD of peroneal nerve maximal motor conduction velocity (m/second), NS; - Exposed: 50.1±5.1; - Referent: 51.1±5.3 | Mean ± SD of peroneal nerve slow fiber motor conduction velocity (m/second), NS; - Exposed: 42.1±5.7; - Referent: 43.9±6.5
Interpretation: Motor nerve conduction velocity in the peroneal nerve was not significantly different between exposed and referent groups; therefore, the midpoint of the range of means (5.6 ppm) is considered a NOAEL for altered nerve conduction velocity.
Reference: Godderis et al. 2006; Study type and population: Retrospective cohort of 85 viscose rayon workers, including 60 workers with “low” exposure (<31 mg/m^3^ [10 ppm]) and 25 workers with “high” (>31 mg/m^3^ [10 ppm]) exposure, and 66 unexposed referents from Belgium. Average duration of exposure of workers was 10.5 years. The mean ages of the exposed workers and referents were 37.2 and 41.2 years, respectively.
Measured air concentration: Annual geometric mean ± SD since 1983 (personal air monitoring); - All exposed: 15.3±3.0 mg/m^3^ (4.91 ppm); - Low exposure: 8.9±1.1 mg/m^3^ (2.9 ppm); - High exposure: 59.2±5.2 mg/m^3^ (19.0 ppm) | Cumulative exposure index: Geometric mean ± SD; - Low: 59.5±17.1 mg/m^3^*years (19.1 ppm-years); - High: 746.6±116.1 mg/m^3^*years (239.8 ppm-years)
Analysis: Subjects were excluded for history of “ethyl abuses” (>40 g/week for >2 years), cerebral contusion, cerebro-vascular accident, epilepsy, diabetes, or depression. Data were analyzed using ANOVA for comparison of means between exposure groups and referents with multiple logistic regression analysis, using race, shift work, BMI, smoking, educational level, age, alcohol use, personality score (NSC-60), and motivation as covariates. For some outcome variables, lognormal transformation was needed in order to compare exposure groups, including sural sensory nerve conduction and peroneal motor nerve conduction velocity.; Results:
Geometric mean ± SE of log(peroneal nerve motor conduction velocity) (m/second); - All fibers, NS; ○ All exposed: 47.71±1.01; ○ High exposed: 47.48±1.02; ○ Low exposed: 47.81±1.01; ○ Referent: 48.39±1.01; - Fastest fibers, NS; ○ All exposed: 49.00±1.01; ○ High exposed: 47.84±1.02; ○ Low exposed: 49.48±1.02; ○ Referent: 49.66±1.02; - Slowest fibers, NS; ○ All exposed: 38.53±1.03; ○ High exposed: 36.72±1.06; ○ Low exposed: 39.28±1.04; ○ Referent: 38.47±1.04 | Geometric mean ± SE of log(sural nerve sensory conduction velocity) (m/second), p<0.001; - All exposed: 36.81±1.09; - High exposed: 27.6±1.24; - Low exposed: 41.39±1.09; - Referent: 55.58±1.02; Multiple logistic regression analysis, β (SE):; - High exposed: −0.18 (0.07), p≤0.01; - Low exposed: −0.13 (0.05), p≤0.01
Interpretation: Significant association between carbon disulfide exposure and sural sensory nerve conduction velocity, after adjustment for confounders, in both low- and high-exposure group; therefore, the geometric mean exposure of the low exposure group (2.9 ppm) is a LOAEL for impaired nerve conduction velocity.
Reference: Hirata et al. 1996; Study type and population: Retrospective cohort of 46 viscose rayon workers (mean age of 43.9 years), including 24 current workers and 22 former workers, and 26 age-matched unexposed referents from Japan. Average duration of exposure of workers was 11.4 years. For the former workers, the average duration since cessation of exposure was 6.28±7.50 years.; Measured air concentration: Personal sampling (conducted 5 years prior to study), 8-hour TWA level:; - Arithmetic mean: 4.76 ppm; - Range: 2.3–17 ppm; Analysis: Subjects were excluded for history of neurological disease or injury or if they consumed more than 80 mL alcohol daily. Data were analyzed using Student’s t test and ANOVA with multiple comparison by Scheffe’s method.; Results:
Mean ± SD of ulnar nerve conduction velocities (m/second); - Motor conduction velocity, NS; ○ All exposed: 54.0±3.74; ○ Current: 53.8±3.56; ○ Former: 54.3±3.90; ○ Referent: 54.9±3.57; - Slow fiber motor conduction velocity, NS; ○ All exposed: 50.5±4.20; ○ Current: 49.6±4.47; ○ Former: 51.3±3.84; ○ Referent: 51.9±4.45; - Mixed nerve conduction velocity, NS; ○ All exposed: 58.5±3.80; ○ Current: 57.8±3.64; ○ Former: 59.3±3.81; ○ Referent: 59.1±3.58 | Mean ± SD of peroneal nerve motor conduction velocity (m/second); - All exposed: 43.2±2.61, p<0.05; - Current: 42.6±2.81, p<0.05; - Former: 43.4±2.11; - Referent: 44.9±2.70; Mean ± SD of sural nerve sensory conduction velocity (m/second); - All exposed: 49.9±5.04, p<0.05; - Current: 49.1±4.82, p<0.05; - Former: 50.0±5.06; - Referent: 53.4±4.96
Interpretation: Significant association between carbon disulfide exposure and sural sensory nerve conduction velocity and peroneal nerve motor conduction velocity in exposed workers. Therefore, the mean exposure of 4.76 ppm is a LOAEL for impaired nerve conduction velocity. Multiple comparison analysis indicates that findings are no longer significant in former workers, suggesting reversibility of effects in this population.
Reference: Johnson et al. 1983; Study type and population: Retrospective cohort of 145 male viscose rayon workers (mean age of 38.5 years) and 212 male referents (mean age 33.9 years) from the United States (Tennessee). Average duration of exposure of workers was 12.1 years.
Measured air concentration: Current mean (median) 8-hour TWAs (personal sampling); - Referent: 0.2 ppm; - Exposed: 7.3 ppm; - Low (n=44): 1.2 (1.0) ppm; - Moderate (n=61): 5.1 (4.1) ppm; - High (n=40): 12.6 (7.6) ppm | Cumulative exposure index:; - Low (n=44): 500–1,000 ppm-months; - Moderate (n=61): 1,000–1,500 ppm-month; - High (n=40): ≥1,500 ppm-months
Analysis: The numbers of men from minority groups and women were too small for valid comparisons; therefore, subjects were restricted to white male workers. Current and cumulative exposure data were analyzed using multivariate ANOVA, including age as a confounder. A two-way ANOVA was used to evaluate dose-effect relationships for nerve conduction velocities.; Results:
Mean ± SD of nerve conduction velocities, adjusted to temperature and terminal distance (m/second); - Ulnar nerve motor conduction velocity, NS; ○ All exposed: 55.9±6.3; ○ High: 55.0±6.6; ○ Moderate: 56.8±6.0; ○ Low: 55.5±6.4; ○ Referent: 56.9±6.7; - Sural nerve sensory conduction velocity; ○ All exposed: 40.4±4.0, p<0.01; ○ High: 40.5±3.0; ○ Moderate: 39.8±3.7; ○ Low: 41.2±5.2; ○ Referent: 41.8±3.4 | Mean ± SD of nerve conduction velocities, adjusted to temperature and terminal distance (m/second); - Peroneal nerve motor conduction velocity; ○ All exposed: 43.2±4.9, p<0.05; ○ High: 41.8±4.5, p<0.05; ○ Moderate: 43.4±4.8; ○ Low: 43.7±5.1; ○ Referent: 45.3±4.4; Cumulative exposure assessment:; - F-value (df): 122.8 (2,115); - PR>F: 0.05
Interpretation: Significant associations were observed between cumulative carbon disulfide exposure and peroneal nerve motor nerve conduction velocity. Group analysis indicated that conduction velocity was only significantly decreased in the highest exposure group. Therefore, the median exposures of 4.1 and 7.6 ppm are considered NOAEL and LOAEL values, respectively, for impaired nerve conduction velocity. A significant decrease in sural nerve sensory conduction velocity was observed in all workers (combined) compared to referents; however, exposure group data did not reveal a concentration-dependent effect.
Reference: Kim et al. 2000; Study type and population: Subcohort of 262 viscose rayon workers and 49 unexposed referents from a larger retrospective cohort in Korea (1,237 workers, 315 referents). Mean ages of the large cohort were 32.5–38.6 years. Duration of exposure of workers was 1–≥15 years.
Measured air concentration: Historical range of mean 8-hour TWA levels (“direct measurements” in different workplaces); - 1986-1992: 0.43–6.28 ppm | Cumulative exposure index:; - Referents (n=49): 0 ppm-years; - Low (n=67): 0.1–49.9 ppm-years; - Moderate (n=74): 50.0–149.9 ppm-years; - High (n=72): ≥150 ppm-years
Analysis: Data were analyzed by comparing the proportion of subjects with abnormal findings across four exposure categories, adjusting for age. Dose-response relationship was evaluated by test of linearity by Cochran-Mantel-Haenszel chi-square test.; Results:
Prevalence of abnormal sensory or motor nerve conduction (median, ulnar, peroneal, and/or tibial nerve):; - All exposed: 28.7; - High: 36.1; - Moderate: 34.5; - Low: 30.1; - Referent: 7.3 p-trend <0.001 | Prevalence ratio (95% CI):; - Exposed/non-exposed: 4.14 (1.59–10.79)
Interpretation: The prevalence of abnormal sensory and/or motor nerve conduction velocity was significantly increased in exposed workers, compared to control. Cumulative exposure analysis showed an association with concentration-duration. Based on available exposure data, the midpoint of the range of exposure means (3.36 ppm) is a LOAEL for impaired nerve conduction velocity.
Reference: Reinhardt et al. 1997a; Study type and population: Retrospective cohort of 222 viscose rayon workers (mean age 35 years) and 191 unexposed referents (mean age 33 years) from Germany. Median duration of exposure of workers was 6 years.; Measured air concentration: Median (range) current air concentrations; - 4.02 (0.2–30) ppm; Note: The study authors calculated cumulative exposure indices for analyses; however, cumulative exposure indices were not reported.; Analysis: Subjects were excluded for alcohol-related neuropathy, diabetes mellitus, and previous work with exposure to potentially neurotoxic solvents. Data were analyzed using cumulative exposure indices and multiple linear regression analysis, using age, weight, height, HbA1c, cigarette consumption (in pack-years), and alcohol consumption as covariates.; Results:
Median (range) of peroneal nerve motor conduction velocity (m/second); - Exposed: 48.00 (35.50–58.80); - Referent: 49.80 (34.30–58.60) | Mean (SD) of sural nerve sensory conduction velocity (m/second); - Exposed: 48.70 (39.70–58.90); - Referent: 49.10 (41.00–58.30)
Multiple linear regression analysis, β; - Exposed versus referent: −0.78, p<0.05; - Cumulative exposure: −0.05, NS | Multiple linear regression analysis, β; - Exposed versus referent: +0.39, NS; - Cumulative exposure: −0.75, NS
Interpretation: Cumulative exposure was not significantly associated with motor or sensory nerve conduction velocity, after adjustment for confounders. Therefore, the median exposure value of 4.02 is considered a NOAEL for impaired nerve conduction velocity.
Reference: Yoshioka et al. 2017; Study type and population: Longitudinal cohort of 347 male viscose rayon workers (mean age 36.1 years) and 337 unexposed male referents (mean age 36.2 years) from Japan. Average duration of exposure of workers was 22.1 years at baseline (1992–1993). Workers were re-examined at 6-year follow-up (1998–1999). In the exposure group, 121 workers ceased employment and/or exposure during the 6-year follow-up period (ex-exposed).; Measured air concentration: During 6-year follow-up period (breathing zone measurements)
- 1^st^ Tertile: 0.8–4.6 ppm (mean 2.84 ppm); - 2^nd^ Tertile: 4.7–6.6 ppm (mean 5.64 ppm); - 3^rd^ Tertile: 6.6–16.0 ppm (mean 9.35 ppm) | - Mean (exposed): 5.96; - Mean (ex-exposed) 3.93
Analysis: Subjects were excluded for medical history of cerebrovascular or cardiovascular disease. Data were analyzed using ANOVA with the Tukey-Kramer method. Multiple linear regression was conducted, adjusting for age, BMI, education status (high school or above versus junior high school or below), smoking status (former or current smoker versus never smoked), and alcohol consumption (occasional or habitual drinker versus non-drinker).; Results:
Mean ± SD of reduction in median nerve motor conduction velocity over 6-year follow-up (m/second), NS; - Currently exposed: −1.60±3.70; - Ex-exposed: −1.61±3.37; - 1^st^ tertile: −1.62±3.56; - 2^nd^ tertile : −1.36±3.92; - 3^rd^ tertile: −1.81±3.64; - Referent: −1.52±3.49 | Mean ± SD of reduction in median nerve sensory conduction velocity over 6-year follow-up (m/second); - Currently exposed: −4.47±3.94, p<0.05; - Ex-exposed: −3.26±3.79; - 1^st^ tertile: −4.23±3.76; - 2^nd^ tertile: −4.27±3.65; - 3^rd^ tertile: −4.89±4.39, p<0.05; - Referent: −3.38±3.97
Multiple linear regression analysis, β; - 1^st^ tertile versus referent: −0.074, NS; - 2^nd^ tertile versus referent: 0.259, NS; - 3^rd^ tertile versus referent: −0.187, NS | Multiple linear regression analysis, β; - 1^st^ tertile versus referent: −0.153, NS; - 2^nd^ tertile versus referent: −0.350, NS; - 3^rd^ tertile versus referent: −1.021, p<0.05
Interpretation: Exposure to carbon disulfide in the highest tertile was associated with a significant reduction in median nerve sensory conduction velocity over the 6-year follow-up period, after adjusting for confounders. Therefore, the mean exposures of 5.64 and 9.34 ppm are considered NOAEL and LOAEL values, respectively, for impaired nerve conduction velocity.

ANOVA = analysis of variance; BMI = body mass index; CI = confidence interval; LOAEL = lowest observed adverse effect level; NOAEL = no observed adverse effect level; NS = not significant; SD = standard deviation; SE = standard error; TWA = time-weighted average

Selection of the Point of Departure for the MRL: The 95% lower confidence limit of the weighted median of 4.02 ppm based on the NOAEL/LOAEL boundary for impaired peripheral nerve conduction in the seven principal studies was selected as the POD for the chronic-duration inhalation MRL.

In order to determine the POD, occupational studies providing adequate exposure assessments to estimated NOAEL and/or LOAEL determinations for impaired peripheral nerve conduction velocity in workers exposed to carbon disulfide were considered as principal studies for the derivation of the chronic-duration inhalation MRL (Table A-7).

Table A-7 NOAEL and LOAEL Values for Occupational Cohort Studies Evaluating Altered Peripheral Nerve Conduction in Viscose Rayon Workers

Study | Measured air concentration (ppm) | | Measurement metric^a^
Study | NOAEL | LOAEL | Measurement metric^a^
Cirla and Graziano 1981 | 5.6 | | Midpoint; range of means over 12 years (3.2–8.0 ppm)
Godderis et al. 2006 | | 2.9 | Annual geometric mean
Hirata et al. 1996 | | 4.76 | Mean 8-hour TWA (measured 5 years prior)
Johnson et al. 1983 | 4.1 | 7.6 | Current median 8-hour TWA
Kim et al. 2000 | | 3.36 | Midpoint; range of means (1986-1992; 0.43–6.28 ppm)
Reinhardt et al. 1997a | 4.02 | | Current median
Ruijten et al. 1990 | | 8.25^b^ | Mean TWA exposure over duration of employment
Ruijten et al. 1993 | | 8.16^c^ | Mean TWA exposure over duration of employment
Yoshioka et al. 2017 | 5.64 | 9.35 | Mean air concentrations during 6-year study
Median | 4.85 | 7.60

a Central estimate of exposure, as reported by the study author (best available).

b Calculated from reported mean cumulative exposure of 165 ppm-years divided by the mean exposure of 20 years; value is consistent with the reported range of means (1–17 ppm).

c Calculated from reported mean cumulative exposure of 213 ppm-years divided by mean exposure of 26.1 years.

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; TWA = time-weighted average

Typically, the POD would be the highest NOAEL below the lowest LOAEL or the lowest free-standing LOAEL. The problem with this approach being applied to the occupational worker nerve conduction studies is that there is substantial overlap in reported NOAELs and LOAELs. The overlap between the lower end of the LOAEL range and the NOAEL range does not support selection of any single NOAEL or LOAEL as a POD. As an alternative approach, the following was assumed:

1. A NOAEL/LOAEL boundary exists and is located somewhere within the range of overlapping NOAELs and LOAELs.
2. Each NOAEL and LOAEL in this range represents an independent estimate of the NOAEL/LOAEL boundary.
3. The best estimate of the NOAEL/LOAEL boundary is the weighted median of the set of overlapping NOAELs and LOAELs (weighted for study size, which assumes greater confidence in estimates from larger studies).
4. The lower 95% confidence limit on the median was selected as the POD to account for uncertainty in the estimated weighted median.

This approach avoids having to make a highly uncertain selection of a single study as the basis for the POD. Instead, this approach utilizes information from multiple studies to identify an exposure that is most likely to be the NOAEL/LOAEL boundary, a threshold exposure level at which neurological effects may (or may not) occur. The POD is then set at the lower 95% confidence limit of the NOAEL/LOAEL boundary to account for uncertainty in the estimate.

Overlapping NOAELs and LOAELs include all LOAELs that are less than or equal to the highest NOAEL for the outcome (5.64 ppm; Yoshioka et al. 2017), plus all NOAELs that are greater than or equal to the lowest LOAEL (2.9 ppm; Godderis et al. 2006). That is, all the values from Table A-7 that fall within the NOAEL/LOAEL boundary range of 2.9–5.64 ppm were included in the calculation of the POD. Based on these criteria, all studies had at least one value included in the MRL calculation (Table A-8), with the exception of Ruitjen et al. (1990, 1993), which only identified LOAEL values >5.64 ppm. Therefore, the studies by Ruitjen et al. (1990, 1993) were excluded from the POD calculation. NOAEL/LOAEL values were used instead of BMC/BMCL values for each study for the following reasons:

- Quantitative data were not available or not amenable to modeling (e.g., reported for only a single exposure group): Cirla and Graziano 1981; Hirata et al. 1996; Kim et al. 2000; Reinhardt et al. 1997a.
- Available quantitative data are amenable to modeling; however, the only values reported are raw values unadjusted for key confounders (e.g., age, height, BMI): Godderis et al. (2006); Johnson et al. (1983); and Yoshioka et al. (2017). For these cohorts, NOAEL/LOAEL determinations based on multivariable regressions accounting for confounders are considered more reliable estimates of the true adverse effect levels.
- As reviewed by Price et al. (1996), several groups have obtained raw data from NIOSH for the Johnson et al. (1983) study and conducted BMD modeling, including modeling with adjustment for confounders; however, only BMC values (not BMCL) values were calculated. Calculated BMC values (11.8–20.0 ppm) are outside the NOAEL/LOAEL boundary range identified for the derivation of the chronic-duration inhalation MRL and are therefore not useful for this analysis.

Table A-8 NOAEL and LOAEL Values for Studies Defining the NOAEL/LOAEL Boundary for Altered Peripheral Nerve Conduction

Study | Study type | Subject number | POD | Measured air concentration^a^ (ppm)
Cirla and Graziano 1981 | Retrospective cohort | 100 | NOAEL | 5.6
Godderis et al. 2006 | Retrospective cohort | 151 | LOAEL | 2.9
Hirata et al. 1996 | Retrospective cohort | 72 | LOAEL | 4.76
Johnson et al. 1983 | Retrospective cohort | 357 | NOAEL | 4.1
Kim et al. 2000 | Retrospective cohort | 311 | LOAEL | 3.36
Reinhardt et al. 1997a | Retrospective cohort | 413 | NOAEL | 4.02
Yoshioka et al. 2017 | Longitudinal cohort | 684 | NOAEL | 5.64
Median NOAEL/LOAEL boundary (95% CI ^b^ ) | | | | 4.10 (3.36, 5.60)
Weighted^c^ median NOAEL/LOAEL boundary (95% CI^b^) | | | | 4.76 (4.02, 5.64)

a POD values are based on the best available central estimate of exposure, as reported by the study author (see Table A-7 for details).

b The 95% CI for the median was calculated using a nonparametric bootstrap (the 97.5th percentile of 10,000 calculations of the weighted median where the probability of selection of any study to include in each median was N_study/N_all studies)

c Median weighted based upon the number of subjects in the study. The lower CI (4.02 ppm) is the selected POD for the chronic-duration inhalation MRL.

CI = confidence interval; LOAEL = lowest observed adverse effect level; NOAEL = no observed adverse effect level; POD = point of departure

Adjustment for Intermittent Exposure: The POD of 4.02 ppm (based on the 95% confidence interval on the weighted median) was adjusted for a continuous exposure scenario, assuming a standard work week of 8 hours/day, 40 hours/week.

P O D_A D J_ = P O D × (hours / day)/(24 h o u r s) × (days / week)/(7 d a y s) = 4.02 p p m × (8 h o u r s)/(24 h o u r s) × (5 d a y s)/(7 d a y s) = 0.957 p p m

Uncertainty Factor: The following uncertainty factors were then applied to the POD_ADJ_ to derive the MRL.

- 10 for human variability

Subsequently, the inhalation MRL for chronic-duration exposure to carbon disulfide is:

M R L = (P O D_A D J_)/(( U F )) = (0.957 p p m)/(10) = 0.0957 p p m ≈ 0.1 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Based upon systematic review, the nervous system is a known target of carbon disulfide toxicity in humans following inhalation exposure based on a high level of evidence in humans and a high level of evidence in laboratory animals (Appendix C).

In humans, there is strong evidence for exposure-related damage to the peripheral nervous system. Findings from occupational cohorts clearly show associations that are both concentration- and duration-dependent. Altered nerve conduction velocity, which is the most sensitive neurological endpoint associated with carbon disulfide exposure, has been reported in several cohorts of viscose rayon workers (Hirata et al. 1996; Kim et al. 2000; Johnson et al. 1983; Ruijten et al. 1990, 1993; Seppalainen and Tolonen 1974; Vanhoorne et al. 1995; Yoshioka et al. 2017). Some of these studies also reported increased self-reported symptoms of polyneuropathy at exposure concentrations ranging from 0.43 to 36 ppm, such as pain, insensitive spots, paresthesia, numbness, and difficulty walking (Kim et al. 2000; Vanhoorne et al. 1994). Overt polyneuritis or polyneuropathy are common findings among highly exposed workers (≥100 ppm), including impaired nerve conduction, subjective complaints, decreased pain sensitivity, tremors, and abnormal movements resembling early Parkinsonism (Chapman et al. 1991; Chu et al. 1995; Lancranjan et al. 1972; Peters et al. 1988; Vasilescu 1976).

In animals, evidence of peripheral nerve damage includes impaired peripheral nerve conduction velocity and behavioral/clinical evidence of peripheral nerve damage (e.g., foot drag, hindlimb paralysis) (Frantik 1970; Graham and Popp 1992a; Herr et al. 1998; Phillips 1983a, 1983b, 1983c; Rebert and Becker 1986; Wrońska-Nofer 1973). Some of the clinical signs may be associated with damage to both the peripheral nerves as well as observed damage to nerve tracts in the spinal cord (Graham and Popp 1992a; Phillips 1983a, 1983b; Valentine et al. 1997).

The proposed mechanism of action (MOA) for peripheral neuropathy following carbon disulfide is biologically plausible in humans. The proposed MOA is based on the formation of crosslinked neurofilaments resulting in axonal damage via the following steps: (1) formation of dithiocarbamate protein adducts; (2) adducts decompose or oxidize to form an electrophile; (3) electrophile reactions with protein nucleophiles, resulting in protein crosslinking; (4) progressive cross-linking of stable neurofilaments during axonal anterograde transport; (5) crosslinked masses block transport at nodes of Ranvier (impeding peripheral nerve signals); and (6) axonal swelling and degeneration (EC/HC 2000; Graham et al. 1995; Harry et al. 1998; Llorens 2013; Newhook et al. 2001). These protein adducts have been demonstrated in rats following inhalation exposure to carbon disulfide (Valentine et al. 1993, 1997).

Agency Contacts (Chemical Managers): Custodio Muianga

## Carbon disulfide Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Carbon disulfide
CAS Numbers: | 75-15-0
Date: | July 2025
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.03 mg/kg/day
Critical Effect: | Increased resorptions/litter
Reference: | NCTR 1984b
Point of Departure: | LOAEL of 25 mg/kg/day
Uncertainty Factor: | 1,000
LSE Graph Key: | 9
Species: | Rabbit

MRL Summary: An acute-duration oral MRL of 0.03 mg/kg/day was derived for carbon disulfide based on developmental effects (increased resorptions per litter) in rabbits exposed to concentrations ≥25 mg/kg/day from GDs 6–19; a NOAEL was not identified (NCTR 1984b). The MRL is based on a LOAEL of 25 mg/kg/day, which was divided by a total uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: Endpoints identified as presumed (neurological) or suspected (developmental) human health effects following oral exposure based on systematic review (Appendix C) were considered as candidate critical effects for the acute-duration oral MRL. No reliable acute-duration human data are available. In animals, the most sensitive effects following acute-duration oral exposure are developmental effects (Table A-9). Therefore, developmental effects were selected as the critical effect for the acute-duration oral MRL.

Table A-9 Selected LOAEL Values in Animals for Acute-Duration Oral Exposure to Carbon Disulfide

Species | Duration | Effect level (mg/kg/day) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Rabbit | 14 days; GDs 6–19 | ND | 25 | Developmental: 32% resorptions per litter (compared to 12% in controls) | NCTR 1984b
Rat | 10 days | 10 | 50 | Neurological: Lethargy | NCTR 1984a
Rabbit | 14 days; GDs 6–19 | 75 | 150; (SLOAEL) | Developmental: 19% fetuses with malformations; 31% decrease in live fetuses/litter; 61% resorptions/litter | NCTR 1984b
Rabbit | 14 days; GDs 6–19 | 100 | 200; (SLOAEL) | Neurological: Convulsions; Developmental: 4/5 litters with complete resorption | NCTR 1984b
Rat | 10 days; GDs 6–15 | 100 | 200 | Developmental: 6% decrease in fetal weight | NCTR 1984a
Rat | Once | ND | 300 | Neurological: Decreased norepinephrine and increased dopamine in the brain | Kanada et al. 1994
Rat | 10 days; GDs 6–15 | 200 | 400; (SLOAEL) | Neurological: Hindlimb paralysis in dams | NCTR 1984a

Selected study for derivation of acute-duration oral MRL.

GD = gestation day; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: NCTR (1984b) was selected as the principal study because it identifies the lowest LOAEL for the critical effect (developmental toxicity).

Summary of the Principal Study:

NCTR. 1984b. Teratologic evaluation of carbon disulfide (CAS No. 75-15-0) administered to New Zealand white rabbits on gestational days 6 through 19. Research Triangle Park, NC: National Center for Toxicological Research. PB84192350. NCTR222802031.

Carbon disulfide was administered to artificially-inseminated New Zealand White rabbits (26–30/group) at doses of 0, 25, 75, or 150 mg/kg/day via gavage in corn oil on GDs 6–19. Does were sacrificed on GD 30. Females were weighed and observed for clinical signs of toxicity. At sacrifice, the gravid uterus was weighed, and the number of implantations sites, live, dead, and resorbed fetuses were recorded. All live fetuses were weighed and examined for gross external, visceral, and skeletal malformations. Each dose was tested in two separate replicates, and statistics were conducted for dose, replicate, and dose x replicate.

No exposure-related mortality was observed. Occasional clinical signs were observed shortly after dosing, predominately at 150 mg/kg/day. The most frequent was reduction or lack of daily fecal output in up to 7/26 animals and alopecia in up to 4/26 animals; other findings were limited to a few animals across all dose groups. Maternal weight gain during gestation was decreased at ≥75 mg/kg/day; however, no exposure-related differences were noted once body weights were controlled for gravid uterine weight (which was decreased at ≥75 mg/kg/day due to increased resorptions). Maternal absolute and relative liver weights were elevated at ≥75 mg/kg/day. At sacrifice on day 30, there were no differences in corpora lutea, implantation sites, or preimplantation loss per doe. However, the number of resorptions/litter was increased by 2.9-, 4.2-, and 5.4-fold at 25, 75, and 150 mg/kg/day, respectively. Consistent with this finding, the percent resorptions per litters was also significantly increased at all exposure doses (mean values of 12.30, 32.47, 41.60, and 61.16% resorptions at 0, 25, 75, and 150 mg/kg/day, respectively). The number of live fetuses/litter was significantly decreased at 150 mg/kg/day only, compared to control. There was a trend toward decreased average live fetal body weight across dose groups; however, no pairwise effects were noted. Regarding malformations among fetuses, there was a significant increase in percent fetuses malformed per litter at 150 mg/kg/day (19.21%) compared to control (5.72%); however, there was no characteristic malformation associated with carbon disulfide exposure. Males were affected to a greater extent than females. The teratogenic effect of carbon disulfide appears to be more severe in males at the 150 mg/kg/day dose than in females (when separated by dose, p<0.036 for males and p<0.481 for females), whereas the percent live fetuses and average fetal body weight were not related to sex.

Selection of the Point of Departure for the MRL: The LOAEL of 25 mg/kg/day for increased resorptions/litter was selected as the POD for the acute-duration oral MRL.

In order to identify the POD, BMD modeling was attempted for both resorptions per litter and percent resorptions per litter reported by NCTR (1984b). The litter resorption data modeled are shown in Table A-10. Data were fit to all available continuous models in EPA’s BMDS (version 3.3) using a BMR of 5% relative deviation since data are for a developmental endpoint. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, BMDL (95% lower confidence limit on the BMD) that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Based on these criteria, none of the models tested adequately fit the data for either dataset. All models for resorptions per litter or percent resorptions per litter were deemed questionable or unusable by BMDS using constant or non-constant variance. Therefore, the LOAEL of 25 mg/kg/day was selected as the POD for the acute-duration oral MRL.

Table A-10 Resorption Data for Pregnant Rabbits Following Gavage Exposure to Carbon Disulfide on GDs 6–19

| Dose (mg/kg/day)
| 0 | 25 | 75 | 150
Percent resorptions per litter^a^ | 12.30±21.15; (27) | 32.47±38.37^b^; (23) | 41.60±40.96^c^; (28) | 61.16±37.25^c^; (25)
Resorptions per litter^a^ | 0.85±1.30; (27) | 2.45±3.17^d^; (23) | 3.54±3.97^e^; (28) | 4.56±3.35^e^; (25)

a Mean±SD (number of animals). SD values calculated from reported SEM values (SD = SEM * √N).

b p<0.05, as reported by the study authors.

c p<0.01, as reported by the study authors.

d p<0.05, as calculated by Student’s t-test for this review (Graph-Pad).

e p<0.01, as calculated by Student’s t-test for this review (Graph-Pad).

GD = gestation day; N = number of animals; SEM = standard error of the mean; SD = standard deviation

Source: NCTR 1984b

Adjustment for Intermittent Exposure: None

Uncertainty Factor: The following uncertainty factors were applied to the LOAEL to derive the MRL:

- Uncertainty factor of 10 for use of a LOAEL
- Uncertainty factor of 10 for extrapolation from animals to humans
- Uncertainty factor of 10 for human variability

Subsequently, the MRL for acute-duration exposure to carbon disulfide via oral exposure is:

M R L = (L O A E L)/(( U F )) = (25 m g / k g / d a y)/(1,000) = 0.025 m g / k g / d a y ≈ 0.03 m g / k g / d a y

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Based upon systematic review, the developmental system is a suspected target of carbon disulfide toxicity in humans based on inadequate data in humans and a moderate level of evidence in laboratory animals (Appendix C).

Data pertaining to developmental toxicity in humans are limited to a single occupational-exposure study, which did not observe an association between occupational exposure during pregnancy and congenital malformations (Zhou et al. 1988).

In animals, developmental effects have been observed in two species (rats and rabbits) following oral exposure to carbon disulfide during gestation (NCTR 1984a, 1984b). Of the two species, rabbits appear to be more susceptible. In the dose-range-finding study for the principal study, complete resorption was observed in four of five litters following maternal exposure to 200 mg/kg/day on GDs 6–19, with high maternal mortality at ≥400 mg/kg/day (NCTR 1984b). In rats, developmental effects were observed at ≥200 mg/kg/day, including mild decreases in fetal weight; maternal toxicity was observed at 400 mg/kg/day (NCTR 1984a). However, another gestational exposure study did not observe exposure-related effects on fetal weight at concentrations up to 1,200 mg/kg/day, despite maternal toxicity (decreased body weight) at 1,200 mg/kg/day (Tsai et al. 2000).

Inhalation exposure studies also reported developmental effects in both rats and rabbits following gestational exposure to carbon disulfide, including increased post-implantation loss, decreased fetal body weight, decreased neonatal viability, and fetal malformations (Denny and Gerhart 1991; Holson 1992; Saillenfait et al. 1989; Tabacova and Balabaeva 1980; Tabacova et al. 1978, 1983). Postnatal exposure was associated with increased perinatal mortality, delayed reflex ontology, and impaired neurodevelopment (Lehotzky et al. 1985).

Agency Contacts (Chemical Managers): Custodio Muianga

## Carbon disulfide Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Carbon disulfide
CAS Numbers: | 75-15-0
Date: | July 2025
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: The intermediate-duration oral database is limited. No human studies were identified. The lowest identified LOAELs in the four available animal studies (Table A-11) are markedly higher (≥200 mg/kg/day) than the lowest identified acute-duration LOAEL (25 mg/kg/day), precluding derivation of an intermediate-duration oral MRL.

Table A-11 Selected LOAEL Values in Animals for Intermediate-Duration Oral Exposure to Carbon Disulfide

Species | Duration | Effect level (mg/kg/day) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Rat | 20 days | ND | 200 | Neurological: Impaired memory | Wang et al. 2017
Rat | 6 weeks | ND | 200 | Body weight: 10% decrease in body weight | Gao et al. 2014; Wang et al. 2016
Rat | 8 weeks | ND | 300 | Neurological: Mild gait impairments, motor incoordination, impaired nerve conduction | Liu et al. 2023, 2024
Rat | 12 weeks | ND | 300 | Neurological: Mild gait impairments | Song et al. 2009
Rat | 6 weeks | 200 | 400; (SLOAEL) | Neurological: Tremors; moderate-to-severe gait impairments | Gao et al. 2014; Wang et al. 2016

ECG = electrocardiogram; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Agency Contacts (Chemical Managers): Custodio Muianga

## Carbon disulfide Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Carbon disulfide
CAS Numbers: | 75-15-0
Date: | July 2025
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: No human or animal studies evaluating potential effects of chronic-duration oral exposure to carbon disulfide were identified, precluding derivation of chronic-duration oral MRL.

Agency Contacts (Chemical Managers): Custodio Muianga