# CHAPTER 8 REFERENCES

Alderson MR, Rattan NS. 1980. Mortality of workers on an isopropyl alcohol plant and two MEK dewaxing plants. Br J Ind Med 37(1):85–89. 10.1136/oem.37.1.85.7370197
Allen N, Mendell JR, Billmaier DJ, 1975. Toxic polyneuropathy due to methyl n-butyl ketone. An industrial outbreak. Arch Neurol 32(4):209–218. 10.1001/archneur.1975.00490460025001.164846
Altenkirch H, Stoltenburg G, Wagner HM. 1978. Experimental studies on hydrocarbon neuropathies induced by methyl-ethyl-ketone (MEK). J Neurol 219(3):159–170. 10.1007/BF00314531.84859
Altenkirch H, Stoltenburg-Didinger G, Wagner H. 1979. Experimental data on the neurotoxicity of methyl-ethyl-ketone. Experentia 35(4):503–504. 10.1007/BF01922732.
Altenkirch H, Mager J, Stoltenburg G, 1977. Toxic polyneuropathies after sniffing a glue thinner. J Neurol 214(2):137–152. 10.1007/BF02430351.64597
Altenkirch H, Wagner HM, Stoltenburg G, 1982. Nervous system responses of rats to subchronic inhalation of N-hexane and N-hexane + methyl-ethyl-ketone mixtures. J Neurol Sci 57(2-3):209–219. 10.1016/0022-510x(82)90028-4.6891717
Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3(6):272–290. 10.1002/jat.2550030603.6376602
Anbar M, Neta P. 1967. A compilation of specific bimolecular rate constant for the reactions of hydrated electrons, hydrogen atoms and hydroxyl radical with inorganic and organic compounds in aqueous solution. Int J Appl Radiat Isot 18(7):493–523. 10.1016/0020-708X(67)90115-9.
Anderson C, Sundberg K, Groth O. 1986. Animal model for assessment of skin irritancy. Contact Dermatitis 15(3):143–151. 10.1111/j.1600-0536.1986.tb01315.x.3780215
Aoki K, Zhao W, Misumi J, 1996. Changes in 2,5-hexanedione concentration in the Sciatic Nerve, serum and urine of rats induced by combined administration of 2,5-hexanedione with acetone or methyl ethyl ketone. J Occup Health 38(1):30–35.
Atkinson R. 1985. Kinetics and mechanisms of the gas-phase reactions of hydroxyl radical with organic compounds under atmospheric conditions. Chem Rev 85:69–201.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2005a. Health consultation: State of Arizona Silver Creek Subdivision. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/hac/PHA/StateOfArizona-SilverCreekSudv/SilverCreekHCFinal060305.pdf. August 12, 2020.
ATSDR. 2005b. Health consultation: Evaluation of potential soil gas migration in residences adjacent to the Pemaco Superfund site Maywood, Los Angeles County, California. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/PemacoSuperfundSite042905/PemacoHC042505.pdf. August 12, 2020.
ATSDR. 2019. 2-Butanone. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Babeu L, Vaishnav DD. 1987. Prediction of biodegradability for selected organic chemicals. J Ind Microbiol 2(2):107–115. 10.1007/BF01569509.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Basler A. 1986. Aneuploidy-inducing chemicals in yeast evaluated by the micronucleus test. Mutat Res 174(1):11–13. 10.1016/0165-7992(86)90070-9.3517637
Beliveau M, Krishnan K. 2000. Estimation of rat blood:air partition coefficients of volatile organic chemicals using reconstituted mixtures of blood components. Toxicol Lett 116(3):183–188. 10.1016/s0378-4274(00)00219-8.10996479
Berg EF. 1971. Retrobulbar neuritis. A case report of presumed solvent toxicity. Ann Ophthalmol 3(12):1351–1253.5138224
Bertsch W, Anderson E, Holzer G. 1975. Trace analysis of organic volatiles in water by gas chromatography-mass spectrometry with glass capillary columns. J Chromatogr 112:701–718. 10.1016/s0021-9673(00)99998-9.1184697
Billmaier D, Allen N, Craft B, 1974. Peripheral neuropathy in a coated fabrics plant. J Occup Med 16(10):665–671.4375708
Blair A, Hartge P, Stewart PA, 1998. Mortality and cancer incidence of aircraft maintenance workers exposed to trichloroethylene and other organic solvents and chemicals: extended follow up. Occup Environ Med 55(3):161–171. 10.1136/oem.55.3.161.9624267
Brady JF, Li D, Ishizaki H, 1989. Induction of cytochromes P450IIE1 and P450IIB1 by secondary ketones and the role of P450IIE1 in chloroform metabolism. Toxicol Appl Pharmacol 100(2):342–349. 10.1016/0041-008x(89)90320-7.2781561
Bridie AL, Wolff CJ M, Winter M. 1979. BOD and COD of some petrochemicals. Water Res 13(7):627–630. 10.1016/0043-1354(79)90011-3.
Brooke I, Cocker J, Delic JI, 1998. Dermal uptake of solvents from the vapour phase: An experimental study in humans. Ann Occup Hyg 42(8):531–540. 10.1016/s0003-4878(98)00064-7.9838866
Brown EM, Hewitt WR. 1984. Dose-response relationships in ketone-induced potentiation of chloroform hepato- and nephrotoxicity. Toxicol Appl Pharmacol 76(3):437–453. 10.1016/0041-008x(84)90348-x.6506071
Brown W, Setzer J, Dick R, 1986. Body burden profiles of single and mixed exposure to solvents. In: The changing nature of work and workforce, Proceedings of the Third Joint US-Finnish Science Symposium, Frankfort, Kentucky. Cincinnati, OH: National Institute for Occupational Safety and Health, 111–114.
Brown WD, Setzer JV, Dick RB, 1987. Body burden profiles of single and mixed solvent exposures. J Occup Med 29(11):877–883.3681498
Browning E. 1965. Ketones. In: Toxicity and metabolism of industrial solvents. New York, NY: Elsevier Publishing Co., 412–462.
Brugnone F, Perbellini L, Apostoli P, 1983. Environmental and biological monitoring of occupational methylethyl ketone exposure. Dev Toxicol Environ Sci 11:571–574.6677508
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: a review of past agency for toxic substances and Disease Registry public health evaluations. J Environ Health 75(9):36–41.
Callender TJ. 1995. Neurotoxic impairment in a case of methylethyl-ketone exposure. Arch Environ Health 50(5):392.7574898
Cammaerts MC, Inwood MR, Morgan ED, 1978. Comparative study of the pheromones emitted by workers of the ants Myrmica rubra and Myrmica scabrinodis. J Insect Physiol 24(3):207–214. 10.1016/0022-1910(78)90036-7.
CAS. 1989. Chemical Abstracts Registry File. September 19, 1989. Chemical Abstracts Service.
Cavender FL, Casey HW. 1981. 90-Day vapor inhalation toxicity study of methyl ethyl ketone in albino rats. Chemical Industrial Institute of Toxicology. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS84003A. 878212064. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0205953.xhtml. May 7, 2020.
Cavender FL, Casey HW, Salem H, 1983. A 90-day vapor inhalation toxicity study of methyl ethyl ketone. Fundam Appl Toxicol 3(4):264–270. 10.1016/s0272-0590(83)80138-9.6628888
Chia SE, Ong CN, Phoon WH, 1993. Neurobehavioural effects on workers in a video tape manufacturing factory in Singapore. Neurotoxicology 14(1):51–56.8361678
Chemline. 1989. National Library of Medicine Chemline Database. September 19, 1989.
Chou WL, Speece RE, Siddiqi RH. 1978. Acclimation and degradation of petrochemical wastewater components by methane fermentation. Biotechnol Bioeng Symp 8:391–414.
Churchill JE, Ashley DL, Kaye WE. 2001. Recent chemical exposures and blood volatile organic compound levels in a large population-based sample. Arch Environ Health 56(2):157–166. 10.1080/00039890109604068.11339680
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Coleman WE, Lingg RD, Melton RG, 1976. The occurrence of volatile organics in five drinking water supplies using gas chromatography/mass spectrometry. In: Keith L, ed. Analysis and identification of organic substances in water. Ann Arbor, MI: Ann Arbor Science, 305–327.
Conkle JP, Camp BJ, Welch BE. 1975. Trace composition of human respiratory gas. Arch Environ Health 30(6):290–295. 10.1080/00039896.1975.10666702.1137435
Corwin JF. 1969. Volatile oxygen-containing organic compounds in seawater: Determination. Bull Mar Sci 19:504–559.
Cosnier F, Nunge H, Brochard C, 2014. Impact of coexposure on toluene biomarkers in rats. Xenobiotica 44(3):217–228. 10.3109/00498254.2013.830204.24015909
Cosnier F, Grossmann S, Nunge H, 2018a. Metabolism of inhaled methylethylketone in rats. Drug Chem Toxicol 41(1):42–50. 10.1080/01480545.2017.1289220.28633598
Cosnier F, Nunge H, Bonfanti E, 2018b. Toluene and methylethylketone: effect of combined exposure on their metabolism in rat. Xenobiotica 48(7):684–694. 10.1080/00498254.2017.1362604.28783416
Couri D, Abdel-Rahman MS, Hetland LB. 1978. Biotransformation of n-hexane and methyl n-butyl ketone in guinea pigs and mice. Am Ind Hyg Assoc J 39(4):295–300. 10.1080/0002889778507761.645557
Cox GE, Bailey DE, Morgareidge K. 1975. Toxicity studies in rats with 2-butanol including growth, reproduction, and teratologic observations. Food and Drug Research Laboratories, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA section 8E. OTS0571256. 88-920009599. 8EHQ-1092-11318. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0571256.xhtml. May 7, 2020.
Cox RA, Derwent RG, Williams MR. 1980. Atmospheric photooxidation reactions. Rates, reactivity, and mechanism for reaction of organic compounds with hydroxyl radicals. Environ Sci Technol 14(1):57–61. 10.1021/es60161a007.
Cox RA, Patrick KF, Chant SA. 1981. Mechanism of atmospheric photooxidation of organic compounds. Reactions of alkoxy radicals in oxidation of n-butane and simple ketones. Environ Sci Technol 15(5):587–592. 10.1021/es00087a011.22283953
Cunningham J, Sharkawi M, Plaa GL. 1989. Pharmacological and metabolic interactions between ethanol and methyl n-butyl ketone, methyl isobutyl ketone, methyl ethyl ketone, or acetone in mice. Fundam Appl Toxicol 13(1):102–109. 10.1016/0272-0590(89)90310-2.2767350
Dahl AR, Snipes MB, Gerde P. 1991. Sites for uptake of inhaled vapors in beagle dogs. Toxicol Appl Pharmacol 109(2):263–275. 10.1016/0041-008x(91)90174-d.2068726
Darnall KR, Lloyd AC, Winer AM, 1976. Reactivity scales for atmospheric hydrocarbons based on reaction with hydroxyl radical. Environ Sci Technol 10(7):692–696. 10.1021/es60118a008.
Davis T, Baker R. 1975. Eye irritation tests with four samples of methyl ethyl ketone in albino rabbits. Celanese Chemical Corporation, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206023. 878211195. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0206023.xhtml. May 7, 2020.
De Ceaurriz J, Desiles J, Bonnet P, 1983. Concentration-dependent behavioral changes in mice following short-term inhalation exposure to various industrial solvents. Toxicol Appl Pharmacol 67:383–389. 10.1016/0041-008x(83)90322-8.6845368
Deacon M, Pilny M, John J, 1981. Embryotoxicity and fetotoxicity of inhaled methyl ethyl ketone in rats. Toxicol Appl Pharmacol 59:620–622. 10.1016/0041-008X(81)90317-3.7268783
Decker DW, Clark CS, Elia VJ, 1983. Worker exposure to organic vapors at a liquid chemical waste incinerator. Am Ind Hyg Assoc J 44(4):296–300. 10.1080/15298668391404833.6305180
Del Rosario R, De Lumen BO, Habu T, 1984. Comparison of headspace volatiles from winged beans and soybeans. J Agric Food Chem 32(5):1011–1015. 10.1021/jf00125a015.
Delfino JJ, Miles CJ. 1985. Aerobic and anaerobic degradation of organic contaminants in Florida groundwater. Soil Crop Sci Soc 44:9–12.
Dick RB, Setzer JV, Wait R, 1984. Effects of acute exposure of toluene and methyl ethyl ketone on psychomotor performance. Int Arch Occup Environ Health 54(2):91–109. 10.1007/BF00378512.6480127
Dick RB, Brown WD, Setzer JV, 1988. Effects of short duration exposures to acetone and methyl ethyl ketone. Toxicol Lett 43(1-3):31–49. 10.1016/0378-4274(88)90019-7.3176071
Dick RB, Setzer JV, Taylor BJ, 1989. Neurobehavioural effects of short duration exposures to acetone and methyl ethyl ketone. Br J Ind Med 46(2):111–121. 10.1136/oem.46.2.111.2923821
Dick RB, Krieg EF, Setzer J, 1992. Neurobehavioral effects from acute exposures to methyl isobutyl ketone and methyl ethyl ketone. Fundam Appl Toxicol 19(3):453–473. 10.1016/0272-0590(92)90185-k.1459376
Dietz FK, Traiger GJ. 1979. Potentiation of CCl4 hepatotoxicity in rats by a metabolite of 2-butanone: 2,3-butanediol. Toxicology 14(3):209–215. 10.1016/0300-483x(79)90003-9.542953
Dietz FK, Rodriguez-Giaxola M, Traiger GJ, 1981. Pharmacokinetics of 2-butanol and its metabolites in the rat. J Pharmacokinet Biopharm 9(5):553–576. 10.1007/BF01061026.7334459
Dilling WL, Bredeweg CJ, Tefertiller NB. 1976. Organic photochemistry. XIII. Simulated atmospheric photo decomposition rates of methylene chloride, 1,1,1-trichlcroethane, trichloroethylene, tetrachloroethylene, and other compounds. Environ Sci Technol 10(4):351–356. 10.1021/es60115a006.
DiVincenzo G, Kaplan C, Dedinas J. 1976. Characterization of the metabolites of methyl n-butyl ketone, methyl iso-butyl ketone, and methyl ethyl ketone in guinea pig serum and their clearance. Toxicol Appl Pharmacol 36:511–522. 10.1016/0041-008x(76)90230-1.941151
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/docs/Revision_29A_Table3.pdf. April 12, 2020.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/. April 12, 2020.
Doty RL, Deems DA, Frye RE, 1988. Olfactory sensitivity, nasal resistance, and autonomic function in patients with multiple chemical sensitivities. Arch Otolaryngol Head Neck Surg 114(12):1422–1427. 10.1001/archotol.1988.01860240072027.2461210
Dumont JP, Adda J. 1978. Occurrence of sesquiterpenes in mountain cheese volatiles. J Agric Food Chem 26(2):364–367. 10.1021/jf60216a037.
Dunovant VS, Clark CS, Que Hee SS, 1986. Volatile organics in the wastewater and airspaces of three wastewater plants. J Water Pollut Control Fed 58(9):886–895.
Kodak Eastman. 1978. Chronic skin application of MnBK, MEK, MiBK, MEK/MiBK and MEK/MnBK. Eastman Kodak Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206514. 878214321. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0206514.xhtml. May 7, 2020.
Edney EO, Kleindienst TE, Corse EW. 1986. Room temperature rate constants for the reaction of OH with selected chlorinated and oxygenated hydrocarbons. Int J Chem Kinet 18(12):1355–1371. 10.1002/kin.550181207.
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38. 10.1021/es00083a002.
EPA. 1974. Draft analytical report: New Orleans Water supply study. Dallas, TX: U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101WZ63.txt. May 7, 2020.
EPA. 1975. Preliminary assessment of suspected carcinogens in drinking water Interim report to Congress. Washington, DC: U.S. Environmental Protection Agency. EPA560475005. PB250961. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91012F6P.txt. May 7, 2020.
EPA. 1986. Validation of OH radical reaction rate constant test protocol. Washington, DC: U.S. Environmental Protection Agency. PB86166758. EPA68024033.
EPA. 1987a. Organic emission measurements via small chamber testing. Washington, DC: U.S. Environmental Protection Agency. PB87199154XAB. EPA600D87187. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB87199154.xhtml. May 7, 2020.
EPA. 1987b. Hydrolysis rate constants, partition coefficients, and their water solubilities for 129 chemicals. A summary of fate constants provided for the concentration-based listing program, 1987. Athens, GA: U.S. Environmental Protection Agency.
EPA. 1987c. Superfund record of decision: Galloway Ponds Site, Galloway, TN. U.S. Environmental Protection Agency. USEPARODR0486013. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91002B7W.txt. June 30, 2020.
EPA. 1987d. Superfund record of decision: Lang Property Pemberton Township, NJ. Washington, DC: U.S. Environmental Protection Agency. EPARODR0286031. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100SALM.txt. October 1, 2020.
EPA. 1988. National ambient volatile organic compounds (VOCS) database update. U.S. Environmental Protection Agency. EPA600388010A. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100SS3R.txt. May 7, 2020.
EPA. 2003. Toxicological review of methyl ethyl ketone. In support of summary information on the Integrated Risk Information System (IRIS). Washington, DC: U.S. Environmental Protection Agency. EPA635R03009. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0071tr.pdf. May 7, 2020.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://19january2017snapshot.epa.gov/sites/production/files/documents/ry2004rfi.pdf. May 7, 2020.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2011. Background indoor air concentrations of volatile organic compounds in North American residences (1990-2005): A compilation of statistics for assessing vapor intrusion. Washington, DC: U.S. Environmental Protection Agency. EPA530R10001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100GL6W.txt. August 12, 2020.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2018c. About Acute Exposure Guideline Levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2020. Chemical data reporting: 2-butanone. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2020-02/csv_data_file.zip. May 6, 2020.
FDA. 2020. 2-Butanone. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/index.cfm?set=FoodSubstances&id=BUTANONE. May 1, 2020.
Fisher GS, Legendre MG, Lovgren NV, 1979. Volatile constituents of southern pea seed [Vigna unguiculata (L.) Walp.]. J Agric Food Chem 27(1):7–11. 10.1021/jf60221a040.
Fisher J, Mahle D, Bankston L, 1997. Lactational transfer of volatile chemicals in breast milk. Am Ind Hyg Assoc J 58(6):425–431. 10.1080/15428119791012667.9183837
Francis AJ, Iden CR, Nine BJ, 1980. Characterization of organics in leachates from low-level radioactive waste disposal sites. Nucl Technol 50(2):158–163. 10.13182/NT80-A32541.
Gao Y, Zhang Y, Kamijima M, 2014. Quantitative assessments of indoor air pollution and the risk of childhood acute leukemia in Shanghai. Environ Pollut 187:81–89. 10.1016/j.envpol.2013.12.029.24463471
Gaudy AF, Turner BG, Pusztaszeri S. 1963. Biological treatment of volatile waste components. J Water Pollut Control Fed 35(1):75–93.
Geller I, Gause E, Kaplan H, 1979. Effects of acetone, methyl ethyl ketone and methyl isobutyl ketone on a match-to-sample task in the baboon. Pharmacol Biochem Behav 11(4):401–406. 10.1016/0091-3057(79)90115-1.118468
Ghittori S, Imbriani M, Pezzagno G, 1987. The urinary concentration of solvents as a biological indicator of exposure: proposal for the biological equivalent exposure limit for nine solvents. Am Ind Hyg Assoc J 48(9):786–790.3687738
Giroux D, Lapointe G, Baril M. 1992. Toxicological index and the presence in the workplace of chemical hazards for workers who breast-feed infants. Am Ind Hyg Assoc J 53(7):471–474. 10.1080/15298669291359960.1496936
Gordon DT, Morgan ME. 1972. Principal volatile compounds in feed flavored milk. J Dairy Sci 55(7):905–912. 10.3168/jds.S0022-0302(72)85595-4.
Graham DG. 2000. Critical analysis of Mitran (1997). Neurotoxicity associated with occupational exposure to acetone. Methyl ethyl ketone, and cyclohexanone. Environ. Res. 73, 181-188. Environ Res 82(2):181–185. 10.1006/enrs.1999.3988.
Grey TC, Shrimpton DH. 1967. Volatile components of raw chicken breast muscle. Br Poult Sci 8(1):23–33. 10.1080/00071666708415646.
Grosjean D. 1982. Formaldehyde and other carbonyls in Los Angeles ambient air. Environ Sci Technol 16(5):254–262. 10.1021/es00099a005.22257249
Grosjean D, Wright B. 1983. Carbonyls in urban fog, ice fog, cloudwater and rainwater. Atmos Environ 17(10):2093–2096. 10.1016/0004-6981(83)90368-2.
Gunster DG, Gillis CA, Bonnevie NL, 1993. Petroleum and hazardous chemical spills in Newark Bay, New Jersey, USA from 1982 to 1991. Environ Pollut 82(3):245–253. 10.1016/0269-7491(93)90126-9.15091773
Güsten H, Klasinc L, Marić D. 1984. Prediction of the abiotic degradability of organic compounds in the troposphere. J Atmos Chem 2(1):83–93. 10.1007/bf00127264.
Hall LW, Scott Hall W, Bushong SJ, 1987. In situ striped bass (Morone saxatilis) contaminant and water quality studies in the Potomac River. Aquat Toxicol 10(2-3):73–99. 10.1016/0166-445x(87)90016-6.
Halvorsen F, Ohneck R. 1985. MEK groundwater decontamination. In: Hazardous wastes and environmental emergencies. Silver Springs, MD: Hazardous Materials Control Research Institute, 193–195.
Hampton CV, Pierson WR, Harvey TM, 1982. Hydrocarbon gases emitted from vehicles on the road. 1. A qualitative gas chromatography/mass spectrometry survey. Environ Sci Technol 16(5):287–298. 10.1021/es00099a011.22257255
Hansch C, Leo A, Hoekman D. 1995. Methyl ethyl ketone. In: Heller SR, ed. Exploring QSAR, hydrophobic, electronic, and steric constants. Washington, DC: American Chemistry Society, 9.
Hansen LF, Knudsen A, Nielsen GD. 1992. Sensory irritation effects of methyl ethyl ketone and its receptor activation mechanism. Pharmacol Toxicol 71(3 Pt 1):201–208. 10.1111/j.1600-0773.1992.tb00546.x.1438043
Haskell Laboratory. 1971. Federal hazardous substances act tests - rabbit eye irritation. E.I. du Pont de Nemours and Company, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0215038. 8878220418. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0215038.xhtml. May 7, 2020.
Hawthorne SB, Sievers RE. 1984. Emission of organic air pollutants from shale oil wastewaters. Environ Sci Technol 18(6):483–490. 10.1021/es00124a016.22247953
Hazleton Laboratories. 1963a. Primary skin irritation - rabbits. Exxon Chemical Americas. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206264. 878210453. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0206264.xhtml. May 7, 2020.
Hazleton Laboratories. 1963b. Acute eye irritation - rabbits. Exxon Chemical Americas. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206264. 878210454. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0206264.xhtml. May 7, 2020.
Hewitt W, Brown E, Plaa G. 1983. Relationship between the carbon skeleton length of ketonic solvents and potentiation of chloroform-induced hepatotoxicity in rats. Toxicol Lett 16:297–304. 10.1016/0378-4274(83)90190-x.6857725
Hewitt L, Ayotte P, Plaa G. 1986. Modifications in rat hepato biliary function following treatment with acetone, 2-butanone, 2-hexanone, mirex or chlordecone and subsequently exposed to chloroform. Toxicol Appl Pharmacol 83:465–473. 10.1016/0041-008x(86)90229-2.2422788
Hewitt LA, Valiquette C, Plaa GL. 1987. The role of biotransformation-detoxication in acetone-, 2-butanone-, and 2-hexanone-potentiated chloroform-induced hepatotoxicity. Can J Physiol Pharmacol 65(11):2313–2318. 10.1139/y87-367.3449191
Hewitt LA, Palmason C, Masson S, 1990. Evidence for the involvement of organelles in the mechanism of ketone-potentiated chloroform-induced hepatotoxicity. Liver 10(1):35–48. 10.1111/j.1600-0676.1990.tb00433.x.2308479
Higgins CE, Griest WH, Olerich. 1983. Application of Tenax trapping to analysis of gas phase organic compounds in ultra-low tar cigarette smoke. J AOAC Int 66(5):1074–1083. 10.1093/jaoac/66.5.1074.
Hodgkin JH, Galbraith MN, Chong YK. 1982. Combustion products from burning polyethylene. J Macromol Sci Chem 17(1):35–43. 10.1080/00222338208056463.
Hoell D, Mensing T, Roggenbuck R, 2012. 2-Butanone. In: Ullmann’s encyclopedia of industrial chemistry. Weinheim, Germany: Wiley-VCH Verlag GmbH & Co., 1–14. 10.1002/14356007.a04_475.pub2.
IARC. 2020. Agents classified by the IARC Monographs, Volumes 1-125. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.fr/list-of-classifications. April 30, 2020.
Ichihara G, Saito I, Kamijima M, 1998. Urinary 2,5-hexanedione increases with potentiation of neurotoxicity in chronic coexposure to n-hexane and methyl ethyl ketone. Int Arch Occup Environ Health 71(2):100–104. 10.1007/s004200050255.9553785
Imaoka S, Funae Y. 1991. Induction of cytochrome P450 isozymes in rat liver by methyl n-alkyl ketones and n-alkylbenzenes. Effects of hydrophobicity of inducers on inducibility of cytochrome P450. Biochem Pharmacol 42(Suppl):S143–150. 10.1016/0006-2952(91)90404-s.1768271
Infante-Rivard C, Siemiatycki J, Lakhani R, 2005. Maternal exposure to occupational solvents and childhood leukemia. Environ Health Perspect 113(6):787–792. 10.1289/ehp.7707.15929905
IRIS. 2003. Methyl ethyl ketone (MEK). Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0071_summary.pdf. November 16, 2017.
Isidorov VA, Zenkevich IG, Ioffe BV. 1985. Volatile organic compounds in the atmosphere of forests. Atmos Environ 19(1):1–8. 10.1016/0004-6981(85)90131-3.
Iyadomi M, Ichiba M, Zhang J, 2000. Evaluation of skin irritants caused by organic solvents by means of the mouse ear thickness measurement method. J Occup Health 42(1):44–46. 10.1539/joh.42.44.
Jarke FH, Dravnieks A, Gordon SM. 1981. Organic contaminants in indoor air and their relation to outdoor contaminants. ASHRAE Trans 87(1):153–166.
Jongeneelen F, Berge WT, Boogaard P. 2013. Interpretation of human biological monitoring data using a newly developed generic physiological-based toxicokinetic model: examples of simulations with carbofuran and methyl ethyl ketone. In: Fowler BA, ed. Computational toxicology: Methods and applications for risk assessment. Boston, MA: Elsevier, Inc., 137–150. 10.1016/B978-0-12-396461-8.00010-5.
Jonsson A, Persson KA, Grigoriadis V. 1985. Measurements of some low molecular-weight oxygenated, aromatic and chlorinated hydrocarbons in ambient air and in vehicle emissions. Environ Int 11(2-4):383–392. 10.1016/0160-4120(85)90033-9.
Jung R, Engelhart G, Herbolt B, 1992. Collaborative study of mutagenicity with Salmonella typhimurium TA102. Mutat Res 278(4):265–270. 10.1016/s0165-1218(10)80006-0.1373863
Jungclaus GA, Lopez-Avila V, Hites RA. 1978. Organic compounds in an industrial waste water: A case study of their environmental impact. Environ Sci Technol 12(1):88–96. 10.1021/es60137a015.
Kavaler AR. 1987. Chemical profile methyl ethyl ketone. Chem Mark Rep 232(8):50.
Kawai T, Zhang ZW, Takeuchi A, 2003. Methyl isobutyl ketone and methyl ethyl ketone in urine as biological markers of occupational exposure to these solvents at low levels. Int Arch Occup Environ Health 76(1):17–23. 10.1007/s00420-002-0374-9.12592578
Keen AR, Walker NJ, Peberdy MF. 1974. The formation of 2-butanone and 2-butanol in cheddar cheese. J Dairy Res 41(2):249–257. 10.1017/S002202990001966X.
Kelly TJ, Callahan PJ, Pleil J, 2002. Method development and field measurements for polar volatile organic compounds in ambient air. Environ Sci Technol 27(6):1146–1153. 10.1021/es00043a014.
Kennah HE, Hignet S, Laux PE, 1989. An objective procedure for quantitating eye irritation based upon changes of corneal thickness. Fundam Appl Toxicol 12(2):258–268. 10.1016/0272-0590(89)90043-2.2714526
Kim KW, Won YL, Park DJ, 2014. Comparative study on the EC50 value in single and mixtures of dimethylformamide, methyl ethyl ketone, and toluene. Toxicol Res 30(3):199–204. 10.5487/tr.2014.30.3.199.25343014
Kimura ET, Ebert DM, Dodge PW. 1971. Acute toxicity and limits of solvent residue for sixteen organic solvents. Toxicol Appl Pharmacol 19(4):699–704. 10.1016/0041-008x(71)90301-2.5132037
King PJ, Morris JG, Pollard JD. 1985. Glue sniffing neuropathy. Aust N Z J Med 15(3):293–299. 10.1111/j.1445-5994.1985.tb04039.x.2998315
Kinlin TE, Muralidhara R, Pittet AO, 1972. Volatile components of roasted filberts. J Agric Food Chem 20(5):1021–1028. 10.1021/jf60183a013.
Klimisch H. 1988. The inhalation hazard test; principle and method. Arch Toxicol 61:411–416.3395251
Kolb DK. 1988. Teratogenic chemicals in undergraduate general chemistry laboratories. Stud Environ Sci 31:247–255. 10.1016/S0166-1116(09)70070-6.
Kopelman PG, Kalfayan PY. 1983. Severe metabolic acidosis after ingestion of butanone. Br Med J 286(6358):21–22. 10.1136/bmj.286.6358.21-a.
Kopfler FC, Melton RG, Mullaney JL, 1977. Human exposure to water pollutants. In: Lloyd AC, ed. Advances in Environmental Science and Technology. Vol. 8. John Wiley & Sons Inc, 419–433.
Kreja L, Seidel HJ. 2002. Evaluation of the genotoxic potential of some microbial volatile organic compounds (MVOC) with the comet assay, the micronucleus assay and the HPRT gene mutation assay. Mutat Res 513(1-2):143–150. 10.1016/s1383-5718(01)00306-0.11719099
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Krotoszynski NK, Bruneau GM, O’Neill HJ. 1979. Measurement of chemical inhalation exposure in urban population in the presence of endogenous effluents. J Anal Toxicol 3(6):225–234. 10.1093/jat/3.6.225.
Kupferschmid LL, Perkins JL. 1986. Organic solvent recycling plant exposure levels. Appl Ind Hyg 1(3):122–131. 10.1080/08828032.1986.10390494.
Labelle CW, Brieger H. 1955. The vapor toxicity of a composite solvent and its principal components. AMA Arch Ind Health 12(6):623–627.13268080
LaRegina J, Bozzelli JW, Harkov R, 1986. Volatile organic compounds at hazardous waste sites and a sanitary landfill in New Jersey. An up-to-date review of the present situation. Environ Prog 5(1):18–27. 10.1002/ep.670050109.
Lemasters GK, Lockey JE, Olsen DM, 1999. Comparison of internal dose measures of solvents in breath, blood and urine and genotoxic changes in aircraft maintenance personnel. Drug Chem Toxicol 22(1):181–200. 10.3109/01480549909029731.10189578
Li GL, Yin SN, Watanabe T, 1986. Benzene-specific increase in leukocyte alkaline phosphatase activity in rats exposed to vapors of various organic solvents. J Toxicol Environ Health 19(4):581–589. 10.1080/15287398609530954.3783773
Liebich HM, Bertsch W, Zlatkis A, 1975. Volatile organic components in the Skylab 4 spacecraft atmosphere. Aviat Space Environ Med 46(8):1002–1007.240349
Liira J, Riihimaki V, Pfaffli P. 1988a. Kinetics of methyl ethyl ketone in man: absorption, distribution and elimination in inhalation exposure. Int Arch Occup Environ Health 60(3):195–200. 10.1007/BF00378697.3384485
Liira J, Riihimaki V, Engstrom K, 1988b. Co-exposure of man to m-xylene and methyl ethyl ketone: Kinetics and metabolism. Scand J Work Environ Health 14:322–327. 10.5271/sjweh.1912.3201193
Liira J, Riihimaki V, Engstrom K. 1990a. Effects of ethanol on the kinetics of methyl ethyl ketone in man. Br J Ind Med 47(5):325–330. 10.1136/oem.47.5.325.2357447
Liira J, Johanson G, Riihimaki V. 1990b. Dose-dependent kinetics of inhaled methylethylketone in man. Toxicol Lett 50(2-3):195–201. 10.1016/0378-4274(90)90011-a.2309238
Liira J, Elovaara E, Raunio H, 1991. Metabolic interaction and disposition of methyl ethyl ketone and m-xylene in rats at single and repeated inhalation exposures. Xenobiotica 21(1):53–63. 10.3109/00498259109039450.2003367
Liu M, Grant SG, Macina OT, 1997. Structural and mechanistic bases for the induction of mitotic chromosomal loss and duplication (’malsegregation’) in the yeast Saccharomyces cerevisiae: relevance to human carcinogenesis and developmental toxicology. Mutat Res 374(2):209–231. 10.1016/s0027-5107(96)00236-9.9100845
Lovegren NV, Fisher GS, Legendre MG, 1979. Volatile constituents of dried legumes. J Agric Food Chem 27(4):851–853. 10.1021/jf60224a055.
Lowry L. 1987. The biological exposure index: Its use in assessing chemical exposures in the workplace. Toxicology 47:55–69. 10.1016/0300-483x(87)90160-0.3686532
Lyman WJ, Reehl WF, Rosenblatt DH. 1982. Methyl ethyl ketone. In: Handbook of chemical property estimation methods. New York, NY: McGraw Hill Book Co., Chapters 4, 7, 15.
Mahle DA, Gearhart JM, Grigsby CC, 2007. Age-dependent partition coefficients for a mixture of volatile organic solvents in Sprague-Dawley rats and humans. J Toxicol Environ Health 70(20):1745–1751. 10.1080/15287390701458991.
Mayer VW, Goin CJ. 1987. Effects of chemical combinations on the induction of aneuploidy in Saccharomyces cerevisiae. Mutat Res 187(1):21–30. 10.1016/0165-1218(87)90072-3.3540657
Mayer VW, Goin CJ. 1994. Induction of chromosome loss in yeast by combined treatment with neurotoxic hexacarbons and monoketones. Mutat Res 341(2):83–91. 10.1016/0165-1218(94)90090-6.7527491
McDermott C, Allshire A, van Pelt FN, 2007. Sub-chronic toxicity of low concentrations of industrial volatile organic pollutants in vitro. Toxicol Appl Pharmacol 219(1):85–94. 10.1016/j.taap.2006.12.004.17239415
Mill T. 1982. Hydrolysis and oxidation processes in the environment. Environ Toxicol Chem 1(2):135–141. 10.1002/etc.5620010204.
Mill T, Hendry DG, Richardson H. 1980. Free-radical oxidants in natural waters. Science 207(4433):886–887. 10.1126/science.207.4433.886.17729869
Misumi J, Nagano M. 1985. Experimental study on the enhancement of the neurotoxicity of methyl n-butyl ketone by non-neurotoxic aliphatic monoketones. Br J Ind Med 42(3):155–161. 10.1136/oem.42.3.155.3970879
Mitran E, Callender T, Orha B, 1997. Neurotoxicity associated with occupational exposure to acetone, methyl ethyl ketone, and cyclohexanone. Environ Res 73(1-2):181–188. 10.1006/enrs.1997.3703.9311545
Miyasaka M, Kumai M, Koizumi A, 1982. Biological monitoring of occupational exposure to methyl ethyl ketone by means of urinalysis for methyl ethyl ketone itself. Int Arch Occup Environ Health 50(2):131–137. 10.1007/BF00378075.7118257
Mortensen B, Zahlsen K, Nilsen OG. 1998. Metabolic interaction of n-hexane and methyl ethyl ketone in vitro in a head space rat liver S9 vial equilibration system. Pharmacol Toxicol 82(2):67–73. 10.1111/j.1600-0773.1998.tb01400.x.9498234
Munies R, Wurster DE. 1965. Investigation of some factors influencing percutaneous absorption. III. Absorption of methyl ethyl ketone. J Pharm Sci 54(9):1281–1284. 10.1002/jps.2600540912.5881221
Muttray A, Jung D, Klimek L, 2002. Effects of an external exposure to 200 ppm methyl ethyl ketone on nasal mucosa in healthy volunteers. Int Arch Occup Environ Health 75(3):197–200. 10.1007/s00420-001-0291-3.11954988
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences. National Research Council. 15–35. https://www.ncbi.nlm.nih.gov/books/NBK218924/. May 7, 2020.
Neier W, Strehlke G. 1985. Methyl ethyl ketone. In: Ullman’s encyclopedia of industrial chemistry. Deerfield Beach, FL: Wiley-VCH Verlag GmbH & Co. KGaA, 475–481.
Nelson KW, Ege JF, Ross M, 1943. Sensory Response to certain Industrial Solvent Vapors. J Ind Hyg Toxicol 25(7):282–285.
NIOSH. 1982. Health hazard evaluation report: Red Wing Shoe Company, Red Wing, Minnesota. Cincinnati, OH: National Institute for Occupational Safety and Health. HETA814551229. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB84172592.xhtml. May 7, 2020.
NIOSH. 1984. Method 2500. NIOSH manual of analytical methods. Cincinnati, OH: National Institute for Occupational Safety and Health. 2500-l to 2500-2503.
NIOSH. 1989. National occupational exposure survey (NOES). Cincinnati, OH: National Institute for Occupational Safety and Health.
NIOSH. 1994. 2-Butanone. Immediately dangerous to life or health concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/78933.html. November 16, 2017.
NIOSH. 1996. Method 2500: Methyl ethyl ketone. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/2500.pdf. September 23, 2020.
NIOSH. 2019. Methyl ethyl ketone. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0069.html. May 1, 2020.
NLM. 2020. Pubchem data: Methyl ethyl ketone. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/6569. August 12, 2020.
NTP. 1989. Inhalation developmental toxicology studies: Teratology study of methyl ethyl ketone in mice. National Toxicology Program. PNL6833. DE89009563. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/DE89009563.xhtml. May 7, 2020.
NTP. 2016. Report on carcinogens, fourteenth edition. CASRN Index in MS Excel. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. March 1, 2017.
NWQMC. 2020. 2-Butanone sample results. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/#characteristicName=Methyl%20ethyl%20ketone&mimeType=csv. May 6, 2020.
O’Donoghue J, Krasavage W, DiVincenzo G, 1984. Further studies on ketone neurotoxicity and interactions. Toxicol Appl Pharmacol 72:201–209. 10.1016/0041-008x(84)90304-1.6546457
O’Donoghue JL, Haworth SR, Curren RD, 1988. Mutagenicity studies on ketone solvents: methyl ethyl ketone, methyl isobutyl ketone, and isophorone. Mutat Res 206(2):149–161. 10.1016/0165-1218(88)90154-1.3050497
Ogawa I, Fritz JS. 1985. Determination of low concentrations of low-molecular-weight aldehydes and ketones in aqueous samples. J Chromatogr 329:81–89. 10.1016/S0021-9673(01)81897-5.
Orti-Pareja M, Jimenez-Jimenez FJ, Miquel J, 1996. Reversible myoclonus, tremor, and ataxia in a patient exposed to methyl ethyl ketone. Neurology 46(1):272. 10.1212/wnl.46.1.272.8559401
Osborne JS, Adamek S, Hobbs ME. 1956. Some components of gas phase of cigarette smoke. Anal Chem 28(2):211–215. 10.1021/ac60110a020.
OSHA. 2019a. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. October 25, 2019.
OSHA. 2019b. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. October 25, 2019.
OSHA. 2019c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. October 25, 2019.
Papa AJ, Sherman PD. 1981. Ketones. In: Kirk-Othmer Encyclopedia of chemical technology. Vol. 13. 3^rd^ ed. New York, NY: John Wiley and Sons, Inc, 894–941.
Patty F, Schrenk H, Yant W. 1935. Acute response of guinea pigs to vapours of some new commercial organic compounds. US Treasury Publ Health Rep 50:1217.
Pellizzari ED. 1982. Analysis for organic vapor emissions near industrial and chemical waste disposal sites. Environ Sci Technol 16(11):781–785. 10.1021/es00105a010.22299786
Pellizzari ED, Castillo NP, Willis S, 1979. Identification of organic components in aqueous effluents from energy-related processes. In: Van Hall CE, ed. Measurement of organic pollutants in water and wastewater. West Conshohocken, PA: ASTM International, 256–274. 10.1520/STP686-EB.
Pellizzari ED, Hartwell TD, Harris BS, 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28(3):322–328. 10.1007/BF01608515.7082873
Perbellini L, Brugnone F, Mozzo P, 1984. Methyl ethyl ketone exposure in industrial workers. Uptake and kinetics. Int Arch Occup Environ Health 54(1):73–81. 10.1007/BF00378730.6724704
Phillips WE, Perry JJ. 1974. Metabolism of n-butane and 2-butanone by Mycobacterium vaccae. J Bacteriol 120(2):987–989.4455691
Price KS, Waggy GT, Conway RA. 1974. Brine shrimp bioassay and seawater BOD of petrochemicals. J Water Pollut Control Fed 46(1):63–77.4812499
Price EA, D’Alessandro A, Kearney T, 1994. Osmolar gap with minimal acidosis in combined methanol and methyl ethyl ketone ingestion. J Toxicol Clin Toxicol 32(1):79–84. 10.3109/15563659409000434.8308953
Radican L, Blair A, Stewart P, 2008. Mortality of aircraft maintenance workers exposed to trichloroethylene and other hydrocarbons and chemicals: extended follow-up. J Occup Environ Med 50(11):1306–1319. 10.1097/JOM.0b013e3181845f7f.19001957
Ralston WH, Hilderbrand RL, Uddin DE, 1985. Potentiation of 2,5-hexanedione neurotoxicity by methyl ethyl ketone. Toxicol Appl Pharmacol 81(2):319–327. 10.1016/0041-008x(85)90169-3.4060157
Rathbun RE, Tai DY. 1987. Vapor pressures and gas-film coefficients for ketones. Chemosphere 16(1):69–78. 10.1016/0045-6535(87)90110-x.
Raunio H, Liira J, Elovaara E, 1990. Cytochrome P450 isozyme induction by methyl ethyl ketone and m-xylene in rat liver. Toxicol Appl Pharmacol 103(1):175–179. 10.1016/0041-008x(90)90273-w.2315928
Raymond P, Plaa GL. 1995a. Ketone potentiation of haloalkane-induced hepato- and nephrotoxicity. I. Dose-response relationships. J Toxicol Environ Health 45(4):465–480. 10.1080/15287399509532009.7643433
Raymond P, Plaa GL. 1995b. Ketone potentiation of haloalkane-induced hepato- and nephrotoxicity. II. Implication of monooxygenases. J Toxicol Environ Health 46(3):317–328. 10.1080/15287399509532038.7473860
Raymond P, Plaa GL. 1996. Ketone potentiation of haloalkane-induced hepatotoxicity: CCl4 and ketone treatment on hepatic membrane integrity. J Toxicol Environ Health 49(3):285–300. 10.1080/00984108.1996.11667602.8876655
RePORTER. 2020. 2-Butanone. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. April 30, 2020.
Richardson SD, Thruston AD, Caughran TV, 1999. Identification of new ozone disinfection byproducts in drinking water. Environ Sci Technol 33(19):3368–3377. 10.1021/es981218c.
Riddick JA, Bunger WB, Sakano TK. 1986. Organic solvents. In: Physical properties and methods of purification techniques of chemistry. 4th ed. New York, NY: Wiley-Interscience, 338–339.
Riihimaki V. 1986. Metabolism and excretion of organic solvents. In: Ulfvarson U, ed. Progress in clinical and biological research. Vol. 220. New York, NY: Alan R Liss, Inc., 61–72.
Robertson P, White EL, Bus JS. 1989. Effects of methyl ethyl ketone pretreatment on hepatic mixed-function oxidase activity and on in vivo metabolism of n-hexane. Xenobiotica 19(7):721–729. 10.3109/00498258909042310.2773508
Roy WR, Griffin RA. 1985. Mobility of organic solvents in water-saturated soil materials. Environ Geol Water Sci 7(4):241–247. 10.1007/BF02509925.
Sabel GV, Clark TP. 1984. Volatile organic compounds as indicators of municipal solid waste leachate contamination. Waste Manag Res 2(2):119–130. 10.1016/0734-242X(84)90135-6.
Saida K, Mendell JR, Weiss HS. 1976. Peripheral nerve changes induced by methyl n-butyl ketone and potentiation by methyl ethyl ketone. J Neuropathol Exp Neurol 35(3):207–225. 10.1097/00005072-197605000-00001.178832
Saillenfait AM, Gallissot F, Sabate JP, 2006. Developmental toxicity of combined ethylbenzene and methylethylketone administered by inhalation to rats. Food Chem Toxicol 44(8):1287–1298. 10.1016/j.fct.2006.02.006.16624470
Sakata M, Kikuchi J, Haga M, 1989. Disposition of acetone, methyl ethyl ketone and cyclohexanone in acute poisoning. J Toxicol Clin Toxicol 27(1-2):67–77. 10.3109/15563658909038570.2769822
SANSS. 1989. Structure and Nomenclature Search System. September 1, 1989.
Sawhney BL, Kozloski RP. 1984. Organic pollutants in leachates from landfill sites. J Environ Qual 13(3):349–352. 10.2134/jeq1984.00472425001300030005x.
Sax NI, Lewis RJ. 1987. Metyhl ethyl ketone. In: Hawley’s condensed chemical dictionary. 11th ed. New York, NY: Van Nostrand Reinhold Co, 769.
Scheiman MA, Saunders RA, Saalfeld FE. 1974. Organic contaminants in the District of Columbia water supply. Biomed Mass Spectrom 1(4):209–211. 10.1002/bms.1200010402.4441614
Schenk L, Rauma M, Fransson MN, 2018. Percutaneous absorption of thirty-eight organic solvents in vitro using pig skin. PLoS ONE 13(10):e0205458. 10.1371/journal.pone.0205458.30379962
Schmidt R, Schnoy N, Altenkirch H, 1984. Ultrastructural alteration of intrapulmonary nerves after exposure to organic solvents. A contribution to ’sniffers disease’. Respiration 46(4):362–369. 10.1159/000194713.6522843
Schwetz BA, Leong BK, Gehring PJ. 1974. Embryo- and fetotoxicity of inhaled carbon tetrachloride, 1,1-dichloroethane and methyl ethyl ketone in rats. Toxicol Appl Pharmacol 28(3):452–464. 10.1016/0041-008x(74)90230-0.4851838
Schwetz BA, Mast TJ, Weigel RJ, 1991. Developmental toxicity of inhaled methyl ethyl ketone in Swiss mice. Fundam Appl Toxicol 16(4):742–748. 10.1016/0272-0590(91)90160-6.1884913
Seeber A, van Thriel C, Haumann K, 2002. Psychological reactions related to chemosensory irritation. Int Arch Occup Environ Health 75(5):314–325. 10.1007/s00420-002-0316-6.11981670
Seizinger DE, Dimitriades B. 1972. Oxygenates in exhaust from simple hydrocarbon fuels. J Air Pollut Control Assoc 22(1):47–51. 10.1080/00022470.1972.10469608.4109317
Shibata E, Huang J, Ono Y, 1990a. Changes in urinary n-hexane metabolites by co-exposure to various concentrations of methyl ethyl ketone and fixed n-hexane levels. Arch Toxicol 64(2):165–168.2350238
Shibata E, Huang J, Hisanaga N, 1990b. Effects of MEK on kinetics of n-hexane metabolites in serum. Arch Toxicol 64(3):247–250. 10.1007/BF02010732.2372236
Shibata E, Johanson G, Lof A, 2002. Changes in n-hexane toxicokinetics in short-term single exposure due to co-exposure to methyl ethyl ketone in volunteers. Int Arch Occup Environ Health 75(6):399–405. 10.1007/s00420-002-0325-5.12070636
Sia GL, Ong CN, Chia SE, 1991. Environmental and biological monitoring of methyl ethyl ketone (MEK). Environ Monit Assess 19(1-3):401–411. 10.1007/BF00401328.24233956
Smet E, Van Langenhove H, De Bo I. 1999. The emission of volatile compounds during the aerobic and the combined anaerobic/aerobic composting of biowaste. Atmos Environ 33(8):1295–1303. 10.1016/s1352-2310(98)00260-x.
Smoyer JC, Shaffer DE, Dewitt IL. 1971. A program to sample and analyze air pollution in the vicinity of a chemical reclamation plant. In: Institute of Environmental Sciences, 1971: Annual technical meeting proceedings. Mt. Prospect, IL: Institute of Environmental Sciences, 339–345.
Smyth HF, Carpenter CP, Weil CS, 1962. Range-finding toxicity data: List VI. Am Ind Hyg Assoc J 23:95–107. 10.1080/00028896209343211.13914538
Snider JR, Dawson GA. 1985. Tropospheric light alcohols, carbonyls, and acetonitrile: Concentrations in the southwestern United States and Henry’s Law data. J Geophys Res 90(D2):3797. 10.1029/JD090iD02p03797.
Sosulski F, Mahmoud RM. 1979. Effects of protein supplements on carbonyl compounds and flavor in bread. Cereal Chem 56(6):533–536.
Speece RE. 1983. Anaerobic biotechnology for industrial wastewater treatment. Environ Sci Technol 17(9):416A-427A. 10.1021/es00115a725.
Spirtas R, Stewart PA, Lee JS, 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility. I. Epidemiological results. Br J Ind Med 48(8):515–530. 10.1136/oem.48.8.515.1878308
Stillmeadow Inc. 1978. Rat acute oral toxicity. Shell Oil Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206206. 878210023. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0206206.xhtml. May 7, 2020.
Stoltenburg-Didinger G. 1991. The effect of pre- and postnatal exposure to organic solvents on the development of the cerebellar cortex in the rat. Prog Histochem Cytochem 23(1-4):227–234. 10.1016/s0079-6336(11)80189-0.1947145
Stoltenburg-Didinger G, Altenkirch H, Wagner M. 1990. Neurotoxicity of organic solvent mixtures: embryotoxicity and fetotoxicity. Neurotoxicol Teratol 12(6):585–589. 10.1016/0892-0362(90)90066-l.2255301
Swann RL, Laskowski DA, McCall PJ, 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio and water solubility. Residue Rev 85:17–28. 10.1007/978-1-4612-5462-1_3.
Takeoka GR, Flath RA, Guentert M, 1988. Nectarine volatiles: Vacuum steam distillation versus headspace sampling. J Agric Food Chem 36(3):553–560. 10.1021/jf00081a037.
Takeuchi Y, Ono Y, Hisanaga N, 1983. An experimental study of the combined effects of n-hexane and methyl ethyl ketone. Br J Ind Med 40(2):199–203. 10.1136/oem.40.2.199.6830718
Tanii H, Tsuji H, Hashimoto K. 1986. Structure-toxicity relationship of monoketones. Toxicol Lett 30(1):13–17. 10.1016/0378-4274(86)90173-6.3952768
Tewari YB, Miller MM, Wasik SP, 1982. Aqueous solubility and octanol/water partition coefficient of organic compounds at 25.0.degree.C. J Chem Eng Data 27(4):451–454. 10.1021/je00030a025.
Thorpe E. 1982. Toxicity studies with chemical solvents Short-term in vitro tests for genotoxic activity with methyl ethyl ketone. Shell Oil Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0206206. 978210097. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0206206.xhtml. June 30, 2020.
Thrall KD, Soelberg JJ, Weitz KK, 2002. Development of a physiologically based pharmacokinetic model for methyl ethyl ketone in F344 rats. J Toxicol Environ Health 65(13):881–896. 10.1080/00984100290071207.
Tichenor BA, Mason MA. 1988. Organic emissions from consumer products and building materials to the indoor environment. JAPCA 38(3):264–268. 10.1080/08940630.1988.10466376.3379453
Toftgard R, Nilsen O, Gustafsson JA. 1981. Changes in rat liver microsomal cytochrome P-450 and enzymatic activities after the inhalation of n-hexane, xylene, methyl ethyl ketone and methyl chloroform for four weeks. Scand J Work Environ Health 7(1):31–37. 10.5271/sjweh.2569.7313607
Tolos W, Setzer J, MacKenzie B, 1987. Biological monitoring of experimental human inhalation exposures of methyl ethyl ketone and toluene. In: Ho M, Dillon H, eds. Biological monitoring of exposure to chemicals, organic compounds. New York, NY: John Wiley and Sons, 133–142.
Tomicic C, Vernez D. 2014. Sex differences in urinary levels of several biological indicators of exposure: a simulation study using a compartmental-based toxicokinetic model. J Occup Environ Hyg 11(6):377–387. 10.1080/15459624.2013.875180.24372376
Tomicic C, Berode M, Oppliger A, 2011. Sex differences in urinary levels of several biological indicators of exposure: a human volunteer study. Toxicol Lett 202(3):218–225. 10.1016/j.toxlet.2011.01.032.21352904
Traiger GJ, Bruckner JV, Jiang WD, 1989. Effect of 2-butanol and 2-butanone on rat hepatic ultrastructure and drug metabolizing enzyme activity. J Toxicol Environ Health 28(2):235–248. 10.1080/15287398909531343.2507790
Tsao MU, Pfeiffer EL. 1957. Isolation and identification of a new ketone body in normal human urine. Proc Soc Exp Biol Med 94(4):628–629. 10.3181/00379727-94-23031.13431900
Tsuchiya Y. 1987. Volatile organic compounds in indoor air. Am Chem Soc Div Environ Chem Preprint 27:183–185.
Tsukamoto S, Chiba S, Muto T, 1985. Study on the metabolism of volatile hydrocarbons in mice--propane, n-butane, and iso-butane. J Toxicol Sci 10(4):323–332. 10.2131/jts.10.323.3913777
Urano K, Kato Z. 1986. Evaluation of biodegradation ranks of priority organic compounds. J Hazard Mater 13(2):147–159. 10.1016/0304-3894(86)80015-2.
Ursin C, Hansen CM, Van Dyk JW, 1995. Permeability of commercial solvents through living human skin. Am Ind Hyg Assoc J 56(7):651–660. 10.1080/15428119591016665.7618604
USDA. 2020. Dr. Duke’s phytochemical and ethnobotanical databases: 2-butanone. U.S. Department of Agriculture. https://phytochem.nal.usda.gov/phytochem/chemicals/show/1109?qlookup=2-butanone&offset=0&max=20&et=. May 6, 2020.
USITC. 1987. Synthetic organic chemicals, United States Production and Sales, 1986. Washington, DC: U.S. International Trade Commission. 210, 226, 238–239. USITC Publication 2009.
USITC. 1988. Synthetic organic chemicals, United States Production and Sales, 1987. Washington, DC: U.S. International Trade Commission. 15-15, 15–22, 1536, 1515-1537. USITC Publication 2118.
USITC. 1989. Synthetic organic chemicals, United States Production and Sales, 1988. Washington, DC: U.S. International Trade Commission. 15-15, 15–23, 15-36 to 15-38. USITC Publication 2219.
Vaishnav DC, Boethling RS, Babeu L. 1987. Quantitative structure - Biodegradability relationships for alcohols, ketones and alicyclic compounds. Chemosphere 16(4):695–703. 10.1016/0045-6535(87)90005-1.
Vallat JM, Leboutet MJ, Loubet A, 1981. N-Hexane- and methylethylketone-induced polyneuropathy. Abnormal accumulation of glycogen in unmyelinated axons. Report of a case. Acta Neuropathol (Berl) 55(4):275–279. 10.1007/BF00690990.6277140
Van Doorn JE, De Cock J, Kezic S, 1989. Determination of methyl ethyl ketone in human urine after derivatization with o-nitrophenylhydrazine, using solid-phase extraction and reversed-phase high-performance liquid chromatography and ultraviolet detection. J Chromatogr 489(2):419–424. 10.1016/s0378-4347(00)82924-2.2753966
van Thriel C, Haumann K, Kiesswetter E, 2002. Time courses of sensory irritations due to 2-butanone and ethyl benzene exposure: influences of self-reported multiple chemical sensitivity (sMCS). Int J Hyg Environ Health 204(5-6):367–369. 10.1078/1438-4639-00112.11885363
van Thriel C, Wiesmuller GA, Blaszkewicz M, 2003. Intranasal effects in chemically sensitive volunteers: an experimental exposure study. Environ Toxicol Pharmacol 14(3):129–137. 10.1016/S1382-6689(03)00047-4.21782672
Varigos GA, Nurse DS. 1986. Contact urticaria from methyl ethyl ketone. Contact Dermatitis 15(4):259–260. 10.1111/j.1600-0536.1986.tb01362.x.
Veronesi B, Lington AW, Spencer PS. 1984. A tissue culture model of methyl ethyl ketone’s potentiation of n-hexane neurotoxicity. Neurotoxicology 5(2):43–52.
Wahlberg JE. 1984. Edema-inducing effects of solvents following topical administration. Derm Beruf Umwelt 32(3):91–94.6468283
Wallace LA, Pellizzari E, Hartwell T, 1984. Personal exposure to volatile organic compounds. I. Direct measurements in breathing-zone air, drinking water, food, and exhaled breath. Environ Res 35(1):293–319. 10.1016/0013-9351(84)90137-3.6489295
Wallington TJ, Kurylo MJ. 1987. Flash photolysis resonance fluorescence investigation of the gas-phase reactions of hydroxyl radicals with a series of aliphatic ketones over the temperature range 240-440 K. J Phys Chem 91(19):5050–5054. 10.1021/j100303a033.
Wallington TJ, Dagaut P, Kurylo MJ. 1988. Correlation between gas-phase and solution-phase reactivities of hydroxyl radicals towards saturated organic compounds. J Phys Chem 92(17):5024-5028. 10.1021/j100328a039.
Wang TC, Bricker JL. 1979. 2-Butanone and tetrahydrofuran contamination in the water supply. Bull Environ Contam Toxicol 23(4-5):620–623. 10.1007/BF01770014.497472
Weast RC, Astle MJ, Beyer WH. 1988. Methyl ethyl ketone. In: O’Neil MJ, ed. CRC handbook of chemistry and physics. 69th ed. Boca Raton, FL: CRC Press, Inc., C-170.
Wen CP, Tsai SP, Weiss NS, 1985. Long-term mortality study of oil refinery workers. IV. Exposure to the lubricating-dewaxing process. J Natl Cancer Inst 74(1):11–18.3855471
Whelan JK, Tarafa ME, Hunt JM. 1982. Volatile C1-C8 organic compounds in macroalgae. Nature 299:50–52.
Whitehead LW, Ball GL, Fine LJ, 1984. Solvent vapor exposures in booth spray painting and spray glueing, and associated operations. Am Ind Hyg Assoc J 45(11):767–772. 10.1080/15298668491400584.6507277
Whittaker SG, Zimmermann FK, Dicus B, 1990. Detection of induced mitotic chromosome loss in Saccharomyces cerevisiae--an interlaboratory assessment of 12 chemicals. Mutat Res 241(3):225–242. 10.1016/0165-1218(90)90020-3.2195333
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Wiesmuller GA, Van Thriel C, Steup A, 2002. Nasal function in self-reported chemically intolerant individuals. Arch Environ Health 57(3):247–254. 10.1080/00039890209602944.12507179
Wilkins CK, Larsen K. 1995. Identification of volatile (micro) biological compounds from household waste and building materials by thermal desorption-capillary gas chromatography-mass spectroscopy. J High Resolut Chromatogr 18(6):373–377. 10.1002/jhrc.1240180610.
Wilkins K, Larsen K. 1996. Volatile organic compounds from garden waste. Chemosphere 32(10):2049–2055. 10.1016/0045-6535(96)00113-0.
Wurster DE, Munies R. 1965. Factors influencing percutaneous absorption. II. Absorption of methyl ethyl ketone. J Pharm Sci 54(4):554–556. 10.1002/jps.2600540412.5842337
Yasui T, Zhao W, Misumi J, 1995. Influence of different doses of methyl ethyl ketone on 2,5-hexanedione concentrations in the sciatic nerve, serum, and urine of rats. Sangyo Eiseigaku Zasshi 37(1):19–24. 10.1539/sangyoeisei.37.19.7780859
Yoshikawa M, Kawamoto T, Murata K, 1995. Biological monitoring of occupational exposure to methyl ethyl ketone in Japanese workers. Arch Environ Contam Toxicol 29(1):135–139. 10.1007/BF00213098.7794011
Young RH, Ryckman DW, Buzzell JC. 1968. An improved tool for measuring biodegrability. J Water Pollut Control Fed 40(8):R354–R368.
Zeiger E, Anderson B, Haworth S, 1992. Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 19 (Suppl 21):2–141. 10.1002/em.2850190603.1541260
Zhao W, Misumi J, Yasui T, 1998a. Relationship between 2,5-hexanedione concentrations in nerve, serum, and urine alone or under co-treatment with different doses of methyl ethyl ketone, acetone, and toluene. Neurochem Res 23(6):837–843. 10.1023/a:1022402810695.9572672
Zhao W, Misumi J, Yasui T, 1998b. Effects of methyl ethyl ketone, acetone, or toluene coadministration on 2,5-hexanedione concentration in the sciatic nerve, serum, and urine of rats. Int Arch Occup Environ Health 71(4):236–244. 10.1007/s004200050275.9638479
Zimmermann FK, Scheel I, Resnick MA. 1989. Induction of chromosome loss by mixtures of organic solvents including neurotoxins. Mutat Res 224(2):287–303. 10.1016/0165-1218(89)90168-7.2677711