# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- G. Daniel Todd, Ph.D.
- ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA
- Julie Melia, Ph.D., D.A.B.T.
  Jenny S. Crisman, B.S.
  Lisa D. Ingerman, Ph.D., D.A.B.T
  David W. Wohlers, Ph.D.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

ATSDR, Office of Community Health and Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice.

## PEER REVIEWERS

1. G.A. Shakeel Ansari, Ph.D.; Professor, Department of Pathology; University of Texas Medical Branch; Galveston, Texas
2. F. Peter Guengerich, Ph.D.; Tadashi Inagami Professor of Biochemistry; Department of Biochemistry; Vanderbilt University School of Medicine; Nashville, Tennessee
3. Dale Hattis, Ph.D.; Research Professor, George Perkins Marsh Institute; Clark University; Worcester, Massachusetts

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.