# VERSION HISTORY

Date | Description
October 2020 | Final toxicological profile released
May 2019 | Draft for public comment toxicological profile released
December 2010 | Addendum to the toxicological profile released
July 1992 | Final toxicological profile released