# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding 2-butanone in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for 2-butanone.

Table 7-1 Regulations and Guidelines Applicable to 2-Butanone

Agency | Description | Information | Reference
Air
EPA | RfC | 5 mg/m^3^ (1.7 ppm) | IRIS 2003
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
| 1-Day health advisory (10-kg child) | 75 mg/L
| 10-Day health advisory (10-kg child) | 7.5 mg/L
| DWEL | 20 mg/L
| Lifetime health advisory | 4 mg/L
| 10^−4^ Cancer risk | No data
| National primary drinking water regulations | Not listed | EPA 2009
| RfD | 0.6 mg/kg/day | IRIS 2003
WHO | Drinking water quality guidelines | Not listed | WHO 2017
FDA | Substances Added to Food^a^ | Approved under food additive and GRAS regulations | FDA 2020
Cancer
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Carcinogenicity classification | Data are inadequate for an assessment of human carcinogenic potential | IRIS 2003
IARC | Carcinogenicity classification | No data | IARC 2020
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | 200 ppm | OSHA 2019a, 2019b, 2019c
NIOSH | REL (up to 10-hour TWA) | 200 ppm | NIOSH 2019
| STEL (15-minute TWA) | 300 ppm
| IDLH | 3,000 ppm | NIOSH 1994
Emergency Criteria
EPA | AEGLs-air | | EPA 2018b
| AEGL 1^b^
| 10-minute, 30-minute, 60-minute, 4-hour, and 8-hour | 200 ppm
| AEGL 2^b^
| 10-minute | 4,900 ppm^c^
| 30-minute | 3,400 ppm^c^
| 60-minute | 2,700 ppm^c^
| 4-hour | 1,700 ppm
| 8-hour | 1,700 ppm
| AEGL 3^b^
| 10-minute | 10,000 ppm^d^
| 30-minute | 10,000 ppm^d^
| 60-minute | 4,000 ppm^c^
| 4-hour | 2,500 ppm^c^
| 8-hour | 2,500 ppm^c^
DOE | PACs-air | | DOE 2018a
| PAC-1^e^ | 200 ppm
| PAC-2^e^ | 2,700 ppm
| PAC-3^e^ | 4,000 ppm

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS”.

b Definitions of AEGL terminology are available from U.S. Environmental Protection Agency (EPA 2018c).

c Concentration is ≥10% of the Lower Explosive Limit (LEL) of 18,000 ppm for methyl ethyl ketone. Safety considerations against the hazard of explosion must be taken into account.

d Concentration is ≥50% of the LEL of 18,000 ppm for methyl ethyl ketone. Extreme safety considerations against the hazard of explosion must be taken into account.

c Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term exposure limit; TWA = time-weighted average; WHO = World Health Organization