# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of 2-butanone are listed in Table 4-1.

Table 4-1 Chemical Identity of 2-Butanone

Characteristic | Information | Reference
Chemical name | 2-Butanone | CAS 1989
Synonym(s) and registered trade name(s) | Methyl ethyl ketone; MEK; ethyl methyl ketone; methyl acetone; and others; Meetco | CAS 1989; SANSS 1989; Chemline 1989; OHM/TADS 1989
Chemical formula | C_4_H_8_O | CAS 1989
Chemical structure | [image]
CAS Registry Number | 78-93-3 | CAS 1989

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of 2-butanone are presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of 2-Butanone

Property | Information | Reference
Molecular weight | 72.11 | Weast et al. 1988
Color | Colorless | Sax and Lewis 1987
Physical state | Liquid | Sax and Lewis 1987
Melting point | −86.3°C | Weast et al. 1988
Boiling point | 79.6°C | Weast et al. 1988
Density (liquid) at 20°C | 0.8054 | Weast et al. 1988
Odor | Acetone-like | Sax and Lewis 1987
Odor threshold:
Water | 8.4 ppm | Amoore and Hautala 1983
Air | 5.4 ppm | Amoore and Hautala 1983
Solubility:
Water at 25°C | 136,000 mg/L | Tewari et al. 1982
Organic solvents | Benzene, alcohol, ether, oils, most organic solvents | Sax and Lewis 1987; Neier and Strehlke 1985
Partition coefficients:
Log K_ow_ | 0.29 | Hansch et al. 1995
Log K_oc_ | 0.55 | Roy and Griffin 1985
Vapor pressure at 25°C | 90.6 mmHg | Riddick et al. 1986
Henry’s law constant at 25°C | 5.77×10^−5^ atm m^3^/mol | Rathbun and Tai 1987
Autoignition temperature | 515°C | Sax and Lewis 1987
Flashpoint:
Closed cup | −2°C | Riddick et al. 1986
Open cup | 1°C | Riddick et al. 1986
Flammability limits in air | 2-10% | Sax and Lewis 1987
Conversion factors:
ppm (v/v) to mg/m^3^ in air (20°C) | 1 ppm=2.95 mg/m^3^
mg/m^3^ to ppm (v/v) in air (20°C) | 1 mg/m^3^=0.339 ppm
Bioconcentration factor | 0.98 (calculated from K_ow_) | Lyman et al. 1982
Explosive limits | 1.4-11.4% at 200°F | NIOSH 2019