# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1-14 days), intermediate (15-364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Butanone
CAS Numbers: | 78-93-3
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL | 1 ppm
Critical Effect: | Neurological (headache, fatigue, feeling of intoxication)
Reference: | Tomicic et al. 2011
Point of Departure: | LOAEL of 99.15 ppm
Uncertainty Factor: | 100
LSE Graph Key: | 5
Species: | Humans

MRL Summary: An acute-duration inhalation MRL of 1 ppm was derived for 2-butanone based on reported neurological symptoms (headache, fatigue, feeling of intoxication) in volunteers. The MRL is based on the LOAEL (not adjusted for continuous exposure) of 99.15 ppm and a total uncertainty factor of 100 (10 for use of a LOAEL and 10 for human variability).

Selection of the Critical Effect: Clinical signs of neurotoxicity in humans (i.e., headache, fatigue, feeling of intoxication) are a sensitive effect of 2-butanone exposure (Tomicic et al. 2011). Neurobehavioral effects in primates (Geller et al. 1979) were also reported at low concentrations (increased response time in match-to-sample tasks).

Selection of the Principal Study: Tomicic et al. (2011) was selected as the principal study because neurological effects were reported in volunteers exposed to 100 ppm.

Summary of the Principal Study:

Tomicic C, Berode M, Oppliger A, et al. 2011. Sex differences in urinary levels of several biological indicators of exposure: A human volunteer study. Toxicol Lett 202:218-225.

Volunteers (10 males and 10 females using hormonal contraceptives and 5 females without hormonal contraceptives) were exposed to 100 ppm 2-butanone for 6 hours (measured concentration 99.15±5.29 ppm). Urinary 2-butanone concentrations were measured every 2 hours before, during, and after exposure (24 hours total). A symptom questionnaire was administered every 2 hours during exposure. The symptoms rated on a visual analog scale (graded from “not at all” to “almost unbearable”) included headache, fatigue, nausea, dizziness, feeling of intoxication, discomfort in the eyes, in the nose, or in the throat or airways, breathing difficulty, and solvent smell. The quantitative symptom ratings were not reported; however, a statistically significant difference between men and women was indicated for neurological effects and irritation symptoms (eyes, nose, and throat) with females giving higher ratings than males. Specific ratings that were described as higher in females compared to males included headache after 4 and 6 hours, fatigue and feeling of intoxication after 6 hours and discomfort in the eyes after 2 and 4 hours.

Selection of the Point of Departure for the MRL: The LOAEL of 100 ppm for neurological effects (headache, fatigue, feeling of intoxication) was selected as the point of departure (POD) for the acute-duration inhalation MRL.

Calculations: Not applicable.

Intermittent Exposure: Because of the reversible nature of mucous membrane irritation, adjustment for intermittent exposure was not necessary.

Human Equivalent Concentration: The POD was derived from human exposure studies (no conversion required).

Uncertainty Factor: The LOAEL is divided by a total uncertainty factor of 100:

- 10 for use of a LOAEL
- 10 for human variability
  - MRL = LOAEL ÷ UFs
    - 99.15 ppm ÷ (10×10) = 1 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Neurobehavioral testing was conducted in four baboons exposed to 100 ppm 2-butanone 24 hours/day for 7 days (Geller et al. 1979). A decrease in the mean response time for a match-to-sample task was observed. Nelson et al. (1943) exposed 10 subjects (both male and female) to 2-butanone at concentrations of 100, 200, or 350 ppm for 3-5 minutes. Symptom classifications were no reaction, slightly irritating, and very irritating. At 100 ppm, slight nose and throat irritation were reported. At 200 ppm, mild eye irritation appeared in some subjects. Exposure to 350 ppm was conclusively rejected as not tolerable for an 8-hour workday. No further details were reported. Sensory irritation effects were seen in mice exposed to 2-butanone concentrations ≥3,809 ppm. A time- and concentration-dependent decrease in respiratory rate and tidal volume was observed (Hansen et al. 1992). Severe respiratory and eye irritation occurred in rats and guinea pigs exposed to 2-butanone concentrations ≥10,000 ppm (Altenkirch et al. 1978; Patty et al. 1935).

Agency Contacts (Chemical Managers): G. Daniel Todd

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Butanone
CAS Numbers: | 78-93-3
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rational for Not Deriving an MRL: Target organs have not been sufficiently identified. In addition, clinical signs of neurotoxicity (i.e., headache, fatigue, feeling of intoxication) and nose, throat, and eye irritation occurred in humans at exposure levels that were much lower than NOAEL values in animals in intermediate-duration studies.

Agency Contacts (Chemical Managers): G. Daniel Todd

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Butanone
CAS Numbers: | 78-93-3
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rational for Not Deriving an MRL: No chronic-duration studies examining noncarcinogenic effects following inhalation exposure were identified.

Agency Contacts (Chemical Managers): G. Daniel Todd

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Butanone
CAS Numbers: | 78-93-3
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rational for Not Deriving an MRL: Target organs have not been sufficiently identified and dose-response data are lacking.

Agency Contacts (Chemical Managers): G. Daniel Todd

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Butanone
CAS Numbers: | 78-93-3
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rational for Not Deriving an MRL: Target organs have not been sufficiently identified and dose-response data are lacking.

Agency Contacts (Chemical Managers): G. Daniel Todd

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Butanone
CAS Numbers: | 78-93-3
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rational for Not Deriving an MRL: No chronic-duration studies examining noncarcinogenic effects following oral exposure were identified.

Agency Contacts (Chemical Managers): G. Daniel Todd