# CHAPTER 8 REFERENCES

Akca ET, Serpil S, Sezer U, . 2009. Health profiles of methyl bromide applicators in greenhouses in Turkey. Ann Acad Med Singapore 38(8):707–713.19736576
Alavanja MCR, Samanic C, Dosemeci M, . 2003. Use of agricultural pesticides and prostate cancer risk in the Agricultural Health Study cohort. Am J Epidemiol 57(9):800–814.
Alexeeff GV, Kilgore WW. 1983. Methyl bromide. Residue Rev 88:101–153.6348905
Alexeeff GV, Kilgore WW, Munoz P, . 1985. Determination of acute toxic effects in mice following exposure to methyl bromide. J Toxicol Environ Health 15(1):109–123. 10.1080/15287398509530639.3981660
Andersen ME, Gargas ML, Jones RA, . 1980. Determination of the kinetic constants for metabolism of inhaled toxicants in vivo using gas uptake measurements. Toxicol Appl Pharmacol 54(1):100–116. 10.1016/0041-008X(80)90011-3.7394779
Anderson TA, Rice PJ, Cink JH, . 1996. Fate of methyl bromide in fumigated soils. In: Fumigants. ACS Symposium Series 652. Washington, DC: American Chemical Society, 42–52. 10.1021/bk-1997-0652.ch005.
Anger WK, Setzer JV, Russo JM, . 1981. Neurobehavioral effects of methyl bromide inhalation exposures. Scand J Work Environ Health 7(4):40–47.7330628
Anger WK, Moody L, Burg J, . 1986. Neurobehavioral evaluation of soil and structural fumigators using methyl bromide and sulfuryl fluoride. Neurotoxicology 7(3):137–156.3822255
ARB. 1986. Inhalation uptake of selected chemical vapors at trace levels. Sacramento, CA: California Air Resources Board. UCD-472-507. https://www.arb.ca.gov/research/apr/past/a3-132-33.pdf. June 19, 2017.
ARB. 1988. Inhalation uptake of xenobiotic vapors by people. Sacramento, CA: California Air Resources Board. PB88202726/AS. https://www.arb.ca.gov/research/apr/past/a5-155-33.pdf. June 19, 2017.
Atkinson R. 1989. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds. National Institute of Standards and Technology. Journal of Physical and Chemical Reference Data, Monograph No. 1. https://srd.nist.gov/JPCRD/jpcrdM1.pdf. June 3, 2019.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles: Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2017. Bromomethane. Full SPL data. Substance priority list (SPL) resource page. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources/index.html. December 2, 2019.
Baker LW, Fitzell DL, Seiber JN, . 1996. Ambient air concentrations of pesticides in California. Environ Sci Technol 30:1365–1368.
Baker JM, Reeves CE, Nightingale PD, . 1999. Biological production of methyl bromide in the coastal waters of the North Sea and open ocean of the northeast Atlantic. Mar Chem 64:267–285.
Balagopal K, Muthusamy K, Alexander M, . 2011. Methyl bromide poisoning presenting as acute ataxia. Neurol India 59(5):768–769. 10.4103/0028-3886.86561.22019671
Bamgbose JT, Bamgbose O. 2008. Effect of methyl bromide on the β-93 sulfhydryl groups of human and mouse hemoglobin. J Chem Soc Nigeria 33(1):47–55.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barry KH, Koutros S, Lubin JH, . 2012. Methyl bromide exposure and cancer risk in the Agricultural Health Study. Cancer Causes Control 23(6):807–818. 10.1007/s10552-012-9949-2.22527160
Baur X, Budnik LT, Zhao ZH, . 2015. Health risks in international container and bulk cargo transport due to volatile toxic compounds. J Occup Med Toxicol 10:19. 10.1186/s12995-015-0059-4.26075009
Behrens RH, Dukes DCD. 1986. Fatal methyl bromide poisoning. Br J Ind Med 43(8):561–562.3730308
Bishop C. 1992. A case of methyl bromide poisoning. Occup Med (Lond) 42(2):107–109.1606304
Bond JA, Dutcher JA, Medinsky MA, . 1985. Disposition of [14C]methyl bromide in rats after inhalation. Toxicol Appl Pharmacol 78:259–267.4035680
Boorman GA, Hong HL, Jameson CW, . 1986. Regression of methyl bromide-induced forestomach lesions in the rat. Toxicol Appl Pharmacol 86(1):131–139. 10.1016/0041-008x(86)90406-0.3764933
Breslin WJ, Zublotny CL, Bradley GL. 1990. Methyl bromide inhalation teratology study in New Zealand white rabbits with cover letter and attachment (declassified). Dow Chemical Company. Submitted to the U.S. Environmental Protection Study under TSCA Section 8E. OTS0522340-3. EPA89910000053.
Brown BD, Rolston DE. 1980. Transport and transformation of methyl bromide in soils. Soil Sci 130(2):68–75.
Bulathsinghala AT, Shaw IC. 2014. The toxic chemistry of methyl bromide. Hum Exp Toxicol 33(1):81–91. 10.1177/0960327113493299.23800997
Butler JH, Rodriguez JM. 1996. Methyl bromide in the atmosphere. In: Bell CH, Price N, Chakrabarti B, eds. The methyl bromide issue. West Sussex, UK: John Wiley & Sons Ltd, 27–90.
Butler ECB, Perry KMA, Williams JRF. 1945. Methyl bromide burns. Br J Ind Med 2(1):30–31.
Cal EPA. 2008. Memorandum: Summary of ambient air monitoring for methyl bromide and 1,3-dichloropropene in Ventura County in 2005 and 2006. California Environmental Protection Agency.
Cal EPA. 2014. Memorandum: Methyl bromide air monitoring results for 2013. California Environmental Protection Agency.
Cal EPA. 2015. Memorandum: Methyl bromide, 1,3-dichloropropene, and chloropicrin air monitoring results for 2010-2014. California Environmental Protection Agency.
Calvert GM, Mueller CA, Fajen JM, . 1998a. Health effects associated with sulfuryl fluoride and methyl bromide exposure among structural fumigation workers. Am J Public Health 88(12):1774–1780.9842373
Calvert GM, Talaska G, Mueller CA, . 1998b. Genotoxicity in workers exposed to methyl bromide. Mutat Res Genet Toxicol Environ Mutagen 417(2):115–128.
Castro CE, Belser NO. 1981. Photohydrolysis of methyl bromide and chloropicrin. J Agric Food Chem 29(5):1005–1008. 10.1021/jf00107a030.
CDC. 2018. Fourth national report on human exposure to environmental chemicals. Updated tables, March 2018, Volume One. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/pdf/FourthReport_UpdatedTables_Volume1_Mar2018.pdf. December 2, 2019.
Chavez CT, Hepler RS, Staatsma BR. 1985. Methyl bromide optic atrophy. Am J Ophthalmol 99:715–719.2990215
Clarke CA, Roworth CG, Holling HE. 1945. Methyl bromide poisoning: An account of four recent cases met with in one of H.M. ships. Br J Ind Med 2(1):17–23.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cockburn M, Mills P, Zhang X, . 2011. Prostate cancer and ambient pesticide exposure in agriculturally intensive areas in California. Am J Epidemiol 173(11):1280–1288. 10.1093/aje/kwr003.21447478
Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the Nationwide Urban Runoff Program. J Water Pollut Control Fed 56(7):898–908.
Coleman WE, Lingg RD, Metten RG, . 1976. The occurrence of volatile organics in five drinking water supplies using gas chromatography/mass spectrometry. In: Keith LH, ed. Identification and analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 305–327.
Connell TL, Joye SB, Miller LG, . 1997. Bacterial oxidation of methyl bromide in Mono Lake, California. Environ Sci Technol 31(5):1489–1495. 10.1021/es960732k.
Daft J. 1987. Determining multi-fumigants in whole grain and legumes, milled and low-fat grain products, spices, citrus fruits and beverages. J Assoc off Agric Chem 70:734–739.
Daft JL. 1988. Rapid determination of fumigant and industrial chemical residues in food. J Assoc off Agric Chem 71:748–760.
Daft JL. 1989. Determination of fumigants and related chemicals in fatty and non-fatty foods. J Agric Food Chem 37:560–564.
Danse LH, van Velsen FL, van der Heijden CA. 1984. Methyl bromide: Carcinogenic effects in the rat forestomach. Toxicol Appl Pharmacol 72(2):262–271.6695375
Davenport CJ, Ali SF, Miller FJ, . 1992. Effects of methyl bromide on regional brain glutathione, glutathione-S-transferases, monoamines, and amino acids in F344 rats. Toxicol Appl Pharmacol 112:120–127.1733043
Davis DD, Machado G, Conaway B, . 1976. A temperature dependent kinetics study of the reaction of OH with CH3Cl, CH2Cl2, CHCl3, and CH3Br. J Chem Phys 65(4):1268–1274. 10.1063/1.433236.
de Souza A, Narvencar KP, Sindhoora KV. 2013. The neurological effects of methyl bromide intoxication. J Neurol Sci 335(1–2):36–41. 10.1016/j.jns.2013.09.022.24094859
de Vreede JA, den Boeft J, van Hemmen JJ. 1998. Exposure to methyl bromide during greenhouse fumigation on Crete, Greece. Arch Environ Contam Toxicol 35(3):539–547.9732489
Deschamps FJ, Turpin JC. 1996. Methyl bromide intoxication during grain store fumigation. Occup Med (Lond) 46(1):89–90.8672804
Djalali-Behzad G, Hussain S, Osterman-Golkar S, . 1981. Estimation of genetic risks of alkylating agents. VI. Exposure of mice and bacteria to methyl bromide. Mutat Res 84(1):1–9.7035924
DOE. 2018a. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/. July 26, 2018.
DOE. 2018b. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 26, 2018.
EFSA. 2015. The 2013 European Union report on pesticide residues in food. EFSA J 13(3):4038. 10.2903/j.efsa.2015.4038.
EPA. 1975. Preliminary assessment of suspected carcinogens in drinking water: Interim report to the Congress. Washington, DC: U.S. Environmental Protection Agency
EPA. 1976. Frequency of organic compounds identified in water. Athens, GA: U.S. Environmental Protection Agency. EPA600476062. PB265470.
EPA. 1979a. Water-related environmental fate of 129 priority pollutants. Vol. I. Introduction and technical background, metals and inorganics, pesticides and PCBs. Washington, DC: U.S. Environmental Protection Agency. EPA440479029a. PB80204373.
EPA. 1979b. Sources of toxic pollutants found in influents to sewage treatment plants. VI. Integrated interpresentation. Washington, DC: U.S. Environmental Protection Agency. EPA440481008. PB81219685.
EPA. 1982. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency. EPA440481014.
EPA. 1986a. Two-generation reproduction study via inhalation in albino rats using methyl bromide. American Biogenics Corp. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8d. OTS0515364. EPA86870000926.
EPA. 1986b. Health and environmental effects profile for methyl bromide. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600X86171. https://cfpub.epa.gov/ncea/risk/hhra/recordisplay.cfm?deid=44080. May 30, 2019.
EPA. 1987. Drinking water health advisory for bromomethane. Cincinnati, OH: U.S. Environmental Protection Agency. ECAOCINW003.
EPA. 1988a. Data evaluation record. Methyl bromide: Subchronic inhalation study in mice. Washington, DC: U.S. Environmental Protection Agency. EPA68D80056. https://www3.epa.gov/pesticides/chem_search/cleared_reviews/csr_PC-053201_15-Nov-88_026.pdf. May 31, 2019.
EPA. 1988b. Recommendations for and documentations of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency. PB88179874.
EPA. 1988c. Method 502.1. Volatile halogenated organic compounds in water by purge and trap gas chromatography. In: Methods for the determination of organic compounds in finished drinking water and raw source water. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600488039.
EPA. 1992. Pesticides in ground water database. A compilation of monitoring studies: 1971-1991. National Summary. U.S. Environmental Protection Agency. EPA7341292001.
EPA. 1993. Memorandum. ID No. 053201. Methyl bromide. Review of inhalation acute neurotoxicity study in rat (81-8SS). Submitted to support reregistration of methyl bromide. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1994a. Data evaluation record. Methyl bromide: Ninety-day vapour inhalation neurotoxicity study in CD rats. Washington, DC: U.S. Environmental Protection. MRID43077401.
EPA. 1994b. Methods for derivation of inhalation reference concentrations and applications of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. EPA600890066F.
EPA. 1996. Data evaluation record. Evaluation of four-week dietary range-finding toxicity study of microencapsulated methyl bromide in rats. Washington, DC: U.S. Environmental Protection Agency. MRID43776401.
EPA. 1999. Memorandum. Methyl bromide-combine chronic/oncogenicity feeding-rat (83.5). U.S. Environmental Protection Agency. MRID4462501.
EPA. 2001a. Data evaluation record. An up and down acute inhalation toxicity study of methyl bromide in the dog. U.S. Environmental Protection Agency. MRID443386801.
EPA. 2001b. Data evaluation record. A four week inhalation toxicity study of methyl bromide in the dog. U.S. Environmental Protection Agency. MRID443386802.
EPA. 2002. Data evaluation record. Methyl bromide - Review of subchronic (6-week) inhalation toxicity study in dogs. U.S. Environmental Protection Agency. MRID45722801.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act. Washington, DC: U.S. Environmental Protection Agency. EPA260B05001. https://ofmpub.epa.gov/apex/guideme_ext/guideme_ext/guideme/file/ry_2004_rfi.pdf. May 31, 2019.
EPA. 2008a. Reregistration eligibility decision for methyl bromide (soil and non-food structural uses). U.S. Environmental Protection Agency. EPA738R08005. https://nepis.epa.gov/EPA/html/DLwait.htm?url=/Exe/ZyPDF.cgi/P1000VUL.PDF?Dockey=P1000VUL.PDF. May 31, 2019.
EPA. 2008b. RED fact sheet for methyl bromide. U.S. Environmental Protection Agency. https://www3.epa.gov/pesticides/chem_search/reg_actions/reregistration/fs_PC-053201_10-Jul-08.pdf. December 2, 2019.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2011. Data evaluation record. 28-Day inhalation immunotoxicity study-rat. U.S. Environmental Protection Agency. OPPTS 870-7800.
EPA. 2012. Benchmark dose technical guidance. Washington, DC: U.S. Environmental Protection Agency. EPA100R12001.
EPA. 2014a. The phaseout of methyl bromide. Ozone layer protection-regulatory programs. U.S. Environmental Protection Agency.
EPA. 2014b. Part 180 - Tolerances and exemptions for pesticide chemical residues in food. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180. https://www.govinfo.gov/app/details/CFR-2014-title40-vol24/CFR-2014-title40-vol24-part180/context. May 31, 2019.
EPA. 2015a. Protection of stratospheric ozone: The 2016 critical use exemption from the phaseout of methyl bromide. Fed Regist 80(199):61985–61993.
EPA. 2015b. Air emissions inventory home. National Emissions Inventory (NEI). U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/national-emissions-inventory. December 2, 2019.
EPA. 2015c. Subchapter D-water programs. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. https://www.gpo.gov/fdsys/pkg/CFR-2015-title40-vol22/pdf/CFR-2015-title40-vol22-sec116-4.pdf. May 30, 2019.
EPA. 2016a. Exemptions for methyl bromide. Phaseout of ozone-depleting substances. U.S. Environmental Protection Agency.
EPA. 2016b. Fact sheet- protection of stratospheric ozone: The 2016 critical use exemption from the phaseout of methyl bromide. U.S. Environmental Protection Agency.
EPA. 2016c. Ozone lay protection- regulatory programs. Methyl bromide. U.S. Environmental Protection Agency.
EPA. 2016d. STORET data warehouse access. Bromomethane. CAS number 74-83-9. U.S. Environmental Protection Agency. http://www3.epa.gov/storet/dbtop.html. February 4, 2016.
EPA. 2016e. Chemical data reporting results: Bromomethane. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-04/2016_cdr_database.zip. May 31, 2019.
EPA. 2016f. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-03/documents/compiled_aegl_update_.pdf. September 8, 2017.
EPA. 2017. The Third Unregulated Contaminant Monitoring Rule (UCMR 3): Data Summary, January 2017. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2017-02/documents/ucmr3-data-summary-january-2017.pdf. December 3, 2019.
EPA. 2018a. Methyl bromide. Draft human health risk assessment for registration review. Washington, DC: U.S. Environmental Protection Agency. D449330. https://files.nc.gov/ncdeq/GenX/SAB/EPA-HQ-OPP-2013-0269-0030.pdf. October 23, 2019.
EPA. 2018b. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018c. About Acute Exposure Guideline Levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2019a. Air quality system (AQS). Data files. Annual summary data. U.S. Environmental Protection Agency. https://www.epa.gov/outdoor-air-quality-data. December 2, 2019.
EPA. 2019b. Data evaluation record. Methyl bromide developmental neurotoxicity study (DNT). Washington, DC: U.S. Environmental Protection Agency. MRID46665001.
Eustis SL, Haber SB, Drew RT, . 1988. Toxicology and pathology of methyl bromide in F344 rats and B6C3F1 mice following repeated inhalation exposure. Fundam Appl Toxicol 11:594–610.3229585
FDA. 2018. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. July 26, 2018.
Fennimore SA, Ajwa HA. 2011. Totally impermeable film retains fumigants, allowing lower application rates in strawberry. Calif Agric 65(4):211–215. 10.3733/ca.E.v065n04p211.
Freeman J. 2015. Totally impermeable film- A new plastic mulch option for 2016 fumigation. University of Florida IFAS Extension. https://nwdistrict.ifas.ufl.edu/phag/2015/11/13/totally-impermeable-film-a-new-plastic-mulch-option-for-2016-fumigation/. December 2, 2019.
Fuhr I, Bransford AV, Silver SD. 1948. Sorption of fumigant vapors by soil. Science 107:274–275.17844507
Gan J, Yates SR. 1996. Degradation and phase partition of methyl iodide in soil. J Agric Food Chem 44(12):4001–4008. 10.1021/jf960413c.
Gan J, Yates SR, Anderson MA, . 1994. Effect of soil properties on degradation and sorption of methyl bromide in soil. Chemosphere 29(12):2685–2700. 10.1016/0045-6535(94)90067-1.
Gan J, Yates SR, Wang D, . 1996. Effect of soil factors on methyl bromide volatilization after soil application. Environ Sci Technol 30(5):1629–1636. 10.1021/es950624i.
Gan J, Yates SR, Ohr HD, . 1997. Volatilization and distribution of methyl iodide and methyl bromide after subsoil application. J Environ Qual 26(4):1107–1115. 10.2134/jeq1997.00472425002600040023x.
Gan J, Yates SR, Papiernik S, . 1998. Application of organic amendments to reduce volatile pesticide emissions from soil. Environ Sci Technol 32(20):3094–3098.
Gan J, Yates SR, Ernst FF, . 2000. Degradation and volatilization of the fumigant chloropicrin after soil treatment. J Environ Qual 29(5):1391–1397. 10.2134/jeq2000.00472425002900050004x.
Gansewendt B, Foest U, Xu D, . 1991. Formation of DNA adducts in F-344 rats after oral administration or inhalation of [14C] methyl bromide. Food Chem Toxicol 29(8):557–563.1894222
Gargas ML, Andersen ME. 1982. Metabolism of inhaled brominated hydrocarbons: Validation of gas uptake results by determination of a stable metabolite. Toxicol Appl Pharmacol 66:55–68.
Gemmill A, Gunier RB, Bradman A, . 2013. Residential proximity to methyl bromide use and birth outcomes in an agricultural population in California. Environ Health Perspect 121(6):737–743. 10.1289/ehp.1205682.23603811
Gentile IA, Ferraris L, Crespi S, . 1989. The degradation of methyl bromide in some natural fresh waters. Influence of temperature, pH and light. Pestic Sci 25(3):261–272. 10.1002/ps.2780250307.
Geyer HL, Schaumburg HH, Herskovitz S. 2005. Methyl bromide intoxication causes reversible symmetric brainstem and cerebellar MRI lesions. Neurology 64(7):1279–1281. 10.1212/01.wnl.0000156835.12492.30.15824365
Goodwin KD, Schaefer JK, Oremland RS. 1998. Bacterial oxidation of dibromomethane and methyl bromide in natural waters and enrichment cultures. Appl Environ Microbiol 64(12):4629–4636.9835541
Gotoh K, Nishizawa T, Yamagucki T, . 1994. Two-year toxicological and carcinogenesis studies of methyl bromide in F344 rats and BDF1 mice - Inhalation studies. In: Proceedings of the ICMR Seminar, 2: Environmental and occupational chemical hazards 2nd Asia-Pacific symposium on environmental and occupational health. Kobe, Japan: International Center for Medical Research, 185–192.
Greenberg JO. 1971. The neurological effects of methyl bromide poisoning. Ind Med Surg 40:27–29.
Gunier RB, Bradman A, Castorina R, . 2017. Residential proximity to agricultural fumigant use and IQ, attention and hyperactivity in 7-year old children. Environ Res 158:358–365. 10.1016/j.envres.2017.06.036.28686950
Hardin BD, Bond GP, Sikov MR, . 1981. Testing of selected workplace chemicals for teratogenic potential. Scand J Work Environ Health 7:66–75.7330632
Harsch DE, Rasmussen RA. 1977. Identification of methyl bromide in urban air. Anal Lett 10(13):1041–1047.
Hastings L, Miller ML, Minnema DJ, . 1991. Effects of methyl bromide on the rat olfactory system. Chem Senses 16(1):43–56.
Hatch GG, Mamay PD, Ayer ML, . 1983. Chemical enhancement of viral transformation in Syrian hamster embryo cells by gaseous and volatile chlorinated methanes and ethanes. Cancer Res 43(5):1945–1950.6299533
Herzstein J, Cullen MR. 1990. Methyl bromide intoxication in four field-workers during removal of soil fumigation sheets. Am J Ind Med 17(3):321–326.2305812
Hezemans-Boer M, Toonstra J, Meulenbelt J, . 1988. Skin lesions due to exposure to methyl bromide. Arch Dermatol 124(6):917–921. 10.1001/archderm.1988.01670060063018.2967677
Hine CH. 1969. Methyl bromide poisoning: A review of ten cases. J Occup Med 11:1–10.5771232
Hines ME, Crill PM, Varner RK, . 1998. Rapid consumption of low concentrations by methyl bromide by soil bacteria. Appl Environ Microbiol 64(5):1864–1870.9572964
Holbrook EH, Iwema CL, Peluso CE, . 2014. The regeneration of P2 olfactory sensory neurons is selectively impaired following methyl bromide lesion. Chem Senses 39(7):601–616. 10.1093/chemse/bju033.25056730
Honma T. 1987. Alteration of catecholamine metabolism in rat brain produced by inhalation exposure to methyl bromide. Sangyo Igaku 29:218–219.3682276
Honma T, Miyagawa M, Sato M. 1987. Methyl bromide alters catecholamine and metabolite concentrations in rat brain. Neurotoxicol Teratol 9:369–375.2447477
Honma T, Sudo A, Miyagawa M, . 1982. Significant changes in monoamines in rat brain induced by exposure to methyl bromide. Neurobehav Toxicol Teratol 4:521–524.6129581
Honma T, Miyagawa M, Sato M, . 1985. Neurotoxicity and metabolism of methyl bromide in rats. Toxicol Appl Pharmacol 81:183–191.4060147
Hori H, Hyakudo T, Oyabu T, . 2002. Effects of inhaled methyl bromide gas on the metabolic system and kinetics of bromine ion in rats. J UOEH 24(2):151–160.12066583
Horiuchi N, Oguchi S, Nagami H, . 2008. Pesticide-related dermatitis in Saku district, Japan, 1975-2000. Int J Occup Environ Health 14(1):25–34. 10.1179/oeh.2008.14.1.25.18320729
HSDB. 2014. Methyl bromide. Hazardous Substances Data Bank. National Library of Medicine. https://toxnet.nlm.nih.gov/cgi-bin/sis/search2/f?./temp/~JuMkjw:3#download. December 2, 2019.
Huard JM, Youngentob SL, Goldstein BJ, . 1998. Adult olfactory epithelium contains multipotent progenitors that give rise to neurons and non-neural cells. J Comp Neurol 400(4):469–486.9786409
Hurtt ME, Working PK. 1988. Evaluation of spermatogenesis and sperm quality in the rat following acute inhalation exposure to methyl bromide. Fundam Appl Toxicol 10:490–498.3371587
Hurtt ME, Morgan KT, Working PK. 1987. Histopathology of acute toxic responses in selected tissues from rats exposed by inhalation to methyl bromide. Fundam Appl Toxicol 9:352–365.3653577
Hurtt ME, Thomas DA, Working PK, . 1988. Degeneration and regeneration of the olfactory epithelium following inhalation exposure to methyl bromide: Pathology, cell kinetics, and olfactory function. Toxicol Appl Pharmacol 94:311–328.2455365
Hustinx WN, van de Laar RT, van Huffelen AC, . 1993. Systemic effects of inhalational methyl bromide poisoning: A study of nine cases occupationally exposed due to inadvertent spread during fumigation. Br J Ind Med 50(2):155–159.8435348
Hyakudo T, Hori H, Tanaka I, . 2001. Inhibition of creatine kinase activity in rat brain by methyl bromide gas. Inhal Toxicol 13:659–669.11498799
IARC. 1986. Methyl bromide. In: IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Some halogenated hydrocarbons and pesticide exposures. Lyon, France: International Agency for Research on Cancer. Vol. 41, 187–212.
IARC. 1999. Methyl bromide. In: IARC monographs on the evaluation of carcinogenic risks to humans. Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide. Lyon, France: International Agency for Research on Cancer. Vol. 71, 1–12. https://monographs.iarc.fr/wpcontent/uploads/2018/06/mono71-31.pdf. May 29, 2019.
IARC. 2016. Agents classified by the IARC monographs. Volumes 1–115. Lyon, France: International Agency for Research on Cancer.
Ikawa N, Araki A, Nozaki K, . 1986. Micronucleus test of methyl bromide by the inhalation method [Abstract]. Mutat Res 164(4):269.
Ikeda T, Kishi R, Yamamura K, . 1980. Behavioural effects in rats following repeated exposure to methyl bromide. Toxicol Lett 6:293–299.7423558
IRAC. 2019. IRAC Mode of action classification scheme. Version 9.3. Insecticide Resistance Action Committee. 7. https://www.irac-online.org/documents/moa-classification/. December 2, 2019.
IRIS. 2002. Bromomethane (CASRN 74-83-9). Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0015_summary.pdf. May 30, 2019.
Irish DD, Adams EM, Spencer HC, . 1940. The response attending exposure of laboratory animals to vapors of methyl bromide. J Ind Hyg Toxicol 22(6):218–230.
Iwasaki K. 1988a. Determination of S-methylcysteine in mouse hemoglobin following exposure to methyl bromide. Ind Health 26:187–190.3182305
Iwasaki K. 1988b. Individual differences in the formation of hemoglobin adducts following exposure to methyl bromide. Ind Health 26(4):257–262.3230058
Jaskot RH, Grose EC, Most BM, . 1988. The distribution and toxicological effects of inhaled methyl bromide in the rat. J Am Coll Toxicol 7:631–642.
Johnstone RT. 1945. Methyl bromide intoxication of a large group of workers. Ind Med 14(6):495–497.
Kaneda M, Hojo H, Teramoto S, . 1998. Oral teratogenicity studies of methyl bromide in rats and rabbits. Food Chem Toxicol 36(5):421–427.9662417
Kantarjian AD, Shaheen AS. 1963. Methyl bromide poisoning with nervous system manifestations resembling polyneuropathy. Neurology 13:1054–1058.
Kato N, Morinobu S, Ishizu S. 1986. Subacute inhalation experiment for methyl bromide in rats. Ind Health 24(2):87–103.3759512
Katz AJ. 1987. Inhalation of methyl bromide gas induces mitotic recombination in somatic cells of Drosophila melanogaster. Mutat Res 192:131–135.3116427
Kishi R, Ishizu I, Ito I, . 1988. Health research on methyl bromide manufacturing workers. Part 1: Symptoms of long-term exposure. In: Occupational health in the chemical industry - Papers presented at the XXII ICOH Congress, Sydney, Australia, 27 September - 2 October 1987. Copenhagen, Denmark: World Health Organization, 120–134.
Kloth S, Baur X, Goen T, . 2014. Accidental exposure to gas emissions from transit goods treated for pest control. Environ Health 14:110. 10.1186/1476-069x-13-110.
Kolpin DW, Barbash JE, Gilliom RJ. 2000. Pesticides in ground water of the United States, 1992-1996. Ground Water 38(6):858–863.
Kool HJ, van Kreijh CF, Zoetman BCJ. 1982. Toxicology assessment of organic compounds in drinking water. Crit Rev Environ Control 12(4):307–357.
Kopfler FC, Melton RG, Mullaney JL, . 1977. Human exposure to water pollutants. Adv Environ Sci Technol 8:419–433.
Kornbrust DJ, Bus JS. 1983. The role of glutathione and cytochrome P-450 in the metabolism of methyl chloride. Toxicol Appl Pharmacol 67:246–256.6836579
Kramers PG, Voogd CE, Knaap AG, . 1985. Mutagenicity of methyl bromide in a series of short-term tests. Mutat Res 155:41–47.3918260
Krill RM, Sonzogni WC. 1986. Chemical monitoring of Wisconsin’s groundwater. J Am Water Works Assoc 78(9):70–75.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kulkarni PA, Duncan MA, Watters MT, . 2015. Severe illness from methyl bromide exposure at a condominium resort - U.S. Virgin Islands, March 2015. MMWR Morb Mortal Wkly Rep 64(28):763–766.26203630
Langard S, Rognum T, Flotterod O, . 1996. Fatal accident resulting from methyl bromide poisoning after fumigation of a neighbouring house; Leakage through sewage pipes. J Appl Toxicol 16(5):445–448. 10.1002/(sici)1099-1263(199609)16:5<445::aid-jat370>3.0.co;2-a.8889797
Larrañaga MD, Lewis RJ, Lewis RA. 2016. Methyl bromide. In: Hawley’s Condensed Chemical Dictionary. 16th ed. John Wiley & Sons, Inc., 896. 10.1002/9781119312468.
Lee S, McLaughlin R, Harnly M, . 2002. Community exposures to airborne agricultural pesticides in California: Ranking of inhalation risks. Environ Health Perspect 110(12):1175–1184.12460795
Lefevre C, Ferrari P, Guenier JP, . 1989. Sampling and analysis of airborne methylbromide. Chromatographia 27:37–43.
Lerro CC, Beane Freeman LE, DellaValle CT, . 2018. Occupational pesticide exposure and subclinical hypothyroidism among male pesticide applicators. Occup Environ Med 75(2):79–89. 10.1136/oemed-2017-104431.28775130
Longley EO, Jones AT. 1965. Methyl bromide poisoning in man. Ind Med Surg 34:499–502.14308332
Lovelock JE. 1975. Natural halocarbons in the air and in the sea. Nature 256:193–194.1152986
Majewski MS, McChesney MM, Woodrow JE, . 1995. Organic chemicals in the environment. Aerodynamic measurements of methyl bromide volatilization from tarped and nontarped fields. J Environ Qual 24:742–752.
Marraccini JV, Thomas GE, Ongley JP, . 1983. Death and injury caused by methyl bromide, an insecticide fumigant. J Forensic Sci 28(3):601–607.6619779
Medinsky MA, Bond JA, Dutcher JS, . 1984. Disposition of [14C]methyl bromide in Fischer-344 rats after oral or intraperitoneal administration. Toxicology 32:187–196.6433513
Medinsky MA, Dutcher JS, Bond JA, . 1985. Uptake and excretion of [14C]methyl bromide as influenced by exposure concentration. Toxicol Appl Pharmacol 78:215–225.4035677
Miller JW. 1943. Fatal methyl bromide poisoning. Arch Pathol 36:505–507.
Mills PK, Yang R. 2003. Prostate cancer risk in California farm workers. J Occup Environ Med 45(3):249–258.12661182
Mills PK, Yang RC. 2007. Agricultural exposures and gastric cancer risk in Hispanic farm workers in California. Environ Res 104(2):282–289.17196584
Moriya M, Ohta T, Watanabe K, . 1983. Further mutagenicity studies on pesticides in bacterial reversion assay systems. Mutat Res 116:185–216.6339892
NAS. 1978. Nonfluorinated halomethanes in the environment. Scientific and Technical Assessments of Environmental Pollutants. Washington, DC: National Academy of Sciences.
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
Neely WB, Branson DR, Blau GE. 1974. Partition coefficient to measure bioconcentrations potential of organic chemicals in fish. Environ Sci Technol 8:1113–1115.
NIOSH. 1980. Teratologic assessment of butylene oxide, styrene oxide and methyl bromide. Cincinnati, OH: National Institute for Occupational Safety and Health. PB81168510.
NIOSH. 1981. Tier II mutagenic screening of 13 NIOSH priority compounds: Individual compound report methyl bromide. Cincinnati, OH: National Institute for Occupational Safety and Health. PB83130211.
NIOSH. 1984. Monohalomethanes: Methyl chloride, methyl bromide, methyl iodide. Current Intelligence Bulletin 43. National Institute for Occupational Safety and Health.
NIOSH. 1994. Methyl bromide. Immediately Dangerous to Life or Health concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/74839.html. May 29, 2019.
NIOSH. 2018. Methyl bromide. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0400.html. May 29, 2019.
NOAA. 2019. Methyl bromide (CAS number: 74-83-9). CAMEO Chemicals. U.S. National Oceanic and Atmospheric Administration. https://cameochemicals.noaa.gov/chemical/1091. May 31, 2019.
NPIRS. 2016. Methyl bromide. PC code: 53201. Search for federal pesticide products. National Pesticide Information Retrieval System. http://npirspublic.ceris.purdue.edu/ppis/Default.aspx. January 29, 2016.
NTP. 1987. A chronic inhalation study of methyl bromide toxicity in B6C3F1 mice. Research Triangle Park, NC: National Toxicology Program. http://www.osti.gov/scitech/servlets/purl/791305 October 7, 2016.
NTP. 1992. Toxicology and carcinogenesis studies of methyl bromide (CAS no. 74-83-9) in B6C3F1 mice (inhalation studies). National Toxicology Program. TR 385. http://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr385.pdf. May 27, 2015.
NTP. 2016. Substances listed in the fourteenth report on carcinogens. Report on carcinogens, fourteenth edition. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/listed_substances_508.pdf. May 30, 2019.
O’Malley MA, Fong H, Mehler L, . 2011. Illness associated with exposure to methyl bromide-fumigated produce - California, 2010. MMWR Morb Mortal Wkly Rep 60(27):923–926.21753746
O’Neal L. 1987. Acute methyl bromide toxicity. J Emerg Nurs 13:96–98.3550201
O’Neil M, Heckelman PE, Dobbelaer R, . 2014. 6103. Methyl bromide. In: The Merck index. 15th ed. London, England: Emerald Group Publishing Limited, 119. 10.1108/rr-08-2014-0224.
Oremland RS, Miller LG, Strohmaier FE. 1994. Degradation of methyl bromide in anaerobic sediments. Environ Sci Technol 28(3):514–520.22165889
OSHA. 2018a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. November 28, 2018.
OSHA. 2018b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. November 1, 2018.
OSHA. 2018c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. November 1, 2018.
Ou LT. 1998. Enhanced degradation of the volatile fumigant-nematicides 1,3-D and methyl bromide in soil. J Nematol 30(1):56–64.19274199
Papiernik SK, Gan J, Yates SR. 2000. Mechanism of degradation of methyl bromide and propargyl bromide in soil. J Environ Qual 29:1322–1328.
Pellizzari ED, Sheldon LS, Bursey JT. 1985. Method 25. GC/MS determination of volatile halocarbons in blood and tissue. In: Environmental carcinogens selected methods of analysis. Vol. 7. Lyon, France: International Agency for Research on Cancer, 435–444.
Piccirillo VJ, Piccirillo AL. 2010. Methyl bromide. In: Krieger R, ed. Hayes’ handbook of pesticide toxicology. 3rd ed. London, UK: Academic Press, 2267–2279.
Plumb RH. 1992. The importance of volatile organic compounds as a disposal site monitoring parameter. In: Lesage S, Jackson R, eds. Groundwater contamination and analysis at hazardous waste sites. New York, NY: Marcel Dekker, Inc., 173–197.
Prain JH, Smith GH. 1952. A clinical-pathological report of eight cases of methyl bromide poisoning. Br J Ind Med 9:44–49.14895802
Prockop LD, Smith AO. 1986. Seizures and action myoclonus after occupational exposure to methyl bromide. J Fla Med Assoc 76:690–692.
Rathus EM, Landy PJ. 1961. Methyl bromide poisoning. Br J Ind Med 18:53–57.13739738
Reed CJ, Gaskell BA, Banger KK, . 1995. Olfactory toxicity of methyl iodide in the rat. Arch Toxicol 70(1):51–56.8750905
Reuzel PG, Kuper CF, Dreef-van der Meulen HC, . 1987. Initial submission: Chronic (29-month) inhalation toxicity and carcinogenicity study of methyl bromide in rats with cover letter dated 081092. DuPont Chem Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP. OTS0546338. EPA88920008788.
Reuzel PG, Dreef-van der Meulen HC, Hollanders VM, . 1991. Chronic inhalation toxicity and carcinogenicity study of methyl bromide in Wistar rats. Food Chem Toxicol 29(1):31–39.1825644
Rhew RC, Aydin M, Saltzman ES. 2003. Measuring terrestrial fluxes of methyl chloride and methyl bromide using a stable isotope tracer technique. Geophys Res Lett 30(21):2103. 10.1029/2003/GL018160.
Robbins DE. 1976. Photodissociation of methyl chloride and methyl bromide in the atmosphere. Geophys Res Lett 3:213–216.
Roy WR, Griffin RA. 1985. Mobility of organic solvents in water-saturated soil materials. Environ Geol Water Sci 7:241–247.
Russo JM, Anger WK, Setzer JV, . 1984. Neurobehavioral assessment of chronic low-level methyl bromide exposure in the rabbit. J Toxicol Environ Health 14(2–3):247–255. 10.1080/15287398409530577.6502736
Ruth JH. 1986. Odor thresholds and irritation levels of several chemical substances: A review. Am Ind Hyg Assoc J 47:142–151.
Sato M, Miyagawa M, Honma T, . 1985. Subacute effects of methyl bromide dosed by inhalation exposure to rats. Ind Health 23:235–238.4066415
Schwob JE, Youngentob SL, Ring G, . 1999. Reinnervation of the rat olfactory bulb after methyl bromide-induced lesion: Timing and extent of reinnervation. J Comp Neurol 412(3):439–457.
Shorter JH, Kolb CE, Crill PM, . 1995. Rapid degradation of atmospheric methyl bromide in soils. Nature 377:717–719.
Simmon VF, Tardiff RG. 1978. The mutagenic activity of halogenated compounds found in chlorinated drinking water. In: Jolley RL, Gorchev H, Hamilton DH, eds. Water chlorination environmental impact and health effects. Vol. 2. Ann Arbor, MI: Ann Arbor Science, 417–431.
Singh HB, Salas LJ, Stiles RE. 1983. Methyl halides in and over the Eastern Pacific (40°N-32°S). J Geophys Res 88:3684–3690.
Singh HB, Salas LJ, Smith AJ, . 1981. Measurements of some potentially hazardous organic chemicals in urban environments. Atmos Environ 15:601–612.
Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
Starratt AN, Bond EJ. 1988. In vitro methylation of DNA by the fumigant methyl bromide. J Environ Sci Health B 23:513–524.
Tanaka S, Arito H, Abuku SI, . 1988. Acute effects of methyl bromide on electroencephalographic activity and sleep-wakefulness in rats. Ind Health 26:101–114.3403303
Tanaka S, Abuku S, Seki Y, . 1991. Evaluation of methyl bromide exposure on the plant quarantine fumigators by environmental and biological monitoring. Ind Health 29(1):11–21.2026507
TRI17. 2019. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. April 4, 2019.
Triky-Dotan S, Ajwa HA. 2014. Dissipation of soil fumigants from soil following repeated applications. Pest Manag Sci 70(3):440–447. 10.1002/ps.3586.23744676
Tucker JD, Xu J, Stewart J, . 1986. Detection of sister chromatid exchanges induced by volatile genotoxicants. Teratog Carcinog Mutagen 6:15–21.2426822
UNEP. 2015. Montreal protocol on substances that deplete the ozone layer. 2014 Report of the methyl bromide technical options committee. United Nations Environment Program. https://ozone.unep.org/node/2058. December 2, 2019.
USGS. 2015. Water quality in principal aquifers of the United States, 1991-2000. U.S. Geological Survey. 10.3133/cir1360.
Van Den Oever RU, Roosels D, Lahaye D. 1982. Actual hazard of methyl bromide fumigation in soil disinfection. Br J Ind Med 39:140–144.7066229
Verberk MM, Rooyakkers-Beemster T, de Vlieger M, . 1979. Bromine in blood, EEG and transaminases in methyl bromide workers. Br J Ind Med 36:59–62.444442
Viner N. 1945. Methyl bromide poisoning: A new industrial hazard. Can Med Assoc J 53:43–45.20323488
Vivas A, Fox JD, Baquerizo Nole KL, . 2015. Cryo-induced thermal wounds: A human acute wound model. J Drugs Dermatol 14(7):734–738.
von Ehrenstein OS, Ling C, Cui X, . 2019. Prenatal and infant exposure to ambient pesticides and autism spectrum disorder in children: Population based case-control study. BMJ 364:l962. 10.1136/bmj.l962.30894343
Wang D, Yates SR, Ernst FF, . 1997. Methyl bromide emission reduction with field management practices. Environ Sci Technol 31(10):3017–3022.
Watrous RM. 1942. Methyl bromide: Local and mild systemic toxic effects. Ind Med 11:575–579.
Wester PW, Kroes R. 1988. Forestomach carcinogens: Pathway and relevance to man. Toxicol Pathol 16:165–171.
WHO. 1994. Health and safety guide no. 86: Methyl bromide. Geneva, Switzerland: World Health Organization. http://www.inchem.org/documents/hsg/hsg/hsg86_e.htm. May 31, 2019.
WHO. 1995. Methyl bromide. Environmental Health Criteria 166. Geneva, Switzerland: World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc166.htm. February 03, 2016.
WHO. 2009. Methyl bromide. International Chemical Safety Card 0109. World Health Organization and International Labor Organization. http://www.inchem.org/documents/icsc/icsc/eics0109.htm. May 31, 2019.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Wilson NH, Newton PE, Rahn M, . 2000. Methyl bromide 1-year dietary study in dogs. Food Chem Toxicol 38(1):115–124.10733319
Windholz M. 1983. Methyl bromide. In: The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 10th ed. Rathway, NJ: Merck & Co., Inc., 865.
WMO. 2011. Scientific assessment of ozone depletion: 2010. Executive summary. National Oceanic and Atmospheric Administration, National Aeronautics and Space Administration, United Nations Environment Programme, World Meteorological Organization, European Commission. https://ozone.unep.org/sites/default/files/2019-05/00-SAP-2010-Assement-report.pdf. December 2, 2019.
Wofford P, Segawa R, Schreider J, . 2014. Community air monitoring for pesticides. Part 3: Using health-based screening levels to evaluate results collected for a year. Environ Monit Assess 186:1355–1370. 10.1007/s10661-013-3394-x.24370859
Wong O, Brocker W, Davis HV, . 1984. Mortality of workers potentially exposed to organic and inorganic brominated chemicals, DBCP, TRIS, PBB, and DDT. Br J Ind Med 41(1):15–24. 10.1136/oem.41.1.15.6318800
Wyers H. 1945. Methyl bromide intoxication. Br J Ind Med 30:24–29.
Yamamoto O, Hori H, Tanaka I, . 2000. Experimental exposure of rat skin to methyl bromide: A toxicokinetic and histopathological study. Arch Toxicol 73(12):641–648.
Yamano Y, Nakadate T. 2006. Three occupationally exposed cases of severe methyl bromide poisoning: Accident caused by a gas leak during the fumigation of a folklore museum. J Occup Health 48(2):129–133.16612042
Yamano Y, Kagawa J, Ishizu S, . 2001. Three cases of acute methyl bromide poisoning in a seedling farm family. Ind Health 39(4):353–358.11759000
Yamano Y, Tokutake T, Ishizu S, . 2011. Occupational exposure in methyl bromide manufacturing workers: 17-year follow-up study of urinary bromide ion concentration for biological monitoring. Ind Health 49(1):133–138.20823625
Yates SR, Gan J, Papiernik SK. 2003. Environmental fate of methyl bromide as a soil fumigant. Rev Environ Contam Toxicol 177:45–122.12666818
Yates SR, Wang D, Ernst FF, . 1997. Methyl bromide emissions from agricultural fields: Bare-soil, deep injection. Environ Sci Technol 31(4):1136–1143.
Youngentob SL, Schwob JE. 2006. Odorant identification and quality perception following methyl bromide-induced lesions of the olfactory epithelium. Behav Neurosci 120(6):1346–1355. 10.1037/0735-7044.120.6.1346.17201480
Yvon SA, Butler JH. 1996. An improved estimate of the oceanic lifetime of atmospheric CH3Br. Geophys Res Lett 23(1):53–56.
Zwaveling JH, de Kort WLAM, Meulenbelt J, . 1987. Exposure of the skin to methyl bromide: A study of six cases occupationally exposed to high concentrations during fumigation. Hum Toxicol 6:491–495.2961680