# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding bromomethane in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

Table 7-1 Regulations and Guidelines Applicable to Bromomethane

Agency | Description | Information | Reference
Air
EPA | RfC | 5×10^−3^ mg/m^3a^ | IRIS 2002
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018b
EPA | 1-Day health advisory (10-kg child) | 0.1 mg/L
EPA | 10-Day health advisory (10-kg child) | 0.1 mg/L
EPA | DWEL | 0.05 mg/L
EPA | Lifetime health advisory | 0.01 mg/L
EPA | 10^−4^ Cancer risk | No data
EPA | National primary drinking water regulations | Not listed | EPA 2009
EPA | RfD | 1.4×10^−3^ mg/kg/day^b^ | IRIS 2002
WHO | Drinking water quality guidelines | No data | WHO 2017
FDA | Substances Added to Food | Not listed^c^ | FDA 2018
Cancer
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Carcinogenicity classification | Group D^d^ | IRIS 2002
IARC | Carcinogenicity classification | Group 3^e^ | IARC 1999
Occupational
OSHA | Ceiling^f^ PEL for general industry, shipyards and construction | 20 ppm^g^ | OSHA 2018a, 2018b, 2018c
NIOSH | REL (up to 10-hour TWA) | None established^h^ | NIOSH 2018
NIOSH | IDLH | 250 ppm | NIOSH 1994
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2016f
| AEGL-1^i^
| 10-minute | NR^j^
| 30-minute | NR^j^
| 60-minute | NR^j^
| 4-hour | NR^j^
| 8-hour | NR^j^
| AEGL-2^i^
| 10-minute | 940 ppm
| 30-minute | 380 ppm
| 60-minute | 210 ppm
| 4-hour | 67 ppm
| 8-hour | 67 ppm
| AEGL-3^i^
| 10-minute | 3,300 ppm
| 30-minute | 1,300 ppm
| 60-minute | 740 ppm
| 4-hour | 230 ppm
| 8-hour | 130 ppm
DOE | PACs-air | | DOE 2018b
DOE | PAC-1^k^ | 19 ppm
DOE | PAC-2^k^ | 210 ppm
DOE | PAC-3^k^ | 740 ppm

a The RfC is based on a LOAEL(HEC) of 0.48 mg/m^3^ for degenerative and proliferative lesions of the olfactory epithelium of the nasal cavity in rats.

b The RfD is based on a NOAEL of 1.4 mg/kg/day for epithelial hyperplasia of the forestomach in rats.

c The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS.”

d Group D: not classifiable as to human carcinogenicity.

e Group 3: not classifiable as to its carcinogenicity to humans.

f An employee’s exposure will at no time exceed the exposure limit given for that substance. If instantaneous monitoring is not feasible, then the ceiling will be assessed as a 15-minute TWA exposure, which will not be exceeded at any time over a working day.

g Skin designation.

h Potential occupational carcinogen.

i Definitions of AEGL terminology are available from EPA (2018c).

j NR: not recommended due to insufficient data.

k Definitions of PAC terminology are available from U.S. DOE (2018a).

AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association; GRAS = generally recognized as safe; HEC = human equivalent concentration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint Expert Committee on Food Additives; LOAEL = lowest-observed-adverse-effect level; NIOSH = National Institute for Occupational Safety and Health; NOAEL = no-observed-adverse-effect level; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization