# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Table 4-1 lists common synonyms, trade names, and other pertinent identification information for bromomethane.

Table 4-1 Chemical Identity of Bromomethane

Characteristic | Information | Reference
Chemical name | Bromomethane | Windholz 1983
Synonym(s) and registered trade name(s) | Methyl bromide; monobromomethane; methyl fume; Embafume; Terabol | EPA 1986b; IRIS 2002
Chemical formula | CH_3_Br | Windholz 1983
Chemical structure | [image] | Windholz 1983
CAS Registry Number | 74-83-9 | Sax and Lewis 1987

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 4-2 Physical and Chemical Properties of Bromomethane

Property | Information | Reference
Molecular weight | 94.94 | HSDB 2014
Color | Colorless | HSDB 2014
Physical state | Gas | HSDB 2014
Melting point | −93.68°C | HSDB 2014
Boiling point | 3.5°C | HSDB 2014
Density at 20°C^a^ | 3.97 at 20°C (gas); 1.73 at 0°C (liquid) | HSDB 2014
Odor | Usually odorless; sweetish chloroform-like odor at high concentrations | HSDB 2014
Odor threshold:
Water | No data
Air | 80 mg/m^3^ (20 ppm) | Ruth 1986
Solubility:
Water at 20°C | 15.2 g/L at 25°C; 18.5 g/L at 20°C; 13.4 g/L at 25°C | HSDB 2014
Organic solvents | Readily soluble in lower alcohols, ethers, esters, ketones, halogenated hydrocarbons, aromatic hydrocarbons, and carbon disulfide; freely soluble in benzene, carbon tetrachloride, and carbon disulfide; miscible in ethanol and chloroform | HSDB 2014
Partition coefficients:
Log K_ow_ | 1.19 | HSDB 2014
Log K_oc_ | 0.95–1.3 | Yates et al. 2003
Vapor pressure at 20°C | 1,420 mmHg | HSDB 2014
Henry’s law constant at 25°C | 0.00734 atm m^3^/mole | HSDB 2014
Autoignition temperature | Nonflammable | EPA 1986b
Flashpoint | Nonflammable | EPA 1986b
Flammability limits | Nonflammable | EPA 1986b
Conversion factors^b^ | 1 ppm=3.88 mg/m^3^; 1 mg/m^3^=0.26 ppm
Explosive limits | Nonflammable | EPA 1986b

a Density of vapor relative to air.

b Based on the following formulas: ppm = (mg/m^3^) (24.45)/ (molecular weight), and mg/m^3^ = (ppm) (molecular weight)/ 24.45.