# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromomethane
CAS Numbers: | 74-83-9
Date: | March 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: Neurological and respiratory systems are the primary targets of acute inhalation of bromomethane in humans. Studies in laboratory animals identify several organ systems (respiratory tract, cardiovascular system, liver, kidneys, immunological system, reproductive system, neurological system, and the developing fetus) as targets of acute exposure to inhaled bromomethane, with neurotoxicity identified as the most sensitive effect. A 2-week study in mice identified neurological effects at an exposure level of 12 ppm (NTP 1992). However, there is considerable uncertainty associated with classifying this concentration as a LOAEL. NTP (1992) reported that “neurological signs including trembling, jumpiness, and paralysis were observed in all groups but were most pronounced in the three highest dose groups (50, 100, 200 ppm).” However, the NTP report did not include incidence data for these effects and it is unclear whether any or all of the effects were observed at the lowest concentration tested (12 ppm). At this time, the database is not considered suitable for identifying a point of departure (POD) for derivation of an acute-duration inhalation MRL because of the uncertainty in establishing the NOAEL and/or LOAEL values in the NTP (1992) study based on the information provided in the study report.

Agency Contacts (Chemical Managers): Sam Keith

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromomethane
CAS Numbers: | 74-83-9
Date: | March 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.02 ppm
Critical Effect: | Decreased locomotor activity
Reference: | NTP 1992
Point of Departure: | LOAEL_[HEC]_ of 1.8 ppm
Uncertainty Factor: | 90
LSE Graph Key: | 41
Species: | Mouse

MRL Summary: The intermediate-duration inhalation MRL for bromomethane was derived based on neurobehavioral effects (temporary decreased locomotor activity in male mice) observed at the 6-month (but not at the 0-, 3-, 9-, 12-, 15-, 18-, 21-, or 24-month) evaluation period of a 2-year cancer bioassay (NTP 1992). In this study, various neurological effects were sporadically observed in male and female mice, but effects did not exhibit temporal- or exposure-related dependence. The MRL of 0.02 ppm was derived from a minimal LOAEL of 10 ppm, adjusted for intermittent exposure, converted to a human equivalent concentration [HEC] of 1.8 ppm, and divided by a total uncertainty factor of 90 (3 for the use of a minimal LOAEL, 3 for extrapolation from animals to humans with dosimetric adjustments, and 10 for human variability).

Selection of the Principal Study: The NTP (1992) study in rats and mice was selected as the principal study for deriving the intermediate-duration inhalation MRL because this study identified the lowest LOAEL value for neurological effects. The study conducted extensive evaluations of neurobehavioral and neurological endpoints using functional observational battery (FOB) testing at numerous intermittent exposure durations and exposure levels. In addition, the study evaluated comprehensive toxicological endpoints.

Selection of the Critical Effect: The MRL was based on a minimal LOAEL of 10 ppm for decreased locomotor activity in male mice. The 10 ppm concentration was considered a minimal LOAEL because of the small magnitude of change (16%) in locomotor activity.

Alterations in performance on neurobehavioral tests were observed in rats and mice throughout the exposure period. However, statistically significant alterations in neurobehavioral effects were not observed at all time points (see Table A-1 for an overview of the statistically significant alterations). The earliest effect was an increased startle response latency in male rats exposed to 120 ppm for 3 weeks and the lowest LOAEL was 10 ppm for decreased locomotor activity in male mice and altered exploratory behavior (decreased novel side crossings and decreased novel side duration) in female mice exposed for 6 months. It is noted that the decreases in locomotor activity were not statistically significant at 9 months, but were significant at ≥10 ppm in female mice exposed for 12 months. There is extensive evidence in humans and laboratory animals that the nervous system in general and motor function specifically is a sensitive target of bromomethane toxicity. Ataxia has been reported in some severe cases of bromomethane poisoning in humans (Balagopal et al. 2011; Behrens and Dukes 1986). Ataxia, gait disturbances, paralysis, and limb crossing and twitching have been observed in laboratory animals exposed to lethal concentrations (Alexeeff et al. 1985; EPA 1988a; Eustis et al. 1988; Hurtt et al. 1987; NTP 1992). Cerebellar and cerebral degeneration or necrosis have also been observed in rats and mice exposed to ≥100 ppm (Eustis et al. 1988; Kato et al. 1986; NTP 1992).

Although the alterations were not observed at all time points, the decrease in locomotor activity observed in male and female mice exposed for 6 months was selected as the critical effect for the MRL.

Table A-1 Alterations in Performance on Neurobehavioral Tests in Rats and Mice Exposed to Inhaled Bromomethane for Intermediate Durations^a^

Test and exposure duration | Male rats | Female rats | Male mice | Female mice
Startle response latency
3 weeks | — | 120 ppm ↑ | No assessment | No assessment
6 weeks | — | —
9 weeks | — | — | No assessment | No assessment
12 weeks | | 120 ppm ↑
3 months | Not evaluated | Not evaluated | 100 ppm ↓ | 100 ppm ↑
6 months | Not evaluated | Not evaluated | — | —
9 months | Not evaluated | Not evaluated | — | —
Startle response amplitude
3 weeks | — | — | No assessment | No assessment
6 weeks | 60 ppm ↓; 120 ppm ↓ | — | — | —
9 weeks | — | — | No assessment | No assessment
12 weeks | — | 120 ppm ↓ | — | —
3 months | Not evaluated | Not evaluated | 100 ppm ↑ | 100 ppm ↑
6 months | Not evaluated | Not evaluated | — | —
9 months | Not evaluated | Not evaluated | — | —
Activity latency
3 weeks | — | — | No assessment | No assessment
6 weeks | — | — | 80 ppm ↑ | —
9 weeks | — | — | No assessment | No assessment
12 weeks | — | — | — | 80 ppm ↓
3 months | Not evaluated | Not evaluated | 100 ppm ↑ | —
6 months | Not evaluated | Not evaluated | — | —
9 months | Not evaluated | Not evaluated | — | —
Novel side time
3 weeks | — | — | No assessment | No assessment
6 weeks | — | — | — | —
9 weeks | — | — | No assessment | No assessment
12 weeks | — | — | — | —
3 months | Not evaluated | Not evaluated | 100 ppm ↓ | 100 ppm ↑
6 months | Not evaluated | Not evaluated | — | 10 ppm ↓; 33 ppm ↓; 100 ppm ↑
9 months | Not evaluated | Not evaluated | — | —
Novel side crossings
3 weeks | — | — | No assessment | No assessment
6 weeks | — | — | — | —
9 weeks | — | — | No assessment | No assessment
12 weeks | 120 ppm ↑ | | — | —
3 months | Not evaluated | Not evaluated | 100 ppm ↓
6 months | Not evaluated | Not evaluated | — | 10 ppm ↓; 33 ppm ↓; 100 ppm ↑
9 months | Not evaluated | Not evaluated | — | —
Locomotor activity
3 weeks | — | — | No assessment | No assessment
6 weeks | — | — | — | —
9 weeks | — | — | No assessment | No assessment
12 weeks | — | — | — | —
3 months | Not evaluated | Not evaluated | 100 ppm ↓ | —
6 months | Not evaluated | Not evaluated | 10 ppm ↓; 33 ppm ↓ | 33 ppm ↓; 100 ppm ↓
9 months | Not evaluated | Not evaluated | — | —
Hindlimb foot splay
3 weeks | — | — | No assessment | No assessment
6 weeks | — | — | — | —
9 weeks | — | — | No assessment | No assessment
12 weeks | — | 120 ppm ↓ | — | —
3 months | Not evaluated | Not evaluated | — | —
6 months | Not evaluated | Not evaluated | — | —
9 months | Not evaluated | Not evaluated | — | —
Hindlimb grip strength
3 weeks | — | — | No assessment | No assessment
6 weeks | 120 ppm ↓ | — | — | —
9 weeks | — | — | No assessment | No assessment
12 weeks | — | — | — | —
3 months | Not evaluated | Not evaluated | 100 ppm ↑ | 100 ppm ↑
6 months | Not evaluated | Not evaluated | — | —
9 months | Not evaluated | Not evaluated | 33 ppm ↓ | —
Forelimb grip strength
3 weeks | — | — | No assessment | No assessment
6 weeks | — | — | — | —
9 weeks | — | — | No assessment | No assessment
12 weeks | — | 120 ppm ↓ | — | —
3 months | Not evaluated | Not evaluated | — | —
6 months | Not evaluated | Not evaluated | — | —
9 months | Not evaluated | Not evaluated | — | —
Hot plate latency
3 weeks | — | — | No assessment | No assessment
6 weeks | — | — | 80 ppm ↑ | —
9 weeks | — | — | No assessment | No assessment
12 weeks | — | — | — | —
3 months | Not evaluated | Not evaluated | — | 100 ppm ↑
6 months | Not evaluated | Not evaluated | — | —
9 months | Not evaluated | Not evaluated | — | —

— = no significant alterations; ↓ = decreased response; ↑ = increased response

a See Table A-2 for magnitude of the alteration.

Source: NTP 1992

Selection of the Principal Study: The NTP (1992) study was selected as the principal study for deriving an intermediate-duration inhalation MRL for bromomethane because it identified the lowest reliable LOAEL for acute effects.

Summary of the Principal Study:

NTP. 1992. Toxicology and carcinogenesis studies of methyl bromide (CAS No. 74-83-9) in B6C3F1 mice (inhalation studies). National Toxicology Program. Technical report series No. 385. http://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr385.pdf. May 27, 2015

NTP (1992) conducted the following series of studies: (1) groups of 10 male and 10 female B6C3F1 mice exposed to 0, 10, 20, 40, 80, or 120 ppm, 6 hours/day, 5 days/week for 13 weeks; (2) groups of 10 male and 10 female F344/N rats exposed to 0, 30, 60, or 120 ppm, 6 hours/day, 5 days/week for 13 weeks; (3) groups of 8 male and 8 female F344/N rats exposed to 0, 30, 60, or 120 ppm, 6 hours/day, 5 days/week for 13 weeks; (4) groups of 8 male and 8 female B6C3F1 mice exposed to 0, 20, 40, or 80 ppm, 5 days/week for 13 weeks; (5) interim neurobehavioral and histopathological assessments (conducted at 3, 6, and 9 months) in groups of 6–13 male and 6–16 female B6C3F1 mice exposed to 0, 10, 33, and 100 ppm bromomethane for 6 hours/day, 5 days/week as part of a 2-year cancer bioassay, and (6) groups of 15 male and female B6C3F1 mice exposed to 0 or 160 ppm, 6 hours/day, 5 days/week for up to 6 weeks (the data for this study are reported in detail in Eustis et al. 1988). In the 13-week studies involving eight animals/sex/species, neurobehavioral assessment were conducted at weeks 3 (rats only), 6, 9, 12 (rats only), and 13 (mice only). Other evaluations at the end of the 13-week treatment period (10 animals/sex/species) included body weight, hematology, clinical chemistry, organ weights, and histopathology of comprehensive tissues. In the 6-week study, histopathology of selected tissues, including brain, was assessed at the end of the treatment period, which was the duration in which mortality was >50% (14 exposures for male rats, 30 exposures female rats, 8 exposures in male mice, and 14 exposures in female mice). In the 2-year cancer bioassay, neurobehavioral effects were evaluated at 3, 6, and 9 months, and histopathology of comprehensive tissues was conducted at 6 months.

Adverse neurological effects of inhaled bromomethane and LOAEL values, with associated NOAELs, for each exposure level and assessment time-point are summarized in Table A-2. Neurobehavioral effects were observed in mice throughout the 6-week to 6-month assessment period. The study authors classified the severity of neurobehavioral effects as mild. In rats, neurobehavioral effects were observed at 3, 6, and 12 weeks, but not at 9 weeks. The study authors classified the severity of neurobehavioral effects as minor. Microscopic evaluation of brain tissues showed neuronal necrosis of the cerebral cortex (mice and rats), cerebellum (mice), and thalamus (rats) following 6 weeks of exposure to 160 ppm. However, no histopathological changes to the brain were observed in mice and rats exposed to ≤120 ppm for 13 weeks. Comparison of LOAEL values for rats and mice in the 6-week exposure study with exposure concentrations up to 120 ppm suggests that mice are more sensitive than rats; the NOAEL and LOAEL values for neurological effects were 80 and 120 ppm in rats, respectively, and 40 and 60 ppm in mice, respectively.

In addition to neurological effects, decreased body weight and histopathological alterations in several tissue types were observed. In rats and mice exposed to 160 ppm for up to 6 weeks (exposures levels that produced substantial mortality), histopathological changes were observed in the nasal cavity, heart, spleen, liver, adrenal glands, and testes. Decreased body weight gain was observed in male and female mice and rats exposed to 160 ppm for up to 6 weeks and to 120 ppm for 13 weeks. In female rats exposed for 13 weeks, decreased erythrocyte count was observed at 60 and 120 ppm, and decreased hematocrit and hemoglobin were observed at 120 ppm (NTP 1992). Additional details on non-neurological adverse effects reported in NTP (1992) are provided in Table 2-1 in Chapter 2.

Table A-2 Neurological Effects Observed in Mice and Rats Exposed to Inhaled Bromomethane for Intermediate-Duration Exposures

Time of observation | Effects in rats | Effects in mice
13-Week exposure study (6 hours/day, 5 days/week)
3 Weeks; 0, 30, 60, or 120 ppm | No death at any exposure | No assessment in mice
3 Weeks; 0, 30, 60, or 120 ppm | 60 ppm: decreased startle response amplitude (males; 15%; p≤0.05)
3 Weeks; 0, 30, 60, or 120 ppm | 120 ppm: decreased startle response amplitude (males; 28%; p≤0.01); increased startle response latency (females; 12%; p≤0.05)
3 Weeks; 0, 30, 60, or 120 ppm | NOAEL/LOAEL: 30 ppm/60 ppm
6 Weeks; Mice: 0, 20, 40, 80, or 120 ppm; Rats: 0, 30, 60, or 120 ppm | No death at any exposure | No death at any exposure
6 Weeks; Mice: 0, 20, 40, 80, or 120 ppm; Rats: 0, 30, 60, or 120 ppm | 120 ppm: decreased hindlimb strength (males: 32%; p≤0.05); NOAEL/LOAEL: 80 ppm/120 ppm | 80 ppm: increased activity latency (males: 156%, p≤0.01); increased hot plate latency (males: 80%, p≤0.05); 120 ppm: severe curling and crossing of the hindlimbs and twitching of the forelimbs; NOAEL/LOAEL: 40 ppm/80 ppm
9 Weeks; 0, 30, 60, or 120 ppm | No death at any exposure | No assessment in mice
9 Weeks; 0, 30, 60, or 120 ppm | No neurobehavioral effects observed (increased hot plate latency in females at 120 ppm was <0.5% and was not considered toxicologically relevant)
9 Weeks; 0, 30, 60, or 120 ppm | NOAEL/LOAEL: 120 ppm/X
12 Weeks (rats), 13 weeks (mice); Mice: 0, 10, 20, 40, 80, or 120 ppm; Rats: 0, 30, 60, or 120 ppm | No death at any exposure | No death at any exposure
12 Weeks (rats), 13 weeks (mice); Mice: 0, 10, 20, 40, 80, or 120 ppm; Rats: 0, 30, 60, or 120 ppm | 120 ppm: increased novel side crossing frequency (males: 480%; p≤0.05); decreased hindlimb foot splay (females: 20%; p≤0.05); decreased forelimb grip strength (females: 25%; p≤0.05); increased startle response latency (females: 17%; p≤0.05); decreased startle response amplitude (females: 22%, p≤0.05); NOAEL/LOAEL: 80 ppm/120 ppm | 80 ppm: decreased activity latency (females 76%, p<0.05); 120 ppm: severe curling and crossing of hindlimbs and twitching of forelimbs; NOAEL/LOAEL: 80 ppm/120 ppm
6-Week exposure study (6 hours/day, 5 days/week) (detailed report of this study is presented in Eustis et al. 1988)
Rats and mice: 0 or 160 ppm | Substantial mortality was observed in both sexes^a^. | Substantial mortality was observed in both sexes^a^
Male rats and male mice were sacrificed after 14 exposures due to high mortality; female mice were sacrificed after 8 exposures | Lethargy and neurological signs (curling and crossing of the hindlimbs, forelimb twitching and tremors); the study authors noted that severity was less than in mice; Neuronal necrosis of cerebral cortex (males and females) and thalamus (females); NOAEL/LOAEL: not applicable (serious LOAEL at 160 ppm) | Lethargy and neurological signs (curling and crossing of the hindlimbs, forelimb twitching and tremors); Neuronal necrosis of cerebral cortex (males) and cerebellum (males and females); NOAEL/LOAEL: not applicable (serious LOAEL at 160 ppm)
24-Month exposure study (6 hours/day, 5 days/week)
3 Months; 0, 10, 33, or 100 ppm | – | 10 ppm: no mortality
3 Months; 0, 10, 33, or 100 ppm | – | 33 ppm: no mortality
3 Months; 0, 10, 33, or 100 ppm | – | 100 ppm: 10/86 deaths in males; 1/86 deaths in females; decreased startle response latency (males: 32%, p<0.01; females; 38%, p<0.01); increases startle response amplitude (males: 62%, p<0.01; females: 66%, p<0.01); increased activity latency (males: 370%; p<0.01); decreased novel side time (males: 44%, p<0.05); increased novel side time (females: 19%, p<0.05), decreased novel side crossing (males: 67%, p<0.01); decreased locomotor activity (males: 39%; p<0.01); increased hind limb grip strength (males: 30%, p<0.05; females: 32%, p<0.01); increased hot plate latency (females: 39%; p<0.01)
3 Months; 0, 10, 33, or 100 ppm | – | NOAEL/LOAEL: 33ppm/100ppm
6 Months; 0, 10, 33, or 100 ppm | – | 10 ppm: 1/86 deaths in males; no deaths in females; decreased novel side crossings (females: 37%, p<0.05); decreased locomotor activity (males: 16%, p<0.01; females: 10%, p<0.05)
6 Months; 0, 10, 33, or 100 ppm | – | 33 ppm: no mortality; decreased novel side crossings (females: 28%, p<0.05); deceased locomotor activity (males: 14%, p≤0.01; females: 11%, p≤0.05)
6 Months; 0, 10, 33, or 100 ppm | – | 100 ppm: 45/86 deaths in males; 14/86 deaths in females; increased novel side crossings (females: 31%, p≤0.01), decreased novel side crossings (females: 55%, p≤0.01); deceased locomotor activity (females: 28%, p≤0.01) (no assessment in males due to excessive mortality)
6 Months; 0, 10, 33, or 100 ppm | – | NOAEL/LOAEL: X/10 ppm
9 Months; 0, 10, 33, or 100 ppm | – | Control: 18/86 deaths in males; 23/85 deaths in females
9 Months; 0, 10, 33, or 100 ppm | – | 10 ppm: 22/85 deaths in males; 18/86 deaths in females
9 Months; 0, 10, 33, or 100 ppm | – | 33 ppm: 18/85 deaths in males; 18/86 deaths in females decreased hindlimb grip strength (males: 21%, p≤0.01)
9 Months; 0, 10, 33, or 100 ppm | – | 100 ppm: 55/86 deaths in males; 22/86 deaths in females; no assessment due to excessive mortality (males)
9 Months; 0, 10, 33, or 100 ppm | – | NOAEL/LOAEL: 10 ppm/33 ppm

a Incidence data for mortality were not reported.

LOAEL = lowest observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; × = NOAEL or LOAEL value not identified

Source: NTP 1992

Selection of the Point of Departure for the MRL: In selecting the POD for derivation of the intermediate-duration inhalation MRL, an important consideration is that death was observed in rats continuously exposed to 10 ppm bromomethane for 3 weeks; no mortality was observed at 0, 1, or 5 ppm (Sato et al. 1985). Therefore, adverse effects associated with LOAEL_adj_ values >5 ppm (adjusted for intermittent exposure) were not considered as the basis of the intermediate-duration inhalation MRL. The LOAEL_adj_ value of 1.8 ppm for decreased locomotor activity in mice (a NOAEL value was not identified) is the only LOAELadj value ≤5 ppm (NTP 1992); therefore, this was selected as the critical effect.

To determine the POD for derivation of the intermediate-duration inhalation MRL, data sets for decreased locomotor activity in male and female mice (summarized in Table A-3) were analyzed by continuous variable models in the EPA Benchmark Dose Software (BMDS, version 3.1.1). The benchmark response (BMR) for continuous models is defined as a change equal to 1 standard deviation (SD) from the control mean. Adequate model fit is judged by three criteria: goodness-of-fit (p>0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMCL (the lower limit of a one-sided 95% CI on the BMC) is selected as a reasonably conservative POD when differences between the BMCLs estimated from these models are >3-fold; otherwise, the BMCL from the model with the lowest Akaike’s information criterion (AIC) is chosen.

For male and female mice, none of the BMC models provided adequate fit to the locomotor activity data. Therefore, the minimal LOAEL of 10 ppm in male mice was selected as the POD for derivation of the intermediate-duration inhalation MRL.

Table A-3 Decreased Locomotor Activity in Male and Female Mice Exposed to Inhaled Bromomethane for 6 Months

Exposure level (ppm) | Number | Mean activity (in instrument units) | SE | SD
Male mice
0 | 13 | 184 | 4.3 | 15.5
10 | 16 | 155^a^ | 10.8 | 43.2
33 | 16 | 158^a^ | 4.2 | 16.8
100 | X | X | X | X
Female mice
0 | 12 | 187 | 3.5 | 12.1
10 | 15 | 168^b^ | 5.0 | 19.4
33 | 16 | 166^b^ | 8.5 | 34
100 | 10 | 135 | 9.5 | 30

a p≤0.01.

b p≤0.05.

SD = standard deviation; SE = standard error; X = due to significant mortality in male mice, neurobehavioral assessments were not conducted

Source: NTP 1992

Calculations

Intermittent Exposure: The LOAEL of 10 ppm identified in male mice was adjusted for intermediate exposure:

LOAEL_adj_ = [ ( LOAEL of 10ppm ) ( 6 hours / 24 hours ) ( 5 days / 7 days ) = 1.8 ppm

Human Equivalent Concentration: The HEC for mice for extrathoracic effects (RGDR_ET_) was calculated by multiplying the LOAEL_adj_ by the regional gas dose ratio (RGDR) for extrarespiratory effects. In the absence of available blood:gas partition coefficients for humans and mice, the default ratio for the RGDR_ET_ of 1 was used:

LOAEL_adj_ × RGDR = LOAEL_HEC_ 1.8 ppm × 1 = 1.8 ppm

Uncertainty Factor: The total uncertainty factor was 90 (3 for the use of a minimal LOAEL, 3 for extrapolation from animals to humans with dosimetric adjustments, and 10 for human variability):

LOAEL_adjHEC_ / total uncertainty factor = intermediate-duration inhalation MRL 1.8 ppm / 90 = 0.02 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Specific information regarding effects of intermediate-duration inhalation exposure of humans is limited to a case report of two workers; no exposure data were reported (O’Malley et al. 2011). Signs and symptoms of neurotoxicity (difficulty with concentration and memory, dizziness, visual disturbances, difficulty with speech, ataxia, and abnormal gait) were reported. Although available data on intermediate-duration exposure of humans is limited, it is well established that exposure to inhaled bromomethane is neurotoxic to humans (Bulathsinghala and Shaw 2014; de Souza et al. 2013).

Several animal studies have evaluated the effects of intermediate-duration inhalation exposure to bromomethane. Results show that bromomethane affects several organ systems, with adverse effects observed in the respiratory tract (Eustis et al. 1988; Irish et al. 1940; Kato et al. 1986; NTP 1992), heart (Eustis et al. 1988; Kato et al. 1986), liver (Eustis et al. 1988; Kato et al. 1986), immunological system (Eustis et al. 1988), nervous system (EPA 1988a; Eustis et al. 1988; Honma et al. 1982; Ikeda et al. 1980; Irish et al. 1940; Kato et al. 1986; NTP 1992), reproductive system (EPA 1988a; Eustis et al. 1988), and the developing fetus (Mayhew et al. 1986, as cited in EPA 1986a; Kato et al. 1986). The lowest effect levels adjusted for intermittent exposure (LOAEL_adj_) identified for each outcome were 10 ppm for pulmonary hemorrhage (Sato et al. 1985), 17.9 ppm for focal fibrosis of the heart (Kato et al. 1986), 28.6 ppm for thymus inflammation and atrophy (Eustis et al. 1988), 1.79 ppm for decreased locomotor activity (NTP 1992), 21.4 ppm for decreased sperm density (EPA 1984), and 5.36 ppm for decreased pup weight (Mayhew et al. 1986, as cited in EPA 1986a).

Numerous studies in laboratory animals support identifying the nervous system as a critical target of toxicity. Overt signs of neurological effects have been observed in animals, including paralysis, tremors, and curling and crossing of limb in monkeys exposed to ≥66 ppm (Irish et al. 1940), rats exposed to 300 ppm (Kato et al. 1986), mice exposed to ≥80 ppm (EPA 1988a), and rabbits exposed to ≥33 ppm (Irish et al. 1940). A dog study reported that during a neurological examination, one dog appeared depressed and one dog was unresponsive and motionless (EPA 2001b). Both dogs were exposed to 5.3 ppm 7 hours/day, 5 days/week for 7 weeks; these symptoms were not observed in the remaining six dogs in this group. The investigators considered the significance of this finding as unclear. However, in a subsequent study, no overt signs of neurotoxicity were observed in eight dogs exposed to 5.3 ppm (EPA 2002); alterations in proprioceptive placing were sporadically observed in dogs exposed to 10 or 20 ppm.

Although there is some uncertainty regarding the toxicological significance of the findings in the two dogs exposed to 5.3 ppm for 7 weeks (EPA 2001b), the findings were not confirmed in a subsequent 6-week dog study (EPA 2002) and the MRL is 250 times lower than this exposure concentration and is likely to be protective of the effect.

Agency Contacts (Chemical Managers): Sam Keith

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromomethane
CAS Numbers: | 74-83-9
Date: | 74-83-9
Profile Status: | March 2020
Route: | Inhalation
Duration: | Chronic
MRL: | 0.001 ppm
Critical Effect: | Respiratory effects (basal cell hyperplasia of the olfactory epithelium)
Reference: | Reuzel et al. 1991
Point of Departure: | LOAEL_(HEC)_ of 0.110 ppm
Uncertainty Factor: | 90
LSE Graph Key: | 50
Species: | Rat

MRL Summary: The chronic-duration inhalation MRL for bromomethane was derived from a minimal LOAEL value of 3.1 ppm (adjusted for intermittent exposure and converted to a LOAEL(_HEC_) of 0.108 ppm) for basal cell hyperplasia of the olfactory epithelium. A total uncertainty factor of 90 was applied (3 for use of a minimal LOAEL, 3 for extrapolation from animals to humans with dosimetric adjustments, and 10 for human variability).

Selection of the Critical Effect: The most sensitive effects of chronic exposure of animals to inhaled bromomethane are lesions of the respiratory epithelium in male and female rats (Reuzel et al. 1987, 1991) and mild neurotoxicity in female mice (NTP 1992). Basal cell hyperplasia of the olfactory epithelium was selected as the critical effect because the LOAEL_adj_ of 0.55 ppm (a NOAEL was not identified) for respiratory lesions is lower than the LOAEL_adj_ of 1.79 ppm (a NOAEL was not identified) for neurotoxicity reported by NTP (1992).

Selection of the Principal Study: The Reuzel et al. (1991) study was selected as the principal study because it reported the lowest LOAEL_adj_ value of 0.55 ppm (a NOAEL was not identified) for lesions of the olfactory epithelium in male and female rats. In addition, the study demonstrated exposure-related increases of hyperplasia of the olfactory epithelium in both male and female rats after 128 weeks of exposure. Severity of nasal lesions increased with exposure concentration and duration.

Summary of the Principal Study:

Reuzel PG, Dreef-van der Meulen HC, Hollanders VM, et al. 1991. Chronic inhalation toxicity and carcinogenicity study of methyl bromide in Wistar rats. Food Chem Toxicol 29(1):31-39. (Data also reported in Reuzel PG, Kuper CF, Dreef-Van Der Meulen HC, et al. 1987. Initial submission: Chronic (29-month) inhalation toxicity and carcinogenicity study of methyl bromide in rats with cover letter dated 081092. DuPont Chem Co. Submitted to the U.S. EPA under TSCA Section 8ECP. EPA Document No. 88-920008788.OTS0546338.)

Groups of 60 male and female Wistar rats were exposed to target concentrations of 0, 3, 60, or 90 ppm (actual concentrations were 3.1, 29.6, and 89.1 ppm) bromomethane for 6 hours/day, 5 days/week for 128 weeks (males) and 129 weeks (females). Animals were examined daily for clinical signs and mortality, and rats were weighed weekly for the first 12 weeks of the study, then monthly for the remainder of the study. Assessments for hematology, clinical chemistry, and urinalysis were conducted at weeks 12–14 and 52–53. Gross pathological examination was performed on all animals at the end of treatment or upon early death. At the end of the treatment period, organ weights were recorded for selected tissues and histopathological examination was conducted on comprehensive tissues.

Cumulative mortality was significantly increased in the 89.1 ppm group at exposure week 114 in male rats (36/60; p<0.05) and at exposure week 121 in female rats (38/50; p<0.05); significant increases were not observed at other time points. Body weights were also decreased throughout the study in males and females exposed to 89.1 ppm. No treatment-related effects were observed for hematology, clinical chemistry, or urinalysis. Significant, exposure-related histopathological changes were observed in the nasal cavity (basal cell hyperplasia of the olfactory epithelium) at all bromomethane concentrations tested, with changes classified as very slight or slight at 3.1 ppm, slight at 29.6 ppm, and slight to moderate at 89.1 ppm. Hyperkeratosis of the esophagus was observed in male rats in the 89.1 ppm group. Microscopic examination of the heart showed cartilaginous metaplasia in males, thrombi in males and females, and moderate to severe myocardial degeneration in females exposed to 89.1 ppm. The incidences of neoplastic lesions in treatment groups were similar to controls.

Selection of the Point of Departure for the MRL: The most sensitive effect identified in the Reuzel et al. (1991) study is nasal lesions (basal cell hyperplasia of the olfactory epithelium) in male and female rats, with a LOAEL of 3.1 ppm at the lowest concentration tested; data are summarized in Table A-4. To determine the POD to derive the chronic-duration inhalation MRL, incidence data were fit to all available dichotomous models in EPA’s BMDS (version 3.1.1) using the extra risk option. Adequate model fit is judged by three criteria: goodness-of-fit (p>0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMCL (the lower limit of a one-sided 95% CI on the BMC) is selected as a reasonably conservative POD when differences between the BMCLs estimated from these models are >3-fold; otherwise, the BMCL from the model with the lowest AIC is chosen (EPA 2012).

Table A-4 Incidence and Severity Data for Basal Cell Hyperplasia of the Olfactory Epithelium in Male and Female Rats Exposed to Inhaled Bromomethane for 29 Months

Exposure level (ppm) | Number of rats affected/number of rats examined | Severity (number of rats)
Male rats
0 | 4/46 | Very slight: 2; Slight: 2; Moderate: 0
3.1 | 13/48^a^ | Very slight: 9; Slight: 3; Moderate: 1
29.6 | 23/48^b^ | Very slight: 7; Slight: 12; Moderate: 4
89.1 | 31/48^b^ | Very slight: 8; Slight:14; Moderate: 9
Female rats
0 | 9/58 | Very slight: 7; Slight: 2; Moderate: 0
3.1 | 19/58^a^ | Very slight: 17; Slight: 2; Moderate: 0
29.6 | 25/59^a^ | Very slight: 13; Slight: 9; Moderate: 3
89.1 | 42/59^b^ | Very slight: 10; Slight: 23; Moderate: 9

a p≤0.05

b p≤0.01

Source: Reuzel et al. 1987, 1991

Only the LogLogistic model provided adequate fit to the incidence data for basal cell hyperplasia of the olfactory epithelium in male rats (BMC_10_ 5.81 ppm; BMCL_10_ 3.65 ppm) (Table A-5). The goodness of fit (p-value) was <0.1 for all other models. The selected model fit is shown in Figure A-1. For basal cell hyperplasia of the olfactory epithelium in female rats, dichotomous models provided adequate fit to the incidence data, except for the Hill and probit models (Table A-6). Using the criteria for model selection, the LogLogistic model (BMC_10_ 6.41 ppm; BMCL_10_ 4.13 ppm) was selected as the best fit model. The selected model fit is shown in Figure A-2. None of the models provided adequate fit for the combined male and female data sets.

Table A-5 Benchmark Dose Model (Version 3.1.1) Predictions for Bromomethane, Incidence of Basal Cell Hyperplasia of the Olfactory Epithelium in Male Rats Following Chronic Inhalation Exposure (Reuzel et al. 1991)

Model | DF | X^2^ | X^2^Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMC_10_ (ppm) | BMCL_10_ (ppm)
Model | DF | X^2^ | X^2^Goodness-of-fit p-value^a^ | Dose below BMC | Dose above BMC | Overall largest | AIC | BMC_10_ (ppm) | BMCL_10_ (ppm)
All doses
Gamma^c^ | 2 | 5.47 | 0.06 | 1.25 | 1.03 | −1.50 | 221.83 | ND-0.10 | ND-0.10
Hill | 1 | 0.11 | 0.74 | −0.02 | −0.12 | 0.17 | 218.22 | ND-10 | ND-10
Logistic | 2 | 8.65 | 0.01 | 0.73 | 1.71 | −2.11 | 225.61 | ND-0.10 | ND-0.10
LogLogistic^d,e^ | 2 | 3.56 | 0.17 | 1.35 | 0.29 | 1.35 | 219.68 | 5.67 | 3.56
LogProbit^d^ | 1 | 0.14 | 0.71 | −0.02 | 0.12 | −0.29 | 218.25 | ND-10 | ND-10
Multistage (1-degree)^f^ | 2 | 5.47 | 0.06 | 1.25 | 1.03 | −1.61 | 221.83 | ND-0.10 | ND-0.10
Multistage (2-degree)^f^ | 2 | 5.47 | 0.06 | 1.25 | 1.03 | −1.61 | 221.83 | ND-0.10 | ND-0.10
Multistage (3-degree)^f^ | 2 | 5.47 | 0.06 | 1.25 | 1.03 | −1.61 | 221.83 | ND-0.10 | ND-0.10
Probit | 2 | 8.48 | 0.01 | 1.78 | −2.08 | −2.08 | 225.31 | ND-0.10 | ND-0.10
Weibull^c^ | 2 | 5.47 | 0.06 | 1.25 | 1.03 | −1.50 | 221.83 | ND-0.10 | ND-0.10

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMC; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Selected model. The only model that provided adequate fit to the data was the Log-Logistic.

f Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk); DF = degrees of freedom; ND-0.10 = not determined, goodness-of-fit criteria, p<0.10; ND-10 = not determined, BMDL is 10-fold lower than the lowest non-zero dose; Hill model BMCL_10_ = 0.028; LobProbit model BMCL_10_ = 0.043

Figure A-1 Selected Model (LogLogistic) for Incidence of Basal Cell Hyperplasia of the Olfactory Epithelium in Male Rats Following Chronic Inhalation Exposure (Reuzel et al. 1991)

Figure A-1 description

Table A-6 Benchmark Dose Model (Version 3.1.1) Predictions for Bromomethane, Incidence of Basal Cell Hyperplasia of the Olfactory Epithelium in Female Rats Following Chronic Inhalation Exposure (Reuzel et al. 1991)

Model | DF | X^2^ | X^2^Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMC_10_ (ppm) | BMCL_10_ (ppm)
Model | DF | X^2^ | X^2^Goodness-of-fit p-value^a^ | Dose below BMC | Dose above BMC | Overall largest | AIC | BMC_10_ (ppm) | BMCL_10_ (ppm)
Gamma^c^ | 2 | 3.53 | 0.17 | 1.44 | −0.24 | 1.44 | 282.22 | 9.44 | 7.00
Hill | 1 | 3.16 | 0.07 | 0.83 | −1.31 | 0.83 | 283.86 | ND-0.10 | ND-0.10
Logistic | 2 | 4.24 | 0.12 | 1.22 | 0.48 | −1.57 | 283.12 | 15.94 | 13.01
LogLogistic ^d^ ^,^ ^e^ | 2 | 3.75 | 0.15 | 1.42 | −0.80 | 1.42 | 282.39 | 6.41 | 4.13
LogProbit^d^ | 1 | 3.40 | 0.06 | 1.48 | 0.20 | −1.56 | 284.11 | ND-0.10 | ND-0.10
Multistage (1-degree)^f^ | 2 | 3.53 | 0.17 | 1.44 | −0.24 | 1.44 | 282.22 | 9.44 | 7.00
Multistage (2-degree)^f^ | 2 | 3.53 | 0.17 | 1.44 | −0.24 | 1.44 | 282.22 | 9.44 | 7.00
Multistage (3-degree)^f^ | 2 | 3.53 | 0.17 | 1.44 | −0.24 | 1.44 | 282.22 | 9.44 | 7.00
Probit | 2 | 4.19 | 0.12 | 1.24 | 0.47 | −1.55 | 283.06 | 15.56 | 12.83
Weibullc | 2 | 3.53 | 0.17 | 1.44 | −0.24 | 1.44 | 282.22 | 9.44 | 7.00

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMC; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Selected model. All models provided adequate fit to the data. BMCLs for models providing adequate fit were not sufficiently close (differed by >2-3-fold). Therefore, the model with lowest BMCL was selected (Log-Logistic).

f Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure concentration associated with 10% extra risk); DF = degrees of freedom; ND-0.10= not determined, goodness-of-fit criteria, p<0.10

Figure A-2 Selected Model (LogLogistic) for Incidence of Basal Cell Hyperplasia of the Olfactory Epithelium in Female Rats Following Chronic Inhalation Exposure (Reuzel et al. 1991)

Figure A-2 description

The BMCL_10_ values of 3.56 and 4.13 ppm for olfactory epithelial basal cell hyperplasia in male and female rats, respectively, which are theoretical no-effect levels, are higher than the empirical LOAEL of 3.1 ppm, suggesting that the BMD models are not predictive of low-concentration effects. Therefore, to determine the POD for derivation of the chronic inhalation MRL, LOAEL_adj_ value for olfactory epithelial hyperplasia was converted to a HEC (LOAEL_HEC_) by multiplying the LOAEL_adj_ by the RGDR values for extrathoracic effects, as shown in Table A-7.

Table A-7 Possible PODs for the Chronic-Duration Inhalation MRL

Species | Exposure | Effect | LOAEL (ppm) | LOAEL_adj_ (ppm)^a^ | RGDR | LOAEL_HEC_ (ppm)^b^ | Reference
Male rats | 29 Months, 6 hours/day, 5 days/week | Basal cell hyperplasia of the olfactory epithelium | 3.1 | 0.55 | 0.280^c^ | 0.154 | Reuzel et al. 1991
Female rats | 29 Months, 6 hours/day, 5 days/week | Basal cell hyperplasia of the olfactory epithelium | 3.1 | 0.55 | 0.200^c^ | 0.110 | Reuzel et al. 1991

a Adjusted for intermittent exposure. See details below under Calculations.

b HEC: LOAEL_adj-HEC_ = (LOAEL_adj_)(RGDR). See details below under Calculations.

c RGDR for rats for extrathoracic respiratory effects (RGDR_ET_). See details below under Calculations.

HEC = human equivalent concentration; LOAEL = lowest observed-adverse-effect level; NOAEL = no-observedadverse-effect level; POD = point of departure; RGDR = regional gas dose ratio

Calculations

Intermittent Exposure: The LOAEL of 3.1 ppm in female rats was adjusted for intermittent exposure (6 hours/day, 5 days/week):

LOAEL_adj_ = [ ( LOAEL of 3.1 ppm ) ( 6 hours / 24 hours ) ( 5 days / 7 days ) = 0.55 ppm

Human Equivalent Concentration: The RGDR for rats for extrathoracic respiratory effects (RGDR_ET_) was calculated using the following equation (EPA 1994b):

R G D R_E T_ = (( (V_E_)/(S A_E T_) )_R a t_)/(( (V_E_)/(S A_E T_) )_H u m a n_)

where V_E_ is the ventilation rate (m^3^/day; humans: 20; male Wistar rats: 0.42; female Wistar rats: 0.30; EPA 1988b), and SA_ET_ is surface are of the extrathoracic region of the respiratory tract (cm^2^; humans: 200; male and female rats: 15) (EPA 1994b).

LOAEL_adj_ × RGDR = LOAEL_HEC_ 0.55 ppm × 0.20 = 0.110 ppm

Uncertainty Factor: The total uncertainty factor was 90 (3 for the use of a minimal LOAEL, 3 for extrapolation from animals to humans with dosimetric adjustments, and 10 for human variability):

LOAEL_adjHEC_ / total uncertainty factor = Chronic-duration inhalation MRL 0.11 ppm / 90 = 0.001 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Information regarding effects of chronic-duration inhalation exposure of humans is limited to occupational survey studies (Akca et al. 2009; Anger et al. 1986) and case reports (Geyer et al. 2005; Greenberg 1971; Hine 1969) in bromomethane workers. Results show that chronic inhalation exposure to bromomethane produces signs and symptoms of neurotoxicity (headache, dizziness, decreased upper extremity sensation, decreased recall, uncoordinated movements, ataxia, seizures, confusion), respiratory effects (nasal irritation, dyspnea, cough, increased phlegm), nausea, and vomiting. The Anger et al. (1986) survey study conducted in 32 bromomethane workers employed as fumigators showed increased muscle ache and fatigue and mild neurotoxic effects (headache, dizziness, decreased upper extremity sensation, and decreased recall). However, exposure levels were not determined for these workers. The reported mean exposure level of 2.3 ppm was determined from personal monitoring data collected in different populations of fumigators. However, since exposures of workers in the survey study are unknown, the outcomes observed cannot quantitatively be related to exposure levels.

Results of animal studies show that chronic exposure to bromomethane produces toxicity to the respiratory tract in rats (Gotoh et al. 1994; Reuzel et al. 1987, 1991) and mice (NTP 1992;), heart in rats (Reuzel et al. 1987, 1991) and mice (NTP 1992), gastrointestinal tract in rats (Reuzel et al. 1987, 1991), skeleton in mice (NTP 1992), and neurological system in mice (NTP 1992). In addition, decreased body weight gain was observed in rats (Reuzel et al. 1987, 1991) and mice (NTP 1992). The lowest effect levels adjusted for continuous exposure (LOAEL_adj_) were 1.79 ppm for decreased locomotor activity (NTP 1992), 17.9 ppm for dysplasia of the sternum (NTP 1992), 0.54 ppm for basal cell hyperplasia of the olfactory epithelium (Reuzel et al. 1987, 1991), 16.1 ppm for myocardial degeneration (Reuzel et al. 1987, 1991), and 16.1 ppm for hyperkeratosis of the esophagus (Reuzel et al. 1987, 1991).

Identification of the respiratory tract as one of the most sensitive targets of toxicity is supported by findings of nasal irritation and cough noted in cases reports and a rat study by Gotoh et al. (1994). Non-neoplastic lesions of the nasal cavity were observed in a 2-year study in male and female F344 rats exposed to 0, 4, 20, or 100 ppm bromomethane 6 hours/day, 5 days/week (Gotoh et al. 1994). Inflammation of the nasal cavity was observed in males exposed to 4, 20, and 100 ppm and in females exposed to 100 ppm, and necrosis of the olfactory epithelium was observed in males exposed to 100 ppm.

Agency Contacts (Chemical Managers): Sam Keith

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromomethane
CAS Numbers: | 74-83-9
Date: | March 2020
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: The oral toxicity of this compound has not been thoroughly studied because bromomethane tends to volatilize and exists mainly as a gas at room temperature. One acute-duration oral study was identified (Kaneda et al. 1998). This study exposed pregnant rats to 0, 3, 10, or 30 mg/kg/day and pregnant rabbits to 0, 1, 3, or 10 mg/kg/day bromomethane in corn oil by gavage on gestation days 6–15. In rats, erosion and thickening of the wall of the non-glandular stomach or adhesion of the stomach to the spleen, liver, or diaphragm was seen in all rats in the 30 mg/kg/day dose group. No clinical signs of toxicity, effects on reproductive function, or developmental effects in fetuses were observed. The only effects observed in rabbits were significant decreases in body weight and decreased food consumption in the 10 mg/kg/day group. Effects on body weight gain in rats and rabbits were considered to be secondary to the decreased food consumption.

It is unclear if effects observed in the glandular stomach are due to the bolus administration of a very reactive chemical, and if gavage administration would be an appropriate model for human exposure to bromomethane. In chronic-duration dietary studies, no gastrointestinal lesions were observed in rats (EPA 1999) or dogs (Wilson et al. 2000). The general population is not likely to be exposed to bromomethane via the oral route; however, exposure to a small amount of bromomethane could occur via contaminated water or food and, therefore, would not mimic the gavage exposure in animal studies. Given the uncertainty of whether the observed forestomach lesions are unique to gavage administration of bromomethane, an acute-duration oral MRL was not derived.

Agency Contacts (Chemical Managers): Sam Keith

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromomethane
CAS Numbers: | 74-83-9
Date: | March 2020
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: The oral toxicity of this compound has not been thoroughly studied because bromomethane tends to volatilize and exists mainly as a gas at room temperature. Two intermediate-duration gavage studies conducted male rats were identified (Boorman et al. 1986; Danse et al. 1984). These studies administer bromomethane by gavage at doses of 0, 0.4, 2, 10, or 50 mg/kg/day (Boorman et al. 1986) for 13 weeks and 0 or 50 mg/kg/day for 13–25 weeks (Danse et al. 1984). Mild focal hyperemia in the forestomach was observed at 2 mg/kg/day (Danse et al. 1984) and forestomach ulceration was observed at 50 mg/kg/day (Boorman et al. 1986; Danse et al. 1984). A 4-week feeding study in rats did not identify any adverse effects of dietary exposure to microencapsulated bromomethane at doses up to 7.98 mg/kg/day (EPA 1996). Although mean body weight gain was decreased by 14% in males during the first week of exposure and by 33% in females during weeks 1–2, but not during other weeks (EPA 1996). These changes were accompanied by decreased food intake and, therefore, are not considered adverse.

It is unclear if effects observed in the forestomach of rats are due to the bolus administration of a very reactive chemical, and if gavage administration would be an appropriate model for human exposure to bromomethane. The general population is not likely to be exposed to bromomethane via the oral route; however, exposure to a small amount of bromomethane could occur via contaminated water or food and, therefore, would not mimic the gavage exposure in animal studies. Given the uncertainty of whether the observed forestomach lesions are unique to gavage administration of bromomethane, an acute-duration oral MRL was not derived.

Agency Contacts (Chemical Managers): Sam Keith

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Bromomethane
CAS Numbers: | 74-83-9
Date: | March 2020
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: The oral toxicity of this compound has not been thoroughly studied because bromomethane tends to volatilize and exists mainly as a gas at room temperature. Two chronic-duration oral studies were identified: one study exposing dogs to dietary bromomethane at doses up to in 0.28 mg/kg/day in males and 0.27 mg/kg/day in females for 1 year (Wilson et al. 2000) and one study exposing rats to microencapsulated bromomethane at doses up to 11.10 and 15.12 mg/kg/day in males and females, respectively, for 12–24 months (EPA 1999). No adverse effects were observed in the study in dogs (Wilson et al. 2000). In rats, decreases in body weight gain were observed in the first 12–18 months at the highest dose levels. However, decreased food consumption were also observed at these doses during the same time period; therefore, decreased body weight gain is not considered adverse (EPA 1999). No other compound-related effects were observed.

This database was not considered adequate for derivation of a chronic-duration oral MRL because the targets of toxicity have not been established.

Agency Contacts (Chemical Managers): Sam Keith