# CHAPTER 8 REFERENCES

+ Cited in supplemental document

Abdel-Rahman MS. 1982. The presence of trihalomethanes in soft drinks. J Appl Toxicol 2:165–166.
Aggazzotti G, Fantuzzi G, Righi E, . 1998. Blood and breath analyses as biological indicators of exposure to trihalomethanes in indoor swimming pools. Sci Total Environ 217(1–2):155–163.9695179
+Aida Y, Ando M, Takada K, . 1989. Practical application of microcapsulation for toxicity studies using bromodichloromethane as a model compound. J Am Coll Toxicol 8(6):1177–1188.
+Aida Y, Yasuhara K, Takada K, . 1992. Chronic toxicity of microencapsulated bromodichloromethane administered in the diet to Wistar rats. J Toxicol Sci 17(2):51–68.1507274
Allis JW, Zhao G. 2002. Quantitative evaluation of bromodichloromethane metabolism by recombinant rat and human cytochrome P450s. Chem Biol Interact 140(2):137–153.12076521
Allis JW, Brown BL, Zhao G, . 2001. The effects of inhalation exposure to bromo-dichloromethane on specific rat CYP isoenzymes. Toxicology 161(1–2):67–77.11295256
Allis JW, Anderson BP, Zhao G, . 2002. Evidence for the involvement of CYP1A2 in the metabolism of bromodichloromethane in rat liver. Toxicology 176(1–2):25–37.12062927
Anderson BE, Zeiger E, Shelby MD, . 1990. Chromosome aberration and sister chromatid exchange test results with 42 chemicals. Environ Mol Mutagen 16(18):55–137.2091924
Arguello MD, Chriswell CD, Fritz JS, . 1979. Trihalomethanes in water: A report on the occurrence, seasonal variation in concentrations, and precursors of trihalomethanes. J Am Water Works Assoc 71:504–508.
Ashley DL, Blount BC, Singer PC, . 2005. Changes in blood trihalomethane concentrations resulting from differences in water quality and water use activities. Arch Environ Occup Health 60(1):7–15.16961003
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 1997. Toxicological profile for chloroform. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/toxprofiles/tp6.pdf. August 16, 2016.
ATSDR. 2005. Toxicological profile for bromoform and dibromochloromethane. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/ToxProfiles/tp130.pdf. August 16, 2016.
ATSDR. 2017. Bromodichloromethane. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
Backer LC, Ashley DL, Bonin MA, . 2000. Household exposures to drinking water disinfection by-products: Whole blood trihalomethane levels. J Expo Anal Environ Epidemiol 10(4):321–326.10981726
+Balster RL, Borzelleca JF. 1982. Behavioral toxicity of trihalomethane contaminants of drinking water in mice. Environ Health Perspect 46:127–136.7151753
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Basu M, Gupta SK, Singh G, . 2011. Multi-route risk assessment from trihalomethanes in drinking water supplies. Environ Monit Assess 178(1–4):121–134. 10.1007/s10661-010-1677-z.20824332
Batterman S, Zhang L, Wang S, . 2002. Partition coefficients for the trihalomethanes among blood, urine, water, milk and air. Sci Total Environ 284(1–3):237–247.11846168
Beech JA, Diaz R, Ordaz C, . 1980. Nitrates, chlorates and trihalomethanes in swimming pool water. Am J Public Health 70:79–82.7350831
Bellar TA, Lichtenberg JJ, Kroner RC. 1974. The occurrence of organohalides in chlorinated drinking water. J Am Water Works Assoc 66:703–706.
+Bielmeier SR, Best DS, Guidici DL, . 2001. Pregnancy loss in the rat caused by bromodichloromethane. Toxicol Sci 59(2):309–315.11158724
+Bielmeier SR, Best DS, Narotsky MG. 2004. Serum hormone characterization and exogeneous hormone rescue of bromodichloromethane-induced pregnancy loss in the F344 rat. Toxicol Sci 77(1):101–108. 10.1093/toxsci/kfh017.14657523
+Bielmeier SR, Murr AS, Best DS, . 2007. Effects of bromodichloromethane on ex vivo and in vitro luteal function and bromodichloromethane tissue dosimetry in the pregnant F344 rat. Toxicol in Vitro 21(5):919–928. 10.1016/j.tiv.2007.01.017.17344021
Bonin MA, Silva LK, Smith MM, . 2005. Measurement of trihalomethanes and methyl tert-butyl ether in whole blood using gas chromatography with high-resolution mass spectrometry. J Anal Toxicol 29(2):81–89.15902975
Bouwer EJ, McCarty PL. 1983a. Transformation of l- and 2-carbon halogenated aliphatic organic compounds under methanogenic conditions. Appl Environ Microbiol 45(4):1286–1294.6859849
Bouwer EJ, McCarty PL. 1983b. Transformation of halogenated organic compounds under denitrification conditions. Appl Environ Microbiol 45(4):1295–1299.6859850
Bouwer EJ, Rittmann BE, McCarty PL. 1981. Anaerobic degradation of halogenated 1- and 2-carbon organic compounds. Environ Sci Technol 15:596–599.22283955
Bove GE, Jr., Rogerson PA, Vena JE. 2007. Case control study of the geographic variability of exposure to disinfectant byproducts and risk for rectal cancer. Int J Health Geogr 6:18. 10.1186/1476-072x-6-18.17535441
+Bowman FJ, Borzelleca JF, Munson AE. 1978. The toxicity of some halomethanes in mice. Toxicol Appl Pharmacol 44:213–215.675691
Brodzinsky R, Singh HB. 1983. Volatile organic chemicals in the atmosphere: An assessment of available data. U.S. Environmental Protection Agency.
Burch JB, Everson TM, Seth RK, . 2015. Trihalomethane exposure and biomonitoring for the liver injury indicator, alanine aminotransferase, in the United States population (NHANES 1999-2006). Sci Total Environ 521–522:226–234. 10.1016/j.scitotenv.2015.03.050.
Cantor KP, Lynch CF, Hildesheim ME, . 1998. Drinking water source and chlorination byproducts. I. Risk of bladder cancer. Epidemiology 9(1):21–28.9430264
Cao WC, Zeng Q, Luo Y, . 2016. Blood biomarkers of late pregnancy exposure to trihalomethanes in drinking water and fetal growth measures and gestational age in a Chinese cohort. Environ Health Perspect 124(4):536–541. 10.1289/ehp.1409234.26340795
Caro J, Gallego M. 2007. Assessment of exposure of workers and swimmers to trihalomethanes in an indoor swimming pool. Environ Sci Technol 41(13):4793–4798.17695931
Caro J, Gallego M. 2008. Alveolar air and urine analyses as biomarkers of exposure to trihalomethanes in an indoor swimming pool. Environ Sci Technol 42(13):5002–5007.18678040
Carter JM, Moran MJ, Zogorski JS, . 2012. Factors associated with sources, transport, and fate of chloroform and three other trihalomethanes in untreated groundwater used for drinking water. Environ Sci Technol 46(15):8189–8197. 10.1021/es301839p.22799526
CDC. 2019. Fourth report on human exposure to environmental chemicals, update tables, (January 2019). Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/pdf/FourthReport_UpdatedTables_Volume1_Jan2019-508.pdf. September 24, 2019.
Chen J, Douglas GC, Thirkill TL, . 2003. Effect of bromodichloromethane on chorionic gonadotrophin secretion by human placental trophoblast cultures. Toxicol Sci 76(1):75–82. 10.1093/toxsci/kfg225.12970577
Chen J, Thirkill TL, Lohstroh PN, . 2004. Bromodichloromethane inhibits human placental trophoblast differentiation. Toxicol Sci 78(1):166–174. 10.1093/toxsci/kfh046.14691210
Chen YJ, Liu C, Huang LL, . 2019. First-trimester blood concentrations of drinking water trihalomethanes and neonatal neurobehavioral development in a Chinese birth cohort. J Hazard Mater 362:451–457. 10.1016/j.jhazmat.2018.09.040.30265976
+Christian MS, York RG, Hoberman AM, . 2001a. Oral (drinking water) developmental toxicity studies of bromodichloromethane (BDCM) in rats and rabbits. Int J Toxicol 20(4):225–237.11563418
+Christian MS, York RG, Hoberman AM, . 2001b. Biodisposition of dibromoacetic acid (DBA) and bromodichloromethane (BDCM) administered to rats and rabbits in drinking water during range-finding reproduction and developmental toxicity studies. Int J Toxicol 20(4):239–253.11563419
+Chu I, Secours V, Marino I, . 1980. The acute toxicity of four trihalomethanes in male and female rats. Toxicol Appl Pharmacol 52:351–353.7361328
+Chu I, Villeneuve DC, Secours VE, . 1982. Toxicity of trihalomethanes: I. The acute and subacute toxicity of chloroform, bromodichloromethane, chlorodibromomethane and bromoform in rats. J Environ Sci Health B 17(3):205–224.7096898
Class T, Kohnle R, Ballschmiter K. 1986. Chemistry of organic traces in air VII: Bromo- and bromochloromethanes in air over the Atlantic Ocean. Chemosphere 15:429–436.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Coleman WE, Lingg RD, Melton RG, . 1975. The occurrence of volatile organics in five drinking water supplies using gas chromatography/mass spectrometry. In: Keith LH, ed. Identification & analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Science Publishers, 305–327.
+Condie LW, Smallwood CL, Laurie RD. 1983. Comparative renal and hepatotoxicity of halomethanes: Bromodichloromethane, bromoform, chloroform, dibromochloromethane and methylene chloride. Drug Chem Toxicol 6(6):563–578.6653442
Da Silva ML, Charest-Tardif G, Krishnan K, . 1999. Influence of oral administration of a quaternary mixture of trihalomethanes on their blood kinetics in the rat. Toxicol Lett 106(1):49–57.10378450
Da Silva ML, Charest-Tardif G, Krishnan K, . 2000. Evaluation of the pharmacokinetic interactions between orally administered trihalomethanes in the rat. J Toxicol Environ Health A 60(5):343–353.10912587
Danileviciute A, Grazuleviciene R, Vencloviene J, . 2012. Exposure to drinking water trihalomethanes and their association with low birth weight and small for gestational age in genetically susceptible women. Int J Environ Res Public Health 9(12):4470–4485. 10.3390/ijerph9124470.23222181
Dionisio KL, Frame AM, Goldsmith M-R, . 2015. Exploring consumer exposure pathways and patterns of use for chemicals in the environment. Toxicol Rep 2:228–237. 10.1016/j.toxrep.2014.12.009.28962356
Dodds L, King WD. 2001. Relation between trihalomethane compounds and birth defects. Occup Environ Med 58(7):443–446.11404448
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 26, 2018.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/. July 26, 2018.
Dunovant VS, Clark CS, Que Hee SS, . 1986. Volatile organics in the wastewater and airspaces of three wastewater treatment plants. J Water Pollut Control Fed 58(9):886–895.
Entz RC, Thomas KW, Diachenko GW. 1982. Residues of volatile halocarbons in foods using headspace gas chromatography. J Agric Food Chem 30:846–849.
EPA. 1979. National interim primary drinking water regulations; control of trihalomethanes in drinking water; Final rule. U.S. Environmental Protection Agency. Fed Regist 44(231):68624–68670.
EPA. 1980. An exposure and risk assessment for trihalomethanes. Final draft report. Washington, DC: U.S. Environmental Protection Agency. EPA440481018. https://nepis.epa.gov/EPA/html/DLwait.htm?url=/Exe/ZyPDF.cgi/9101LCWY.PDF?Dockey=9101LCWY.PDF. September 26, 2019.
EPA. 1983. Treatability manual: Volume I. Treatability data. U.S. Environmental Protection Agency. EPA600282001a. https://nepis.epa.gov/EPA/html/DLwait.htm?url=/Exe/ZyPDF.cgi/30005R3P.PDF?Dockey=30005R3P.PDF. September 26, 2019.
EPA. 1985. Health and environmental effects document for bromochloromethane. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600891016. https://nepis.epa.gov/EPA/html/DLwait.htm?url=/Exe/ZyPDF.cgi/900G0K00.PDF?Dockey=900G0K00.PDF. September 26, 2019.
EPA. 1987. Determination of Henry’s law constants of selected priority pollutants. U.S. Environmental Protection Agency. PB87212684. EPA600D87229. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100LHQP.txt. July 12, 2016.
EPA. 1990. Method 551.1. Determination of chlorination disinfection byproducts, chlorinated solvents, and halogenated pesticides/herbicides in drinking water by liquid-liquid extraction and gas chromatography with electron-capture detection. Cincinnati, OH: U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-06/documents/epa-551.1.pdf. July 13, 2016.
EPA. 1996a. Method 3585. Waste dilution for volatile organics. The SW-846 compendium U.S. Environmental Protection Agency. https://www.epa.gov/hw-sw846/method-3585-waste-dilution-volatile-organics-part-test-methods-evaluating-solid-waste. July 13, 2016.
EPA. 1996b. Method 5030B. Purge-and-trap for aqueous samples. The SW-846 compendium U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-12/documents/5030b.pdf. July 15, 2016.
EPA. 1996c. Method 8021b. Aromatic and halogenated volatiles by gas chromatography using photoionization and/or electrolytic conductivity detectors. The SW-846 compendium U.S. Environmental Protection Agency. https://www.epa.gov/hw-sw846/method-8021b-aromatic-and-halogenated-volatiles-gas-chromatography-using-photoionization. July 13, 2016.
EPA. 1999. Compendium of methods for the determination of toxic organic compounds in ambient air. Second Edition. Compendium method TO-15. Determination of volatile organic compounds (VOCs) in air collected in specially-prepared canisters and analyzed by gas chromatography/mass spectrometry (GC/MS). U.S. Environmental Protection Agency. EPA625R96010b. https://www3.epa.gov/ttnamti1/files/ambient/airtox/to-15r.pdf. July 13, 2016.
EPA. 2002. Method 5035. Closed-system purge-and-trap and extraction for volatile organics in soil and waste samples. The SW-846 compendium U.S. Environmental Protection Agency. https://www.epa.gov/hw-sw846/method-5035-closed-system-purge-and-trap-and-extraction-volatile-organics-soil-and-waste. July 13, 2016.
EPA. 2003. 2-Year oral carcinogenicity and chronic toxicity study in rats (summary tables included). Submitted under TSCA Section FYI to the U.S. Environmental Protection Agency. FYI050301446. https://yosemite.epa.gov/oppts/epatscat8.nsf/by+Service/AE4793D42355EAFC85256F390055C5D1/$File/84030000013.pdf. July 13, 2016.
EPA. 2005a. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2005b. Drinking water criteria document for brominated trihalomethanes. Washington, DC: U.S. Environmental Protection Agency. EPA822R05011. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1006GVD.txt July 11, 2016.
EPA. 2009a. Provisional peer-reviewed toxicity values for bromodichloromethane. Washington, DC: U.S. Environmental Protection Agency. EPA/690/R-09/006F. https://cfpub.epa.gov/ncea/pprtv/documents/Bromodichloromethane.pdf. September 19, 2019.
EPA. 2009b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2014a. Bromodichloromethane. Curated chemical and product categories data were retrieved from the CPCat Database. CPCat: Chemical and Product Categories. U.S. Environmental Protection Agency. https://actor.epa.gov/cpcat/faces/chemicalUse.xhtml?casrn=75-27-4. July 12, 2016.
EPA. 2014b. 2012 National monitoring programs annual report (UATMP, NATTS, CSATAM). U.S. Environmental Protection Agency. EPA454R14006a. https://www3.epa.gov/ttnamti1/files/ambient/airtox/2012nmpreport.pdf. July 12, 2016.
EPA. 2014c. 2012 National monitoring programs annual report (UATMP, NATTS, CSATAM) appendices. U.S. Environmental Protection Agency. EPA454R14006b. https://www3.epa.gov/ttnamti1/files/ambient/airtox/2012nmpappendix.pdf. July 12, 2016.
EPA. 2014d. Method 5021A. Volatile organic compounds in various sample matrices using equilibrium headspace analysis. The SW-846 compendium. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-12/documents/5021a.pdf. July 13, 2016.
EPA. 2015a. 2013 National monitoring programs annual report (UATMP, NATTS, CSATAM). U.S. Environmental Protection Agency. EPA454R15005a. https://www3.epa.gov/ttnamti1/files/ambient/airtox/2013nmpreport.pdf. July 12, 2016.
EPA. 2015b. 2013 National monitoring programs annual report (UATMP, NATTS, CSATAM) appendices. U.S. Environmental Protection Agency. EPA454R15005b. https://www3.epa.gov/ttnamti1/files/ambient/airtox/2013nmpappendix.pdf. July 12, 2016.
EPA. 2015d. Background on drinking water standards in the Safe Drinking Water Act (SDWA). U.S. Environmental Protection Agency. https://www.epa.gov/dwstandardsregulations/background-drinking-water-standards-safe-drinking-water-act-sdwa. July 12, 2016.
EPA. 2016. Drinking water contaminants-standards and regulations. U.S. Environmental Protection Agency. https://www.epa.gov/dwstandardsregulations. July 12, 2016.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. June 5, 2019.
EPA. 2019. Air quality system (AQS). Data files. Annual summary data. U.S. Environmental Protection Agency. https://www.epa.gov/aqs. September 4, 2019.
Fantuzzi G, Righi E, Predieri G, . 2001. Occupational exposure to trihalomethanes in indoor swimming pools. Sci Total Environ 264(3):257–265.11213196
FDA. 2006. Total diet study market baskets 1991-3 through 2003-4. U.S. Food and Drug Administration: http://www.fda.gov/downloads/Food/FoodScienceResearch/TotalDietStudy/UCM184303.pdf. July 13, 2016.
FDA. 2017. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations 21 CFR 165.110 https://www.govinfo.gov/content/pkg/CFR-2017-title21-vol2/pdf/CFR-2017-title21-vol2-sec165-110.pdf. September 7, 2017.
FDA. 2019. Substances Added to Food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. September 2, 2019.
Fleming-Jones ME, Smith RE. 2003. Volatile organic compounds in foods: A five year study. J Agric Food Chem 51(27):8120–8127. 10.1021/jf0303159.14690406
+French AS, Copeland CB, Andrews D, . 1999. Evaluation of the potential immunotoxicity of bromodichloromethane in rats and mice. J Toxicol Environ Health A 56(5):297–310. 10.1080/009841099158024.10094244
Fujie K, Aoki T, Wada M. 1990. Acute and subacute cytogenetic effects of the trihalomethanes on rat bone marrow cells in vivo. Mutat Res 242(2):111–119.2233827
Fujie K, Aoki T, Ito Y, . 1993. Sister-chromatid exchanges induced by trihalomethanes in rat erythroblastic cells and their suppression by crude catechin extracted from green tea. Mutat Res 300(3–4):241–246.7687024
Furlong EAN, D’Itri FM. 1986. Trihalomethane levels in chlorinated Michigan drinking water. Ecol Modell 32:215–225.
Gao P, Thornton-Manning JR, Pegram RA. 1996. Protective effects of glutathione on bromodichloromethane in vivo toxicity and in vitro macromolecular binding in Fisher 344 rats. J Toxicol Environ Health 49(2):145–159.8874533
+George MH, Olson GR, Doerfler D, . 2002. Carcinogenicity of bromodichloromethane administered in drinking water to male F344/N rats and B6C3F1 mice. Int J Toxicol 21(3):219–230. 10.1080/10915810290096351.12055023
Geter DR, Chang LW, Hanley NM, . 2004. Analysis of in vivo and in vitro DNA strand breaks from trihalomethane exposure. J Carcinog 3(1):2. 10.1186/1477-3163-3-2.14969591
Gordon SM, Brinkman MC, Ashley DL, . 2006. Changes in breath trihalomethane levels resulting from household water-use activities. Environ Health Perspect 114(4):514–521.16581538
Gottlieb MS, Carr JK, Morris DT. 1981. Cancer and drinking water in Louisiana: Colon and rectum. Int J Epidemiol 10(2):117–126.7287272
+Grazuleviciene R, Kapustinskiene V, Vencloviene J, . 2013. Risk of congenital anomalies in relation to the uptake of trihalomethane from drinking water during pregnancy. Occup Environ Med 70(4):274–282. 10.1136/oemed-2012-101093.23404756
Gschwend PM, Macfarlane JK, Newman KA. 1985. Volatile halogenated organic compounds released to seawater from temperate marine macroalgae. Science 227:1033–1035.17794227
Hauser TR, Bromberg SM. 1982. EPA’s monitoring program at Love Canal 1980. Environ Monit Assess 2(3):249–271. 10.1007/bf00394456.24264296
Haynes WM. 2014. Bromodichloromethane. In: CRC Handbook of chemistry and physics. 95th ed. Boca Raton, FL: CRC Press, 3–64.
Hewitt WR, Brown EM, Plaa GL. 1983. Acetone-induced potentiation of trihalomethane toxicity in male rats. Toxicol Lett 16:285–296.6857724
Hiatt MH, Pia JH. 2004. Screening processed milk for volatile organic compounds using vacuum distillation/gas chromatography/mass spectrometry. Arch Environ Contam Toxicol 46(2):189–196. 10.1007/s00244-003-2308-2.15106669
Hoekstra EJ, De Leer EW, Brinkman UAT. 1998. Natural formation of chloroform and brominated trihalomethanes in soil. Environ Sci Technol 32(23):3724–3729.
Hoffman CS, Mendola P, Savitz DA, . 2008. Drinking water disinfection by-product exposure and fetal growth. Epidemiology 19(5):729–737. http://www.jstor.org/stable/25662620. September 26, 2019.18633330
+Hooth MJ, McDorman KS, Hester SD, . 2002. The carcinogenic response of Tsc2 mutant Long-Evans (Eker) rats to a mixture of drinking water disinfection by-products was less than additive. Toxicol Sci 69(2):322–331.12377981
HSDB. 2012. Bromodichloromethane. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. July 11, 2016.
IARC. 1991. Bromodichloromethane. In: IARC Monographs on the evaluation of carcinogenic risks to humans. Chlorinated drink-water; chlorination by-products; some other halogenated compounds; cobalt and cobalt compounds. Lyon, France: International Agency for Research on Cancer, 179–212.
IARC. 1999. Bromodichloromethane. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 71. Re-evaluation of some organic chemicals, hydrazine, and hydrogen peroxide. Lyon, France: International Agency for Research on Cancer. http://publications.iarc.fr/89. September 19, 2019.
IARC. 2016. Agents classified by the IARC monographs. Volumes 1–117. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf. November 4, 2016.
IRIS. 2002. Bromodichloromethane; CASRN 75-27-4. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0213_summary.pdf. March 24, 2016.
Ishidate MJ, Harnois MC, Sofuni T. 1988. A comparative analysis of data on the clastogenicity of 951 chemical substances tested in mammalian cell cultures. Mutat Res 195(2):151–213.3277036
+Iszatt N, Nieuwenhuijsen MJ, Nelson P, . 2011. Water consumption and use, trihalomethane exposure, and the risk of hypospadias. Pediatrics 127(2):e389–397. 10.1542/peds.2009-3356.21220402
Johnsrud EK, Koukouritaki SB, Divakaran K, . 2003. Human hepatic CYP2E1 expression during development. J Pharmacol Exp Ther 307(1):402–407. 10.1124/jpet.102.053124.14500779
Jones RR, DellaValle CT, Weyer PJ, . 2019. Ingested nitrate, disinfection by-products, and risk of colon and rectal cancers in the Iowa Women’s Health Study cohort. Environ Int 126:242–251. 10.1016/j.envint.2019.02.010.30822653
Kaczmar SW, D’Itri FM, Zabik MJ. 1984. Volatilization rates of selected haloforms from aqueous environments. Environ Toxicol Chem 3:31–35.
Kanarek MS, Young TB. 1982. Drinking water treatment and risk of cancer death in Wisconsin. Environ Health Perspect 46:179–186.7151760
Keefe SH, Barber LB, Runkel RL, . 2004. Fate of volatile organic compounds in constructed wastewater treatment wetlands. Environ Sci Technol 38(7):2209–2216.15112826
+Keegan TE, Simmons JE, Pegram RA. 1998. NOAEL and LOAEL determinations of acute hepatotoxicity for chloroform and bromodichloromethane delivered in an aqueous vehicle to F344 rats. J Toxicol Environ Health A 55(1):65–75.9747604
Kenyon EM, Eklund C, Leavens T, . 2016. Development and application of a human PBPK model for bromodichloromethane to investigate the impacts of multi-route exposure. J Appl Toxicol 36(9):1095–1111. 10.1002/jat.3269.26649444
Kenyon EM, Lipscomb JC, Pegram RA, . 2019. The impact of scaling factor variability on risk-relevant pharmacokinetic outcomes in children: A case study using bromodichloromethane (BDCM). Toxicol Sci 167(2):347–359. 10.1093/toxsci/kfy236.30252107
Kerger BD, Schmidt CE, Paustenbach DJ. 2000. Assessment of airborne exposure to trihalomethanes from tap water in residential showers and baths. Risk Anal 20(5):637–651.11110211
Kerger BD, Suder DR, Schmidt CE, . 2005. Airborne exposure to trihalomethanes from tap water in homes with refrigeration-type and evaporative cooling systems. J Toxicol Environ Health A 68(6):401–429. 10.1080/15287390590903577.15799243
Kim H, Shim J, Lee S. 2002. Formation of disinfection by-products in chlorinated swimming pool water. Chemosphere 46(1):123–130.11806524
+King WD, Dodds L, Allen AC. 2000. Relation between stillbirth and specific chlorination by-products in public water supplies. Environ Health Perspect 108(9):883–886.
+Klinefelter GR, Suarez JD, Roberts NL, . 1995. Preliminary screening for the potential of drinking water disinfection byproducts to alter male reproduction. Reprod Toxicol 9(6):571–578.8597653
Kogevinas M, Villanueva CM, Font-Ribera L, . 2010. Genotoxic effects in swimmers exposed to disinfection by-products in indoor swimming pools. Environ Health Perspect 118(11):1531–1537. 10.1289/ehp.1001959.20833606
Kool HJ, van KCF, van KHJ, . 1981. Toxicity assessment of organic compounds in drinking water in the Netherlands. Sci Total Environ 18:135–153.7015503
Krasner SW, McGuire MJ, Jacangelo JG, . 1989. The occurrence of disinfection by-products in US drinking water. Am Water Works Assoc J 81(8):41–53.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kuo TM, Chen CM, Lin HC, . 2000. Surveys of volatile organic compounds in soil and groundwater at industrial sites in Taiwan. Bull Environ Contam Toxicol 65(5):654–659. 10.1007/s0012800173.11014851
Lan J, Rahman SM, Gou N, . 2018. Genotoxicity assessment of drinking water disinfection byproducts by DNA damage and repair pathway profiling analysis. Environ Sci Technol 52(11):6565–6575. 10.1021/acs.est.7b06389.
Leavens TL, Blount BC, DeMarini DM, . 2007. Disposition of bromodichloromethane in humans following oral and dermal exposure. Toxicol Sci 99(2):432–445.17656487
Lee J, Kim ES, Roh BS, . 2013. Occurrence of disinfection by-products in tap water distribution systems and their associated health risk. Environ Monit Assess 185(9):7675–7691. 10.1007/s10661-013-3127-1.23446885
+Lilly PD, Simmons JE, Pegram RA. 1994. Dose-dependent vehicle differences in the acute toxicity of bromodichloromethane. Fundam Appl Toxicol 23(1):132–140.7958557
+Lilly PD, Simmons JE, Pegram RA. 1996. Effect of subchronic corn oil gavage on the acute toxicity of orally administered bromodichloromethane. Toxicol Lett 87(2–3):93–102.8914616
+Lilly PD, Ross TM, Pegram RA. 1997. Trihalomethane comparative toxicity: Acute renal and hepatic toxicity of chloroform and bromodichloromethane following aqueous gavage. Fundam Appl Toxicol 40(1):101–110.9398492
Lilly PD, Andersen ME, Ross TM, . 1998. A physiologically based pharmacokinetic description of the oral uptake, tissue dosimetry, and rates of metabolism of bromodichloromethane in the male rat. Toxicol Appl Pharmacol 150(2):205–217. 10.1006/taap.1998.8405.9653052
Lindstrom AB, Pleil JD, Berkoff DC. 1997. Alveolar breath sampling and analysis to assess trihalomethane exposures during competitive swimming training. Environ Health Perspect 105(6):636–642.9288498
+Lipsky MM, Skinner M, O’Connell C. 1993. Effects of chloroform and bromodichloromethane on DNA synthesis in male F344 rat kidney. Environ Health Perspect 101 (Suppl 5):249–252.8013415
+Lock T, Cottrell L, Soames T, . 2004. Formic acid excretion in rats and mice exposed to bromodichloromethane: a possible link to renal tubule cell proliferation in long-term studies. Arch Toxicol 78(7):410–417. 10.1007/s00204-004-0548-1.15141287
Lourencetti C, Ballester C, Fernandez P, . 2010. New method for determination of trihalomethanes in exhaled breath: applications to swimming pool and bath environments. Anal Chim Acta 662(1):23–30. 10.1016/j.aca.2009.12.040.20152261
Lynberg M, Nuckols JR, Langlois P, . 2001. Assessing exposure to disinfection by-products in women of reproductive age living in Corpus Christi, Texas, and Cobb County, Georgia: Descriptive results and methods. Environ Health Perspect 109(6):597–604.11445514
Mabey WR, Smith JH, Podoll RT, . 1982. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards.
+MacLehose RF, Savitz DA, Herring AH, . 2008. Drinking water disinfection by-products and time to pregnancy. Epidemiology 19(3):451–458. 10.1097/EDE.0b013e31816a23eb.18379423
Marienfeld CJ, Collins M, Wright H, . 1986. Cancer mortality and the method of chlorination of public drinking water: St. Louis City and St. Louis County, Missouri. J Environ Pathol Toxicol Oncol 7(1/2):141–158.3795009
Mathews JM, Troxler PS, Jeffcoat AR. 1990. Metabolism and distribution of bromodichloromethane in rats after single and multiple oral doses. J Toxicol Environ Health 30(1):15–22. 10.1080/15287399009531406.2112202
Matsuoka A, Yamakage K, Kusakabe H, . 1996. Re-evaluation of chromosomal aberration induction on nine mouse lymphoma assay “unique positive’ NTP carcinogens. Mutat Res 369(3–4):243–252.8792842
+McDorman KS, Hooth MJ, Starr TB, . 2003. Analysis of preneoplastic and neoplastic renal lesions in Tsc2 mutant Long-Evans (Eker) rats following exposure to a mixture of drinking water disinfection by-products. Toxicology 187(1):1–12.12679048
McGregor DB, Brown A, Cattanach P, . 1988. Responses of the L5178Y tk+/tk-mouse lymphoma cell forward mutation assay II: 18 coded chemicals. Environ Mol Mutagen 11(1):91–118.3338442
Miermans CJ, van der Velde LE, Frintrop PC. 2000. Analysis of volatile organic compounds, using the purge and trap injector coupled to a gas chromatograph/ion-trap mass spectrometer: review of the results in Dutch surface water of the Rhine, Meuse, Northern Delta Area and Westerscheldt, over the period 1992-1997. Chemosphere 40(1):39–48. 10.1016/s0045-6535(99)00229-5.10665443
Min JY, Min KB. 2016. Blood trihalomethane levels and the risk of total cancer mortality in US adults. Environ Pollut 212:90–96. 10.1016/j.envpol.2016.01.047.26840521
Mink FL, Brown TJ, Rickabaugh J. 1986. Absorption, distribution, and excretion of 14C-trihalomethanes in mice and rats. Bull Environ Contam Toxicol 37:752–758.3779162
Morimoto K, Koizumi A. 1983. Trihalomethanes induce sister chromatid exchanges in human lymphocytes in vitro and mouse bone marrow cells in vivo. Environ Res 32:72–79.6617620
Mortelmans K, Haworth S, Lawlor T, . 1986. Salmonella mutagenicity tests: II. Results from the testing of 270 chemicals. Environ Mutagen 8(Suppl 7):1–119.
+Moser VC, Phillips PM, McDaniel KL, . 2007. Neurotoxicological evaluation of two disinfection by-products, bromodichloromethane and dibromoacetonitrile, in rats. Toxicology 230(2–3):137–144. 10.1016/j.tox.2006.11.007.17157428
+Munson AE, Sain LE, Sanders VM, . 1982. Toxicology of organic drinking water contaminants: trichloromethane, bromodichloromethane, dibromochloromethane and tribromoethane. Environ Health Perspect 46:117–126.7151752
+Narotsky MG, Pegram RA, Kavlock RJ. 1997. Effect of dosing vehicle on the developmental toxicity of bromodichloromethane and carbon tetrachloride in rats. Fundam Appl Toxicol 40(1):30–36.9398485
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
Nestmann EA, Lee EGH. 1985. Genetic activity in Saccharomyces cerevisiae of compounds found in effluents of pulp and paper mills. Mutat Res 155:53–60.3881665
NIOSH. 2015. Bromodichloromethane. ICSC: 0393. International Chemical Safety Cards. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/ipcsneng/neng0393.html. July 11, 2016.
NIOSH. 2018. NIOSH pocket guide to chemical hazards. Index of Chemical Abstracts Service Registry Numbers (CAS No. 75-27-4). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgdcas.html. September 2, 2019.
+NTP. 1987. NTP technical report on the toxicology and carcinogenesis studies of bromodichloromethane (CAS No. 75-27-4) in F344/n rats and B6C3F1 mice. Research Triangle Park, NC: National Toxicology Program.
+NTP. 2006. Toxicology and carcinogenesis studies of bromodichloromethane in male F344/N rats and female B6C3F1 mice (drinking water studies). National Toxicology Program. NTP TR 532. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr532.pdf?utm_source=direct&utm_medium=prod&utm_campaign=ntpgolinks&utm_term=tr532.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments – February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/hat/review/index-2.html. September 26, 2019.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2016. Bromodichloromethane. In: Report on carcinogens, Fourteenth edition. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/bromodichloromethane.pdf. September 19, 2019.
Nuckols JR, Ashley DL, Lyu C, . 2005. Influence of tap water quality and household water use activities on indoor air and internal dose levels of trihalomethanes. Environ Health Perspect 113(7):863–870.16002374
O’Neil MJ, ed. 2013. Bromodichloromethane. In: The Merck index. 15th ed. Whitehouse, NJ: The Royal Society of Chemistry, 250.
OSHA. 2018a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Code of Federal Regulations 29 CFR 1910.1000. Occupational Safety and Health Administration. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. November 28, 2018.
OSHA. 2018b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Code of Federal Regulations 29 CFR 1915.1000. Occupational Safety and Health Administration. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. November 1, 2018.
OSHA. 2018c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Code of Federal Regulations 29 CFR 1926.55 Appendix A. Occupational Safety and Health Administration. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. November 1, 2018.
Page-Lariviere F, Tremblay A, Campagna C, . 2016. Low concentrations of bromodichloromethane induce a toxicogenomic response in porcine embryos in vitro. Reprod Toxicol 66:44–55. 10.1016/j.reprotox.2016.09.010.27671623
Perry DL, Chuang CC, Jungclaus GA, . 1979. Identification of organic compounds in industrial effluent discharges.
Pleil JD, Lindstrom AB. 1997. Exhaled human breath measurement method for assessing exposure to halogenated volatile organic compounds. Clin Chem 43(5):723–730.9166222
Potter CL, Chang LW, DeAngelo AB, . 1996. Effects of four trihalomethanes on DNA strand breaks, renal hyaline droplet formation and serum testosterone in male F-344 rats. Cancer Lett 106:235–242.8844978
Riederer AM, Dhingra R, Blount BC, . 2014. Predictors of blood trihalomethane concentrations in NHANES 1999-2006. Environ Health Perspect 122(7):695–702. 10.1289/ehp.1306499.24647036
+Rivera-Núñez Z, Wright JM. 2013. Association of brominated trihalomethane and haloacetic acid exposure with fetal growth and preterm delivery in Massachusetts. J Occup Environ Med 55(10):1125–1134. 10.1097/JOM.0b013e3182a4ffe4.24064786
Rivera-Núñez Z, Wright JM, Meyer A. 2018. Exposure to disinfectant by-products and the risk of stillbirth in Massachusetts. Occup Environ Med 75(10):742–751. 10.1136/oemed-2017-104861.
Rivera-Núñez Z, Wright JM, Blount BC, . 2012. Comparison of trihalomethanes in tap water and blood: A case study in the United States. Environ Health Perspect 120(5):661–667. 10.1289/ehp.1104347.22281753
Robbiano L, Baroni D, Carrozzino R, . 2004. DNA damage and micronuclei induced in rat and human kidney cells by six chemicals carcinogenic to the rat kidney. Toxicology 204(2–3):187–195. 10.1016/j.tox.2004.06.057.15388244
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rostad CE, Martin BS, Barber LB, . 2000. Effect of a constructed wetland on disinfection byproducts: Removal processes and production of precursors. Environ Sci Technol 34(13):2703–2710. 10.1021/es9900407.
+Ruddick JA, Villeneuve DC, Chu I, . 1983. A teratological assessment of four trihalomethanes in the rat. J Environ Sci Health B 18:333–349.6875216
Savitz DA, Singer PC, Herring AH, . 2006. Exposure to drinking water disinfection by-products and pregnancy loss. Am J Epidemiol 164(11):1043–1051.16957027
Shikiya J, Tsou G, Kowalski J, . 1984. Ambient monitoring of selected halogenated hydrocarbons and benzene in the California south coast air basin. Proc APCA Ann Meet 77:1–21.
Silva LK, Backer LC, Ashley DL, . 2013. The influence of physicochemical properties on the internal dose of trihalomethanes in humans following a controlled showering exposure. J Expo Sci Environ Epidemiol 23(1):39–45. 10.1038/jes.2012.80.22829048
Silva ZI, Rebelo MH, Silva MM, . 2012. Trihalomethanes in Lisbon indoor swimming pools: occurrence, determining factors, and health risk classification. J Toxicol Environ Health A 75(13–15):878–892. 10.1080/15287394.2012.690706.22788374
Simmon VF, Kauhanen K, Tardiff RG. 1977. Mutagenic activity of chemicals identified in drinking water. In: Scott D, Bridges BA, Sobels, eds. Progress in genetic toxicology: Proceedings of the Second International Conference on Environmental Mutagens, Edinburgh, July 11–15, 1977. New York, NY: Elsevier, 249–258.
Sittig M. 1985. Bromodichloromethane. In: Handbook of toxic and hazardous chemicals and carcinogens. 2nd ed. Norwich, NY: Noyes/William Andrew Publishing, 148–149.
Smith CC, Cragg ST, Wolfe GF, . 1985. Investigation of the metabolism of chlorinated hydrocarbons in subhuman species. U.S. Environmental Protection Agency.
Sofuni T, Honma M, Hayashi M, . 1996. Detection of in vitro clastogens and spindle poisons by the mouse lymphoma assay using the microwell method: Interim report of an international collaborative study. Mutagenesis 11(4):349–355.8671759
Squillace PJ, Moran MJ, Price CV. 2004. VOCs in shallow groundwater in new residential/commercial areas of the United States. Environ Sci Technol 38(20):5327–5338.15543733
Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
Stocker KJ, Statham J, Howard WR, . 1997. Assessment of the potential in vivo genotoxicity of three trihalomethanes: Chlorodibromomethane, bromodichloromethane and bromoform. Mutagenesis 12(3):169–173.9175643
St-Pierre A, Krishnan K, Tardif R. 2003. Evaluation of the influence of chloroacetic acids on the pharmacokinetics of trihalomethanes in the rat. J Toxicol Environ Health A 66(23):2267–2280. 10.1080/713853999.14612337
St-Pierre A, Krishnan K, Tardif R. 2005. Characterization of the metabolic interaction between trihalomethanes and chloroacetic acids using rat liver microsomes. J Toxicol Environ Health A 68(4):287–298. 10.1080/15287390590895847.15799452
+Summerhayes RJ, Morgan GG, Edwards HP, . 2012. Exposure to trihalomethanes in drinking water and small-for-gestational-age births. Epidemiology 23(1):15–22. 10.1097/EDE.0b013e31823b669b.22157301
Symons JM, Bellar TA, Carswell JK, . 1975. National organics reconnaissance survey for halogenated organics. J Am Water Works Assoc 67:634–648.
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Tao L, Wang W, Li L, . 2005. DNA hypomethylation induced by drinking water disinfection by-products in mouse and rat kidney. Toxicol Sci 87(2):344–352. 10.1093/toxsci/kfi257.16014735
+Thornton-Manning JR, Seely JC, Pegram RA. 1994. Toxicity of bromodichloromethane in female rats and mice after repeated oral dosing. Toxicology 94(1–3):3–18.7801327
Tomasi A, Albano E, Biasi F, . 1985. Activation of chloroform and related trihalomethanes to free radical intermediates in isolated hepatocytes and in the rat in vivo as detected by the ESR-spin trapping technique. Chem Biol Interact 55(3):303–316. 10.1016/s0009-2797(85)80137-x.3000632
+Torti VR, Cobb AJ, Everitt JI, . 2001. Nephrotoxicity and hepatotoxicity induced by inhaled bromodichloromethane in wild-type and p53-heterozygous mice. Toxicol Sci 64(2):269–280.11719710
Torti VR, Cobb AJ, Wong VA, . 2002. Induction of micronuclei in wild-type and p53(+/−) transgenic mice by inhaled bromodichloromethane. Mutat Res 520(1–2):171–178.12297157
Tucker JD, Auletta A, Cimino MC, . 1993. Sister-chromatid exchange: Second report of the Gene-Tox Program. Mutat Res 297(2):101–180.7687323
+Tumasonis CF, McMartin N, Bush B. 1985. Lifetime toxicity of chloroform and bromodichloromethane when administered over a lifetime in rats. Ecotoxicol Environ Saf 9(2):233–240.3987603
Uhler AAD, Diachenko GW. 1987. Volatile halocarbon compounds in process water and processed foods. Bull Environ Contam Toxicol 39:601–607.3689989
USGS. 1998. Organic compounds and parameter codes: Volatile organic compounds, whole water, gas chromatography/mass spectrometry, purge and trap, O-4127-96 (see table 1). Methods of analysis by the U.S. Geological Survey national water quality laboratory — determination of 86 volatile organic compounds in water by gas chromatography/mass spectrometry, including detections less than reporting limits. Denver, CO: U.S. Geological Survey. Open-File report 97-829. http://nwql.usgs.gov/pubs/OFR/OFR-97-829.pdf. July 13, 2016.
USGS. 2003. Quality and sources of shallow ground water in areas of recent residential development in Salt Lake Valley, Salt Lake County, Utah. U.S. Geological Survey. Water-Resources Investigations Report 03–4028. http://pubs.usgs.gov/wri/wri034028/PDF/WRI034028.pdf. July 12, 2016.
USGS. 2006a. Chapter 5 - Additional information for selected VOCs. Volatile organic compounds in the nation’s ground water and drinking-water supply wells: Supporting information. U.S. Geological Survey. Circular 1292. http://water.usgs.gov/nawqa/vocs/national_assessment/report/chapter5.html. July 12, 2016.
USGS. 2006b. Occurrence of trihalomethanes in the nation’s ground water and drinking-water supply wells, 1985-2002. Reston, VA: U.S. Geological Survey. Scientific Investigations Report 2006–5068. http://pubs.usgs.gov/sir/2006/5068/sir20065068.pdf. July 12, 2016.
USGS. 2007. Anthropogenic organic compounds in ground water and finished water of community water systems in the northern Tampa Bay area, Florida, 2002–04. U.S. Geological Survey. Scientific Investigations Report 2006-5267. http://pubs.usgs.gov/sir/2006/5267/pdf/sir2006-5267web.pdf. July 12, 2016.
USGS. 2010a. Estimated use of water in the United States in 2010. U.S. Geological Survey. Circular 1405. http://pubs.usgs.gov/circ/1405/pdf/circ1405.pdf. July 11, 2016.
USGS. 2010b. Quality of source water from public-supply wells in the United States, 1993-2007. U.S. Geological Survey. Scientific Investigations Report 2010–5024. http://pubs.usgs.gov/sir/2010/5024/. July 12, 2016.
USGS. 2015. Water quality in principal aquifers of the United States, 1991-2010. U.S. Geological Survey. Circular 1360. 10.3133/cir1360. September 4, 2019.
Varma MM, Ampy FR, Verma K, . 1988. In-vitro mutagenicity of water contaminants in complex mixtures. J Appl Toxicol 8(4):243–248.3183290
Verschueren K. 1977. Bromodichloromethane. In: Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company, 130.
Verschueren K. 1983. Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company, Inc., 291.
Vlaanderen J, van Veldhoven K, Font-Ribera L, . 2017. Acute changes in serum immune markers due to swimming in a chlorinated pool. Environ Int 105:1–11. 10.1016/j.envint.2017.04.009.28478232
Waller K, Swan SH, DeLorenze G, . 1998. Trihalomethanes in drinking water and spontaneous abortion. Epidemiology 9(2):134–140.9504280
Weaver WA, Li J, Wen Y, . 2009. Volatile disinfection by-product analysis from chlorinated indoor swimming pools. Water Res 43(13):3308–3318. 10.1016/j.watres.2009.04.035.19501873
WHO. 2000. Disinfectants and disinfectant by-products. Environmental Health Criteria 216. World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc216.htm. July 11, 2016.
WHO. 2006. Guidelines for safe recreational water environments. Volume 2. Swimming pools and similar environments. World Health Organization. Guidelines for safe recreational water environments. Volume 2. Swimming pools and similar environments. July 12, 2016.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Wilson JT, Enfield CG, Dunlap WJ, . 1981. Transport and fate of selected organic pollutants in a sandy soil. J Environ Qual 10:501–506.
+Windham GC, Waller K, Anderson M, . 2003. Chlorination by-products in drinking water and menstrual cycle function. Environ Health Perspect 111:935–941.12782495
WQP. 2017. Bromodichloromethane. Water quality portal. Advisory Committee on Water Information (ACWI); Agricultural Research Service (ARS); Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/portal/. April 5, 2017.
+Wright JM, Schwartz J, Dockery DW. 2004. The effect of disinfection by-products and mutagenic activity on birth weight and gestational duration. Environ Health Perspect 112(8):920–925.
Wright JM, Evans A, Kaufman JA, . 2017. Disinfection by-product exposures and the risk of specific cardiac birth defects. Environ Health Perspect 125(2):269–277. 10.1289/ehp103.27518881
Yalkowsky SH, He Y, Jain P. 2010. Bromodichloromethane. In: Handbook of aqueous solubility data. 2nd ed. Boca Raton, FL: Taylor & Francis Group, LLC, 1.
Yang P, Zeng Q, Cao WC, . 2016. Interactions between CYP2E1, GSTZ1 and GSTT1 polymorphisms and exposure to drinking water trihalomethanes and their association with semen quality. Environ Res 147:445–452. 10.1016/j.envres.2016.03.009.26970898
Yang P, Zhou B, Cao WC, . 2017. Prenatal exposure to drinking water disinfection by-products and DNA methylation in cord blood. Sci Total Environ 586:313–318. 10.1016/j.scitotenv.2017.01.224.28174046
Zeiger E. 1990. Mutagenicity of 42 chemicals in Salmonella. Environ Mol Mutagen 16(Suppl 18):32–54.
+Zeng Q, Li M, Xie SH, . 2013. Baseline blood trihalomethanes, semen parameters and serum total testosterone: A cross-sectional study in China. Environ Int 54:134–140. 10.1016/j.envint.2013.01.016.
Zhang L, Xu L, Zeng Q, . 2012. Comparison of DNA damage in human-derived hepatoma line (HepG2) exposed to the fifteen drinking water disinfection byproducts using the single cell gel electrophoresis assay. Mutat Res 741(1–2):89–94. 10.1016/j.mrgentox.2011.11.004.
Zhao G, Allis JW. 2002. Kinetics of bromodichloromethane metabolism by cytochrome P450 isoenzymes in human liver microsomes. Chem Biol Interact 140(2):155–168.12076522
Zoccolillo L, Amendola L, Cafaro C, . 2005. Improved analysis of volatile halogenated hydrocarbons in water by purge-and-trap with gas chromatography and mass spectrometric detection. J Chromatogr A 1077(2):181–187.16001554