# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Susan Zells Ingber, A.B., M.S.P.P. (Lead)
  Melanie Buser, M.P.H.
- ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA
- Lisa Ingerman, Ph.D., D.A.B.T.
  Christina Coley, B.S.
  Mario Citra, Ph.D.
  Fernando Llados, Ph.D.
  Laura A. McIlroy, B.A.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Health and Safety (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

ATSDR, Division of Community Health Investigations; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice; EPA, National Center for Environmental Assessment.

## PEER REVIEWERS

1. Bill L. Lasley, Ph.D., Center for Health and Environment, University of California, Davis, California;
2. David Savitz, Ph.D., Brown University, Providence, Rhode Island; and
3. June K. Dunnick, Ph.D., NIEHS, Research Triangle Park, North Carolina.

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.