# VERSION HISTORY

Date | Description
March 2020 | Final toxicological profile released
April 2018 | Draft for public comment toxicological profile released
December 1989 | Final toxicological profile released