# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding bromodichloromethane in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for bromodichloromethane.

Table 7-1 Regulations and Guidelines Applicable to Bromodichloromethane

Agency | Description | Information | Reference
Air
EPA | RfC | Not evaluated | IRIS 2002
EPA | Subchronic p-RfC | 0.02 mg/m^3^ ^a^ | EPA 2009a
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | 1-Day health advisory (10-kg child) | 1 mg/L | EPA 2018a
EPA | 10-Day health advisory (10-kg child) | 0.6 mg/L | EPA 2018a
EPA | DWEL | 0.1 mg/L | EPA 2018a
EPA | Lifetime health advisory | No data | EPA 2018a
EPA | 10^-4^ Cancer risk | 0.1 mg/L | EPA 2018a
EPA | National primary drinking water regulations | | EPA 2009b
EPA | MCL - Total trihalomethanes | 0.080 mg/L | EPA 2009b
EPA | MCLG - Bromodichloromethane | 0 mg/L | EPA 2009b
EPA | RfD | 0.02 mg/kg/day^b^ | IRIS 2002
EPA | Subchronic p-RfD | 0.008 mg/kg/day^c^ | EPA 2009a
WHO | Drinking water quality guidelines | | WHO 2017
WHO | Guideline value | 0.06 mg/L (60 μg/L) | WHO 2017
WHO | TDI | 21.4 μg/kg body weight | WHO 2017
FDA | Substances Added to Food | Not listed^d^ | FDA 2019
FDA | Allowable level for disinfection byproducts in bottled water – Total trihalomethanes | 0.080 mg/L | FDA 2017
Cancer
HHS | Carcinogenicity classification | Reasonably anticipated to be a human carcinogen | NTP 2016
EPA | Carcinogenicity classification | B2^e^ | IRIS 2002
IARC | Carcinogenicity classification | Group 2B^f^ | IARC 1999
Occupational
OSHA | PEL (8-hour TWA) for general industry | No data | OSHA 2018a
OSHA | PEL (8-hour TWA) for shipyards and construction | No data | OSHA 2018b
OSHA | PEL (8-hour TWA) for construction | No data | OSHA 2018c
NIOSH | REL (up to 10-hour TWA) | No data | NIOSH 2018
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018b
DOE | PACs-air | | DOE 2018a
DOE | PAC-1^g^ | 1.3 mg/m^3^ | DOE 2018a
DOE | PAC-2^g^ | 14 mg/m^3^ | DOE 2018a
DOE | PAC-3^g^ | 85 mg/m^3^ | DOE 2018a

a The subchronic p-RfC is based on a NOAEL of 20 mg/m^3^ for kidney degeneration in mice.

b The RfD is based on a LOAEL of 17.9 mg/kg/day for renal cytomegaly in a chronic mouse gavage bioassay.

c The subchronic p-RfD is based on pregnancy loss in gavage-treated rats.

d The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS.”

e B2: probable human carcinogen.

f Group 2B: possibly carcinogenic to humans.

g Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor Extract Manufacturer’s Association; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; LOAEL = lowest-observed-adverse-effect level; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; PPRTV = provisional peer-reviewed toxicity value; p-RfC = provisional inhalation reference concentration; p-RfD = provisional oral reference dose; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TDI = tolerable daily intake; TLV = threshold limit value; TWA = time-weighted average; WHO = World Health Organization