# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Bromodichloromethane is a trihalomethane with one bromide atom and two chloride atoms. It is a colorless liquid with relatively high vapor pressure and high water solubility. It was previously used as a halogenated fire retardant. Bromodichloromethane is a disinfection byproduct formed during the chlorination of waters.

Table 4-1 lists common synonyms, trade names, and other pertinent identification information for bromo-dichloromethane.

Table 4-1 Chemical Identity of Bromodichloromethane

Characteristic | Information | Reference
Chemical name | Bromodichloromethane | HSDB 2012
Synonym(s) and registered trade name(s) | Dichlorobromomethane; BDCM; monobromodichloromethane; methane, bromodichloro-; Halon 1021 | HSDB 2012; NIOSH 2015
Chemical formula | CHBrCl_2_ | HSDB 2012
Chemical structure | [image] | Haynes 2014
CAS Registry Number | 75-27-4 | HSDB 2012

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 4-2 lists important physical and chemical properties of bromodichloromethane.

Table 4-2 Physical and Chemical Properties of Bromodichloromethane

Property | Information | Reference
Molecular weight | 163.829 | Haynes 2014
Color | Colorless | O’Neil 2013
Physical state | Liquid | O’Neil 2013
Melting point | −56.0°C | Haynes 2014
Boiling point | 90°C | Haynes 2014
Density: | | Haynes 2014
at 20°C/4°C | 1.980
Odor | No data
Odor threshold:
Water | No data
Air | No data
Taste threshold | No data
Solubility:
Water | 3,030 mg/L at 30°C | Yalkowsky et al. 2010
Organic solvent(s) | Very soluble in ethanol, acetone, and benzene; slightly soluble in carbon tetrachloride | Haynes 2014
Partition coefficients:
Log K_ow_ | 2.00 | HSDB 2012
Log K_oc_ | 1.8 | Mabey et al. 1982
Vapor pressure
at 20°C | 50 mm Hg | HSDB 2012
Henry’s law constant | 2.12x10^-3^ at 25°C | EPA 1987
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Conversion factors | 1 ppm=6.70 mg/m^3^; 1 mg/m^3^=0.15 ppm | Verschueren 1977
Explosive limits | No data